# Appendix III - Additional Data Years Available

Click here for spreadsheet version (ftp://ftp.cdc.gov/pub/Health_Statistics/NCHS/Publications/Health_US/hus04tables/)

For trend tables spanning many years of data, only selected data years are shown in the printed book to highlight major trends. Additional years of data are available for some trend tables in spreadsheet files through the Internet and on a CD-ROM. In addition spreadsheet files with National Health Interview Survey data also include standard errors starting with data year 1997.

To access spreadsheet files on the Internet, go to the Health, United States Web site at www.cdc.gov/nchs/hus.htm and scroll down to “Spreadsheet files.” Spreadsheet files in Excel are presently available starting with Health, United States, 1995 through the current edition, Health, United States, 2004.

Excel spreadsheet files are also available on a CD-ROM. A limited supply of CD-ROMs is available from the National Center for Health Statistics upon request, while supplies last. CD-ROMs also may be purchased from the Government Printing Office.

The following list by table number and table topic specifies the additional data years, beyond those shown in the printed book, that are available in Excel spreadsheet files.

Table number | Table topic | Additional data years available
1 | Resident population | 1981–89, 1991–99
2 | Poverty | 1986–89, 1991–93, 1996–98
3 | Fertility rates and birth rates | 1981–84, 1986–89, 1991–94, 1996
4 | Live births | 1971–74, 1976–79, 1981–84, 1986–89, 1991–94, 1996–99
6 | Prenatal care | 1981–84, 1986–89, 1991–94, 1996
8 | Teenage childbearing | 1981–84, 1986–89, 1991–94, 1996
9 | Nonmarital childbearing | 1981–84, 1986–89, 1991–94, 1996
10 | Maternal education | 1981–84, 1986–89, 1991–94, 1996
11 | Maternal smoking | 1991–94, 1996
12 | Low birthweight | 1981–84, 1986–89, 1991–94, 1996
13 | Low birthweight | 1991–94, 1996
16 | Abortions | 1981–84, 1986–89, 1991–94
19 | Infant mortality rates | 1984, 1986–89, 1991, 1996–97
20 | Infant mortality rates | 1984, 1985–89, 1991, 1996–99
21 | Infant mortality rates | 1984, 1986–89, 1992–94, 1996
22 | Infant mortality rates | 1981–84, 1986–89, 1991–94
27 | Life expectancy | 1975, 1981–84, 1986–89
29 | Age-adjusted death rates for selected causes | 1981–89, 1991–94, 1996–99
30 | Years of potential life lost | 1991–94, 1996–97, 1999; Crude 1999–2000
35 | Death rates for all causes | 1981–89, 1991–94, 1996–97
36 | Diseases of heart | 1981–89, 1991–94, 1996–99
37 | Cerebrovascular diseases | 1981–89, 1991–94, 1996–99
38 | Malignant neoplasms | 1981–89, 1991–94, 1996–99
39 | Malignant neoplasms of trachea, bronchus, and lung | 1981–89, 1991–94, 1996–99
40 | Malignant neoplasm of breast | 1981–89, 1991–94, 1996–99
41 | Chronic lower respiratory diseases | 1981–89, 1991–94, 1996–97
42 | Human immunodeficiency virus (HIV) disease | 1988–89, 1991–94, 1996–97
43 | Maternal mortality | 1981–89, 1991–94, 1996–98
44 | Motor vehicle-related injuries | 1981–89, 1991–94, 1996–99
45 | Homicide | 1981–89, 1991–94, 1996–99
46 | Suicide | 1981–89, 1991–94, 1996–99
47 | Firearm-related injuries | 1981–89, 1991–94, 1996–99
48 | Occupational diseases | 1981–84, 1986–89, 1991–94, 1996–98
49 | Occupational injury deaths | 1983, 1994
50 | Occupational injuries | 1981–84, 1986–89, 1991–94, 1996
51 | Notifiable diseases | 1985, 1988–89, 1991–94, 1996–98
56 | Limitation of activity | 2000
57 | Respondent-assessed health status | 1998
60 | Cigarette smoking | 1983, 1987–88, 1991–94
61 | Cigarette smoking | 1983, 1987–88, 1991–94
62 | Cigarette smoking | 1993–95, 1994–97, 1999–2001
64 | Use of selected substances | 1981–89, 1992–94, 1996–98
65 | Cocaine-related emergency department episodes | 1992–94, 1996
66 | Alcohol consumption | 1998, 2000–2001
71 | Health care visits | 1998, 2000–2001
75 | No usual source of health care | 1995–96, 1997–98
76 | Emergency department visits for children | 1998, 2000–2001
78 | Emergency department visits for adults | 1998, 2000
79 | Dental visits | 1998, 2000–2001
83 | Ambulatory care visits | 1997–99
84 | Injury-related visits | 1997–98, 1999–2000, 2000–2001
85 | Ambulatory care visits | 1980, 1997–2001
89 | Additions to mental health organizations | 1992
92 | Discharges | 1998, 2000–2001
93 | Discharges | 1991–94, 1996, 1999
95 | Rates of discharges | 1995–99, 2001
96 | Discharges | 1995–99, 2001
98 | Hospital admissions | 1985, 1991–94, 1996–98
99 | Nursing home residents | 1997
100 | Nursing home residents | 1997
103 | Physicians | 1970, 1980, 1987, 1989, 1990, 1992–94, 1996–97
104 | Primary care doctors of medicine | 1994, 1996–98
106 | Health professions schools | 1996, 2000
109 | Hospitals | 1985, 1991–94, 1996–98
111 | Community hospital beds | 1985, 1988–89, 1995–99, 2001
112 | Occupancy rates | 1985, 1988–89, 1995–99, 2001
113 | Nursing homes | 1996–99, 2001
120 | Expenditures for health care | 1996, 1998
121 | Sources of payment for health care | 1996, 1998
124 | Employers’ costs and health insurance | 1992–93, 1995–95
125 | Hospital expenses | 1975, 1985, 1991–94, 1996–98
126 | Nursing home average monthly charges | 1977, 1997
129 | Private health insurance | 1994, 1996
130 | Medicaid coverage | 1994
131 | No health insurance coverage | 1994, 1996
132 | Health care coverage | 1984, 1994, 1996–98
133 | Health maintenance organization | 1997
134 | Health maintenance organizations | 1984–87, 1989, 1991–94, 1997
138 | Medicare | 1993–99
139 | Medicaid | 1975, 1985–89, 1991–94, 1996
140 | Medicaid | 1975, 1985–89, 1991–94, 1996
141 | Department of Veterans Affairs | 1985, 1988–89, 1991–94, 1996–98
142 | Personal health care per capita expenditures | 1992–93
143 | Hospital care per capita expenditures | 1992–93
144 | Physician services per capita expenditures | 1992–93
145 | Nursing home care per capita expenditures | 1992–93
146 | Drugs per capita expenditures | 1992–93
150 | Medicare | 1995–99
151 | Medicaid | 1998, 2000
152 | Health maintenance organizations | 1994, 1996–99
153 | Persons without health insurance coverage | 1992–94, 1996