# Appendix I - Data Sources

Government sources:

Abortion Surveillance AIDS Surveillance Census of Fatal Occupational Injuries (CFOI) Consumer Price Index (CPI) Current Population Survey (CPS) Department of Veterans Affairs National Patient Care Database and National Enrollment Database Drug Abuse Warning Network (DAWN) Employee Benefits SurveySee National Compensation Survey Medicaid Data System Medical Expenditure Panel Survey (MEPS) Medicare Administrative Data Medicare Current Beneficiary Survey (MCBS) Monitoring the Future Study (MTF) National Ambulatory Medical Care Survey (NAMCS) National Compensation Survey National Health Accounts National Health Care Survey (NHCS) National Health and Nutrition Examination Survey (NHANES) National Health Interview Survey (NHIS) National Health Provider Inventory (NHPI) National Home and Hospice Care Survey (NHHCS) National Hospital Ambulatory Medical Care Survey (NHAMCS) National Hospital Discharge Survey (NHDS) National Immunization Survey (NIS) National Medical Expenditure Survey (NMES)See Medical Expenditure Panel Survey National Notifiable Disease Surveillance System (NNDSS) National Nursing Home Survey (NNHS) National Survey on Drug Use & Health (NSDUH) National Survey of Family Growth (NSFG) National Survey of Substance Abuse Treatment Services (N-SSATS) National Vital Statistics System (NVSS) Online Survey Certification and Reporting Database (OSCAR) Population Census and Population Estimates Sexually Transmitted Disease (STD) Surveillance Surveillance, Epidemiology, and End Results Program (SEER) Survey of Mental Health Organizations (SMHO) Survey of Occupational Injuries and Illnesses (SOII) Youth Risk Behavior Survey (YRBS)

Private and global sources:

Alan Guttmacher Institute Abortion Provider Survey American Association of Colleges of Pharmacy American Association of Colleges of Podiatric Medicine American Dental Association American Hospital Association Annual Survey of Hospitals American Medical Association Physician Masterfile Association of American Medical Colleges Association of Schools and Colleges of Optometry Association of Schools of Public Health European Health for All Database InterStudy National Health Maintenance Organization Census National League for Nursing Organization for Economic Cooperation and Development Health Data United Nations Demographic Yearbook World Health Statistics Annual

This report consolidates the most current data on the health of the population of the United States, the availability and use of health resources, and health care expenditures. Information was obtained from data files and published reports of many Federal Government and private and global agencies and organizations. In each case, the sponsoring agency or organization collected data using its own methods and procedures. Therefore, data in this report vary considerably with respect to source, method of collection, definitions, and reference period.

Although a detailed description and comprehensive evaluation of each data source are beyond the scope of this Appendix, users should be aware of the general strengths and weaknesses of the different data collection systems. For example, population-based surveys obtain socioeconomic data, data on family characteristics, and information on the impact of an illness, such as days lost from work or limitation of activity. These data are limited by the amount of information a respondent remembers or is willing to report. A respondent may not know detailed medical information, such as precise diagnoses or the types of operations performed, and therefore cannot report it. Health care providers, such as physicians and hospitals, usually have good diagnostic information but little or no information about the socioeconomic characteristics of individuals or the impact of illnesses on individuals.

The populations covered by different data collection systems may not be the same, and understanding the differences is critical to interpreting the data. Data on vital statistics and national expenditures cover the entire population. Most data on morbidity and utilization of health resources cover only the civilian noninstitutionalized population. Such statistics may not include data for military personnel, who are usually young; for institutionalized people, who may be any age; or for nursing home residents, who are usually old.

All data collection systems are subject to error, and records may be incomplete or contain inaccurate information. People may not remember essential information, a question may not mean the same thing to different respondents, and some institutions or individuals may not respond at all. It is not always possible to measure the magnitude of these errors or their effect on the data. Where possible, table notes describe the universe and method of data collection to enable the user to place his or her evaluation on the data quality.

Some information is collected in more than one survey, and estimates of the same statistic may vary among surveys because of different survey methodologies, sampling frames, questionnaires, definitions, and tabulation categories. For example, cigarette use is measured by the National Health Interview Survey, the National Survey on Drug Use & Health, the Monitoring the Future Survey, and the Youth Risk Behavior Survey, which use slightly different questions for persons of differing ages and interview in different settings (at school versus at home), so estimates will differ.

Overall estimates generally have relatively small sampling errors, but estimates for certain population subgroups may be based on small numbers and have relatively large sampling errors. Numbers of births and deaths from the vital statistics system represent complete counts (except for births in those States where data are based on a 50-percent sample for certain years). Therefore, they are not subject to sampling error. However, when the figures are used for analytical purposes, such as the comparison of rates over a period, the number of events that actually occurred may be considered as one of a large series of possible results that could have arisen under the same circumstances. When the number of events is small and the probability of such an event is rare, estimates may be unstable and considerable caution must be observed in interpreting the statistics. Estimates that are unreliable because of large sampling errors or small numbers of events are noted with asterisks in selected tables. The criteria used to designate unreliable estimates are indicated in notes to the applicable tables.

Government data sources are listed alphabetically by data set name; private and global sources are listed separately. To the extent possible, government data systems are described using a standard format. “Overview” is a brief, general statement about the purpose or objectives of the data system. “Selected Content” lists major data elements that are collected or estimated using interpolation or modeling. “Data Years” gives the years that the survey or data system has existed or been fielded. “Coverage” describes the population that the data system represents; for example, residents of the United States, the noninstitutionalized population, persons in specific population groups, or other entities that comprise the survey. The “Methodology” section presents a short description of methods used to collect data. “Sample Size and Response Rates” are given for surveys. “Issues Affecting Interpretation” describes major changes in the data collection methodology or other factors that must be considered when analyzing trends—for example, a major survey redesign that may introduce a discontinuity in the trend. For more information about the methodology, data files, and history of a data source, consult the “References” and Web sites at the end of each summary. For more information about private and global organizations’ data sources, refer to the organization’s Web sites.

## Government Sources

### Abortion Surveillance

#### Centers for Disease Control and Prevention

##### National Center for Chronic Disease Prevention and Health Promotion

Overview: The abortion surveillance program documents the number and characteristics of women obtaining legal induced abortions, monitors unintended pregnancy, and assists efforts to identify and reduce preventable causes of morbidity and mortality associated with abortions.

Selected Content: Content includes age, race/ethnicity, marital status, previous live births, period of gestation, and previous induced abortions of women obtaining legal induced abortions.

Data Years: Between 1973 and 1997, the number of abortions is based on reporting from 52 reporting areas: 50 States, the District of Columbia, and New York City. In 1998 and 1999, CDC compiled abortion data from 48 reporting areas: Alaska, California, New Hampshire, and Oklahoma did not report, and data for these areas were not estimated. In 2000, Oklahoma again reported these data, increasing the number of reporting areas to 49.

Coverage: The system includes women of all ages, including adolescents, who obtain legal induced abortions.

Methodology: Beginning with data year 2000, data concerning the number and characteristics of women who obtain legal induced abortions are provided for 49 reporting areas by central health agencies such as State health departments and the health departments of New York City and the District of Columbia, and by hospitals and other medical facilities. In general, the procedures are reported by the State in which the procedure is performed (i.e., state of occurrence). In 2000, three states (Delaware, Maryland, and Wisconsin) reported characteristics only for women who were residents and who obtained abortions in the State. One State (Iowa) provided numbers and characteristics only for state residents. While the total number of legal induced abortions is available for those 49 reporting areas, not all areas collect information on the characteristics of women who obtain abortions. The number of areas reporting each characteristic and the number of areas with complete data for each characteristic vary from year to year. For example, in 2000, the number of areas reporting different characteristics ranged from 26 areas reporting Hispanic ethnicity and 37 areas reporting race and marital status to 47 areas reporting age. Data from reporting areas with more than 15 percent unknown for a given characteristic are excluded from the analysis of that characteristic.

Issues Affecting Interpretation: Between 1989 and 1997, the total number of abortions reported to CDC was about 10 percent less than the total estimated independently by the Alan Guttmacher Institute (AGI), a not-for-profit organization for reproductive health research, policy analysis, and public education. In 1998–99, the total number of abortions reported to CDC was about 33 percent less than the total estimated by AGI. The four reporting areas (the largest of which was California) that did not report abortions to CDC in 1998 accounted for 18 percent of all abortions tallied by AGI’s 1995–96 survey. See Appendix I, Alan Guttmacher Institute Abortion Provider Survey.

##### Reference

Centers for Disease Control and Prevention, CDC Surveillance Summaries, November 2003. MMWR 2002;52 (NoSS-12), Abortion Surveillance—United States, 2000.
For More Information: See the NCCDPHP surveillance and research Web site at www.cdc.gov/nccdphp/drh/surveil.htm.

### AIDS Surveillance

#### Centers for Disease Control and Prevention

##### National Center for HIV, STD, and TB Prevention

Overview: Acquired immunodeficiency syndrome (AIDS) surveillance data are used to detect and monitor cases of human immunodeficiency virus (HIV) disease and AIDS in the United States, identify epidemiologic trends, identify unusual cases requiring follow-up, and inform public health efforts to prevent and control the disease.

Selected Content: Data collected on cases diagnosed with AIDS include age, sex, race/ethnicity, mode of exposure, and geographic region.

Data Years: Reports on AIDS cases are available from the beginning of the epidemic in 1981.

Coverage: All 50 States, the District of Columbia, U.S. dependencies and possessions, and independent nations in free association with the United States report AIDS cases to CDC using a uniform surveillance case definition and case report form.

Methodology: AIDS surveillance is conducted by health departments in each State or territory and the District of Columbia. Although surveillance activities range from passive to active, most areas employ multifaceted active surveillance programs, which include four major reporting sources of AIDS information: hospitals and hospital-based physicians, physicians in nonhospital practice, public and private clinics, and medical record systems (death certificates, tumor registries, hospital discharge abstracts, and communicable disease reports). Using a standard confidential case report form, the health departments collect information that is then transmitted electronically without personal identifiers to CDC.

Issues Affecting Interpretation: Although completeness of reporting of AIDS cases to State and local health departments differs by geographic region and patient population, studies conducted by State and local health departments indicate that the reporting of AIDS cases in most areas of the United States is more than 85 percent complete.

The original definition of AIDS was modified in 1985 and 1987. The case definition for adults and adolescents was modified again in 1993. The revisions incorporated a broader range of AIDS-indicator diseases and conditions and used HIV diagnostic tests to improve the sensitivity and specificity of the definition. Laboratory and diagnostic criteria for the 1987 pediatric case definition were updated in 1994. Effective January 2000, the surveillance case definition for HIV infection was revised to reflect advances in laboratory HIV virologic tests. The definition incorporates the reporting criteria for HIV infection and AIDS into a single case definition for adults and children.

Decreases in AIDS incidence and in the number of AIDS deaths, first noted in 1996, have been ascribed to the effect of new treatments, which prevent or delay the onset of AIDS and premature death among HIV-infected persons and result in an increase in the number of persons living with HIV and AIDS. A growing number of States require confidential reporting of persons with HIV infection and participate in CDC’s integrated HIV/AIDS surveillance system that compiles information on the population of persons newly diagnosed and living with HIV infection.

##### Reference

Centers for Disease Control and Prevention, HIV/AIDS Surveillance Report, published annually at www.cdc.gov/hiv/stats/hasrlink.htm.
For More Information: See the NCHSTP Web site at www.cdc.gov/nchstp/od/nchstp.html.

### Census of Fatal Occupational Injuries (CFOI)

#### Bureau of Labor Statistics

Overview: The Census of Fatal Occupational Injuries (CFOI) compiles comprehensive and timely information on fatal work injuries occurring in the 50 States and the District of Columbia to monitor workplace safety and to inform private and public health efforts to improve workplace safety.

Selected Content: Information is collected about each workplace fatality, including occupation and other worker characteristics, equipment involved, and circumstances of the event.

Data Years: Data have been collected annually since 1992.

Coverage: The data cover all 50 States and the District of Columbia.

Methodology: CFOI is administered by the Bureau of Labor Statistics (BLS) in conjunction with participating State agencies to compile counts that are as complete as possible to identify, verify, and profile fatal work injuries. Key information about each workplace fatality (occupation and other worker characteristics, equipment or machinery involved, and circumstances of the event) is obtained by cross-referencing source records. For a fatality to be included in the census, the decedent must have been employed (that is, working for pay, compensation, or profit) at the time of the event, engaged in a legal work activity, or present at the site of the incident as a requirement of his or her job. These criteria are generally broader than those used by Federal and State agencies administering specific laws and regulations. Fatalities that occur during a person’s commute to or from work are excluded from the census counts.

Data for the CFOI are compiled from various Federal, State, and local administrative sources—including death certificates, workers’ compensation reports and claims, reports to various regulatory agencies, medical examiner reports, and police reports—as well as news reports. Diverse sources are used because studies have shown that no single source captures all job-related fatalities. Source documents are matched so that each fatality is counted only once. To ensure that a fatality occurred while the decedent was at work, information is verified from two or more independent source documents or from a source document and a follow-up questionnaire.

Issues Affecting Interpretation: The number of occupational fatalities and fatality rates are periodically revised. States have up to 1 year to update their initial published State counts. States may identify additional fatal work injuries after data collection closeout for a reference year. In addition, other fatalities excluded from the published count because of insufficient information to determine work relationship may subsequently be verified as work-related. Increases in the published counts based on additional information have averaged less than 100 fatalities per year, or less than 1.5 percent of the total.

##### Reference

Bureau of Labor Statistics. National Census of Fatal Occupational Injuries, 2002. Washington, DC: U.S. Department of Labor. August 2003.
For More Information: See the CFOI Web site at www.bls.gov/iif/oshcfoi1.htm.

### Consumer Price Index (CPI)

#### Bureau of Labor Statistics

Overview: The Consumer Price Index (CPI) is designed to produce a monthly measure of the average change in the prices paid by urban consumers for a fixed market basket of goods and services.

Selected Content: Price indexes are available for the United States, the four census regions, size of city, cross-classifications of regions and size-classes, and 26 local areas. Indexes are available for major groups of consumer expenditures (food and beverages, housing, apparel, transportation, medical care, recreation, education and communications, and other goods and services), for items within each group, and for special categories, such as services. Monthly indexes are available for the United States, the four census regions, and some local areas. More detailed item indexes are available for the United States than for regions and local areas. Indexes are available for two population groups: a CPI for All Urban Consumers (CPI-U) which covers approximately 87 percent of the total population, and a CPI for Urban Wage Earners and Clerical Workers (CPI-W), which covers 32 percent of the population.

Data Years: The index has been constructed annually since 1978.

Coverage: The all-urban index (CPI-U) introduced in 1978 covers residents of metropolitan areas as well as residents of urban parts of nonmetropolitan areas (about 87 percent of the U.S. population in 2000).

Methodology: In calculating the index, price changes for the various items in each location were averaged together with weights that represent their importance in the spending of all urban consumers. Local data were then combined to obtain a U.S. city average.

The index measures price changes from a designated reference date, 1982–84, which equals 100. An increase of 22 percent, for example, is shown as 122. Change can also be expressed in dollars as follows: the price of a base period “market basket” of goods and services bought by all urban consumers has risen from $100 in 1982–84 to $184 in 2003.

The current revision of the CPI, completed in 2000, reflects spending patterns based on the Survey of Consumer Expenditures from 1993 to 1995, the 1990 Census of Population, and the ongoing Point-of-Purchase Survey. Using an improved sample design, prices for the goods and services required to calculate the index are collected in urban areas throughout the country and from retail and service establishments. Data on rents are collected from tenants of rented housing and residents of owner-occupied housing units. Food, fuels, and other goods and services are priced monthly in urban locations. Price information is obtained through visits or calls by trained BLS field representatives using computer-assisted telephone interviews.

Issues Affecting Interpretation: A 1987 revision changed the treatment of health insurance in the cost-weight definitions for medical care items. This change has no effect on the overall index result but provides a clearer picture of the role of health insurance in the CPI. As part of the revision, three new indexes have been created by separating previously combined items, for example, eye care is separated from other professional services, and inpatient and outpatient treatment is separated from other hospital and medical care services.

Effective January 1997 the hospital index was restructured by combining the three categories—room, inpatient services, and outpatient services—into one category: hospital services. In addition new procedures for hospital data collection identify a payor, diagnosis, and the payor’s reimbursement arrangement from selected hospital bills.

##### References

Bureau of Labor Statistics. Handbook of Methods. BLS Bulletin 2490. Washington, DC: U.S. Department of Labor. April 1997; Revising the Consumer Price Index, Monthly Labor Review, Dec 1996.
U.S. Department of Labor, Bureau of Labor Statistics, Washington, DC; IK Ford and D Ginsburg, Medical Care and the Consumer Price Index, National Bureau of Economic Research, Research Studies in Income and Wealth vol. 62.
For More Information: See the BLS/CPI Web site at www.bls.gov/cpi/home.htm.

### Current Population Survey (CPS)

#### Bureau of the Census

##### Bureau of Labor Statistics

Overview: The Current Population Survey (CPS) provides current estimates and trends in employment, unemployment, and other characteristics of the general labor force, the population as a whole, and various population subgroups.

Selected Content: Estimates of poverty and health insurance coverage presented in Health, United States are derived from the Annual Social and Economic Supplement (ASEC), formerly called the Annual Demographic Supplement (ADS), or simply the “March Supplement.” The ASEC includes a series of questions asked each March in addition to core CPS questions. Information is gathered on more than 50 different sources of income, including noncash income sources such as food stamps, school lunch program, employer-provided group health insurance plan, employer-provided pension plan, personal health insurance, Medicaid, Medicare, CHAMPUS or military health care, and energy assistance. Comprehensive work experience information is given on the employment status, occupation, and industry of persons interviewed.

Data Years: The basic CPS has been conducted since 1945, although some data were collected prior to that time. Collection of income data began in 1948.

Coverage: The CPS sample is located in 754 sample areas, with coverage in every State and the District of Columbia. The adult universe (i.e., population of marriageable age) is composed of persons 15 years of age and over in the civilian noninstitutionalized population for CPS labor force data. The sample for the March CPS supplement is expanded to include members of the Armed Forces who are living in civilian housing or with their family on a military base, as well as additional Hispanic households that are not included in the monthly labor force estimates.

Methodology: The basic CPS sample is selected from multiple frames using multiple stages of selection. Each unit is selected with a known probability to represent similar units in the universe. The sample design is a State-based design, with the sample in each State being independent of the others.

The additional Hispanic sample is from the previous November’s basic CPS sample. If a person is identified as being of Hispanic origin from the November interview and is still residing at the same address in March, that housing unit is eligible for the March survey. This amounts to a near doubling of the Hispanic sample since there is no overlap of housing units between the basic CPS samples in November and March.

For all CPS data files a single weight is prepared and used to compute the monthly labor force status estimates. An additional weight was prepared for the earnings universe that roughly corresponds to wage and salary workers in the two outgoing rotations. The difference in content of the March CPS supplement requires the presentation of additional weights: a household weight, a family weight, and a March supplement weight. The final weight is the product of (1) the basic weight, (2) adjustments for special weighting, (3) noninterview adjustment, (4) first-stage ratio adjustment factor, and (5) second-stage ratio adjustment factor. This final weight should be used when producing estimates from the basic CPS data. Differences in the questionnaire, sample, and data uses for the March CPS supplement result in the need for additional adjustment procedures to produce what is called the March supplement weight.

Sample Size and Response Rate: Beginning with 2001, the State Children’s Health Insurance Program (SCHIP) sample expansion was introduced. This included an increase in the basic CPS sample to 60,000 households per month. Prior to 2001 estimates were based on 50,000 households per month. The expansion also included an additional 12,000 households that were allocated differentially across States, based on prior information of the number of uninsured children in each State, to produce statistically reliable current State data on the number of low-income children who do not have health insurance coverage. In an average month the nonresponse rate for the basic CPS is about 6–7 percent.

Issues Affecting Interpretation: Over the years, the number of income questions has expanded, questions on work experience and other characteristics have been added, and the month of interview was moved to March.

In 1994 major changes were introduced, which included a complete redesign of the questionnaire including new health insurance questions and the introduction of computer-assisted interviewing for the entire survey. In addition, there were revisions to some of the labor force concepts and definitions. Prior to the redesign, CPS data were primarily collected using a paper-and-pencil form. Beginning in 1994, new population controls were used based on the 1990 census and adjusted for the estimated population undercount. Starting with Health, United States, 2003, poverty estimates for 2000 were recalculated based on the expanded SCHIP sample, and beginning with 2000 data, census 2000-based population controls were implemented. Beginning with 2002 data, 1997 race standards were implemented in which people could report more than one race.

##### References

U.S. Census Bureau. Technical Paper 63RV. Current Population Survey: Design and Methodology. TP63RV, March 2002 found at www.census.gov/prod/2002pubs/tp63rv.pdf.
For More Information: See the CPS Web site at www.bls.census.gov/cps/cpsmain.htm.

### Department of Veterans Affairs National Patient Care Database and National Enrollment Database

#### Department of Veterans Affairs

Overview: The Department of Veterans Affairs (VA) compiles and analyzes multiple data sets on the health and health care of its clients and other veterans to monitor access and quality of care and to conduct program and policy evaluations.

Selected Content: VA maintains the National Patient Care Database (NPCD) and the National Enrollment Database (NED).

The NPCD is a nationwide system that contains a statistical record for each episode of care provided under VA auspices in VA and non-VA hospitals, nursing homes, VA residential rehabilitation treatment programs (formerly called domiciliaries), and VA outpatient clinics. Three major extracts from the NPCD are the patient treatment file (PTF), the patient census file, and the outpatient clinic file (OPC).

The patient treatment file (PTF) collects data at the time of the patient’s discharge on each episode of inpatient care provided to patients at VA hospitals, VA nursing homes, VA residential rehabilitation treatment programs, community nursing homes, and other non-VA facilities. The PTF record contains the scrambled social security number, dates of inpatient treatment, date of birth, State and county of residence, type of disposition, place of disposition after discharge, and ICD–9–CM diagnostic and procedure or operative codes for each episode of care.

The patient census file collects data on each patient remaining in a VA medical facility at midnight at the end of each quarter of the fiscal year. The census record includes information similar to that reported in the PTF record.

The outpatient clinic file (OPC) collects data on each instance of medical treatment provided to a veteran in an outpatient setting. The OPC record includes the age, scrambled social security number, State and county of residence, VA eligibility code, clinic(s) visited, purpose of visit, and date of visit for each episode of care.

The VA also maintains the National Enrollment Database (NED) as the official repository of enrollment information for each veteran enrolled in the VA health care system.

Coverage: U.S. veterans who receive services within the VA medical system are included. Data are available for some nonveterans who receive care at VA facilities.

Methodology: NPCD is the source data for the Veterans Health Administration (VHA) Medical SAS Datasets. NPCD is the VHA’s centralized relational database (a data warehouse) that receives encounter data from VHA clinical information systems. It is updated daily. Data are collected locally at each VA medical center and are transmitted electronically to the VA Austin Automation Center for use in providing nationwide statistics, reports, and comparisons.

In all of the medical data sets each patient has a unique identifier, which is a formula-based encryption of the individual’s social security number (SSN). The identifier is consistent for a given patient across data sets and fiscal years. An extract containing selected information from the NPCD, the NED, and the cost distribution system is produced by the Austin Automation Center.

Issues Affecting Interpretation: The databases include users of the VA health care system. VA eligibility is a hierarchy based on service-connected disabilities, income, age, and availability of services. Therefore, different VA programs may serve populations with different sociodemographic characteristics than other health care systems.

For More Information: See the VHA Information Systems Web site at www.virec.research.med.va.gov/Support/Training-newUsersToolkit/IntroToVAData.htm.

### Drug Abuse Warning Network (DAWN)

#### Substance Abuse and Mental Health Services Administration

Overview: Drug Abuse Warning Network (DAWN) is a national public health surveillance system that monitors trends in drug-related emergency department visits and deaths. It also collects data on drug-related deaths from medical examiner and coroner (ME/C) jurisdictions throughout the country. It determines drug-abuse patterns and trends, identifies substances associated with drug-abuse episodes, and assesses drug-related consequences and other health hazards.

Selected Content: For each reportable case, limited information—including patient demographics, reason for ED visit, and the drug(s) involved—is abstracted from visit records. DAWN collects detailed data on use of drugs, including illegal drugs, nonmedical use of prescription and over-the-counter medications, dietary supplements, and nonpharmaceutical inhalants.

Data Years: DAWN data have been collected annually since 1988.

Coverage: Hospitals eligible for DAWN are non-Federal, short-stay general hospitals that have a 24-hour emergency department. The DAWN emergency department data have been collected from a representative sample of eligible hospitals located throughout the coterminous United States, including 21 oversampled metropolitan areas.

Methodology: Within each facility, a designated DAWN reporter is responsible for identifying eligible drug-abuse episodes by reviewing emergency department records and abstracting and submitting data on each reportable case. To be included in DAWN, the patient presenting to the ED must meet all of the following four criteria: (a) patient was between ages 6 and 97 years and was treated in the hospital’s ED; (b) patient’s presenting problem(s) for the ED visit was induced by or related to drug use, regardless of when drug use occurred; (c) episode involved use of an illegal drug or use of a legal drug or other chemical substance contrary to directions; (d) patient’s reason for using the substance(s) was dependence, suicide attempt or gesture, and/or psychic effect. DAWN cases include drug abuse and misuse, adverse reactions, accidental ingestion, overmedication, malicious poisoning, suicide attempts, underage drinking, and patients seeking detoxification or drug abuse treatment. Patients are never interviewed. All data are collected through a retrospective review of patient medical records and decedent case files.

Sample Size and Response Rate: In 2002 the DAWN emergency department sample consisted of 549 eligible hospitals. Of these, 437 (80 percent) participated in DAWN. Response rates in the 21 metropolitan areas ranged from 65 percent to 100 percent, with 7 metropolitan areas having response rates below 75 percent. The 2002 sample of hospitals submitted data on 189,616 drug abuse episodes, with an average of 1.8 drug mentions per episode.

Issues Affecting Interpretation: Estimates reported in this publication are from the hospital ED component of DAWN. Participation in DAWN is voluntary, and there are minor variations in the number of participating hospitals from year to year. The number of ED episodes reported to DAWN is not equivalent to the number of individual patients, because one person may make repeated visits to an ED. DAWN does not measure the frequency or prevalence of drug use.

##### Reference

Substance Abuse and Mental Health Services Administration, Office of Applied Studies. Emergency Department Trends From the Drug Abuse Warning Network, Final Estimates 1995–2002. DAWN Series: D-24, DHHS Pub. No. (SMA) 03–3780. Rockville, MD: Department of Health and Human Services. 2003.
For More Information: See the DAWN Web site at http://dawninfo.samhsa.gov.

### Employee Benefits Survey—See National Compensation Survey

### Medicaid Data System

#### Centers for Medicare & Medicaid Services

Overview: The Centers for Medicare & Medicaid Services (CMS) works with its State partners to collect data on persons served by the Medicaid program to monitor and evaluate access and quality of care, trends in program eligibility, characteristics of enrollees, changes in payment policy, and other program-related issues.

Selected Content: Data collected include medical vendor payments for Medicaid recipients by type of service and information on the characteristics of Medicaid recipients, including race/ethnicity, age, and basis of eligibility.

Data Years: Selected State data are available from 1992 on. Data for the 50 States and the District of Columbia are available from 1999 on.

Coverage: The data include individuals enrolled in the Medicaid program or receiving Medicaid benefits.

Methodology: The primary data sources for Medicaid statistical data are the Medicaid Statistical Information System (MSIS) and the CMS-64 reports.

MSIS is the basic source of State-reported eligibility and claims data on the Medicaid population, and their characteristics, utilization, and payments. Beginning in FY1999, as a result of legislation enacted from the Balanced Budget Act of 1997, States are required to submit individual eligibility and claims data tapes to CMS quarterly through the Medicaid Statistical Information System (MSIS). Prior to FY1999, States were required to submit an annual HCFA-2082 report, designed to collect aggregated statistical data on eligibles, recipients, services, and expenditures during a Federal fiscal year (October 1 through September 30). The data reported for each year represented people on the Medicaid rolls, recipients of Medicaid services, and payments for claims adjudicated during the year. The data reflected bills adjudicated or processed during the year, rather than services used during the year. States summarized and reported the data processed through their own Medicaid claims processing and payment operations, unless they opted to participate in MSIS, in which case the HCFA-2082 report was produced by the Health Care Financing Administration (the predecessor to CMS).

The CMS-64 is a product of the financial budget and grant system. The CMS-64 is a statement of expenditures for the Medicaid program that States submit to CMS 30 days after each quarter. The report is an accounting statement of actual expenditures made by the States for which they are entitled to receive Federal reimbursement under title XIX for that quarter. The amount claimed on the CMS-64 is a summary of expenditures derived from source documents such as invoices, cost reports, and eligibility records.

The CMS-64 shows the disposition of Medicaid grant funds for the quarter being reported and previous years, the recoupments made or refunds received, and income earned on grant funds. The data on the CMS-64 are used to reconcile the monetary advance made on the basis of States’ funding estimates filed prior to the beginning of the quarter on the CMS-37. As such, the CMS-64 is the primary source for making adjustments for any identified overpayments and underpayments to the States. Also incorporated into this process are disallowance actions forwarded from other Federal financial adjustments. Finally, the CMS-64 provides information that forms the basis for a series of Medicaid financial reports and budget analyses. Also included are third-party liability (TPL) collections tables. Third-party liability refers to the legal obligation of certain health care sources to pay the medical claims of Medicaid recipients before Medicaid pays these claims. Medicaid pays only after the TPL sources have met their legal obligation to pay.

Issues Affecting Interpretation: Health, United States Medicaid tables are based on MSIS data. Users of Medicaid data may note apparent inconsistencies in Medicaid data that are primarily a result of the difference in information captured in MSIS versus CMS-64 reports. The most substantive difference is caused by payments made to “disproportionate share hospitals.” Payments to disproportionate share hospitals do not appear in MSIS because States directly reimburse these hospitals and there is no fee-for-service billing. Other less significant differences between MSIS and CMS-64 occur because adjudicated claims data are used in MSIS versus actual payments reflected in the CMS-64. Differences also may occur because of internal State practices for capturing and reporting these data through two separate systems. Finally, national totals for the CMS-64 are different because they include other jurisdictions, such as the Northern Mariana Islands and American Samoa.

For More Information: See the CMS Web site at www.cms.hhs.gov/ or the Research Data Assistance Center (ResDAC) Web site at www.resdac.umn.edu/medicaid/data_available.asp. Also see Appendix II, Medicaid.

### Medical Expenditure Panel Survey (MEPS)

#### Agency for Healthcare Research and Quality

Overview: The Medical Expenditure Panel Survey (MEPS) produces nationally representative estimates of health care use, expenditures, sources of payment, insurance coverage, and quality of care for the U.S. civilian noninstitutionalized population.

Selected Content: MEPS data in Health, United States include total health care expenses and prescribed medicine expenses, presented by sociodemographic characteristics, type of health insurance, and sources of payment.

Data Years: The 1977 National Medical Care Expenditure Survey and the 1987 National Medical Expenditure Survey (NMES) are earlier versions of this survey. Since 1996, MEPS has been conducted on an annual basis.

Coverage: U.S. civilian noninstitutionalized population is the primary population represented. The 1987 and 1996 surveys also had an institutionalized population component.

Methodology: MEPS is a national probability survey conducted on an annual basis since 1996. The panel design of the survey features several rounds of interviewing covering 2 full calendar years. The MEPS consists of three components: the Household, the Medical Provider, and the Insurance Components.

The Household Component (HC) is a nationally representative survey of the civilian noninstitutionalized population drawn from a subsample of households that participated in the prior year’s National Health Interview Survey conducted by the National Center for Health Statistics. Missing expenditure data are imputed using data collected in the Medical Provider Component whenever possible.

Data are collected in the Medical Provider Component (MPC) to improve the accuracy of expenditure estimates derived solely from the Household Component (HC). The MPC is particularly useful in obtaining expenditure information for persons enrolled in managed care plans and Medicaid recipients. The MPC collects data from hospitals, physicians, and home health providers that were reported in the HC as providing care to MEPS sample persons. Sample sizes for the MPC vary from year to year depending on the HC sample size and the MPC sampling rates for providers.

The Insurance Component (IC) consists of two subcomponent samples: a household sample and list sample. The household sample collects detailed information from employers on the health insurance held by and offered to respondents to the MEPS-HC. The list sample collects data on the types and costs of workplace health insurance from a total of about 40,000 business establishments and governments each year.

The Medical Expenditure Panel Surveys (MEPS) update the 1987 National Medical Expenditure Survey (NMES). The NMES consists of two components: the Household Survey (HS) and the Medical Provider Survey (MPS). The NMES-HS was designed to provide nationally representative estimates of health insurance status, health insurance coverage, and health care use for the U.S. civilian noninstitutionalized population for the calendar year 1987. Data from the NMES-MPS component were used in conjunction with HS data to produce estimates of health care expenditures. The NMES-HS consisted of four rounds of household interviews. Income was collected in a special supplement administered early in 1988. Events under the scope of the NMES-MPS included medical services provided by or under the direction of a physician, all hospital events, and home health care. The sample of events included in the NMES-MPS was all events for persons covered by Medicaid and for a 25 percent sample of NMES-HS respondents. Missing expenditure data were imputed.

Sample Size and Response Rate: For MEPS first core household interview, 17,500 households were selected. The sample sizes for the MEPS-HC are approximately 10,000 families in 1996 and 1998–2000, 13,500 families in 1997 and 2001, and 15,000 families annually beginning in 2002. The full-year household core response rate has generally been about 66 percent. The 12-month joint core questionnaire/health questionnaire/access supplement response rate for the household component of the NMES was 80 percent.

Issues Affecting Interpretation: The 1987 estimates are based on the NMES, and 1996–2000 estimates are based on the MEPS. Because expenditures in NMES were based primarily on charges while those for MEPS were based on payments, data for NMES were adjusted to be more comparable to MEPS using estimated charge-to-payment ratios for 1987. For a detailed explanation of this adjustment, see Zuvekas and Cohen, 2002.

##### References

National Medical Expenditure Survey: Hahn B and Lefkowitz D. Annual expenses and sources of payment for health care services. National Medical Expenditure Survey Research Findings 14, Agency for Healthcare Research and Quality Pub. No. 93–0007. Rockville, MD: Public Health Service. November 1992.
Medical Expenditure Panel Survey: Cohen SB. Sample design of the 1997 Medical Expenditure Panel Survey Household Component. MEPS Methodology Report No. 11. AHRQ Pub. No. 01–0001. Rockville MD: Agency for Healthcare Research and Quality. 2000.
Zuvekas S, Cohen S. (2002). A guide to comparing health care estimates in the 1996 Medical Expenditure Panel Survey to the 1987 National Medical Expenditure Survey. Inquiry.
For More Information: See the MEPS Web site at www.meps.ahrq.gov.

### Medicare Administrative Data

#### Centers for Medicare & Medicaid Services

Overview: The Centers for Medicare & Medicaid Services (CMS) collects and synthesizes Medicare enrollment, spending, and claims data to monitor and evaluate access to and quality of care, trends in utilization, changes in payment policy, and other program-related issues.

Selected Content: Data include claims information for services furnished to Medicare beneficiaries and Medicare enrollment data. Claims data include type of service, procedures, diagnoses, dates of service, and claim amount. Enrollment data include date of birth, sex, race/ethnicity, and reason for entitlement.

Data Years: Some data files are available as far back as 1987, but CMS no longer provides technical support for files with data prior to 1996.

Coverage: Enrollment data are for all persons enrolled in the Medicare program. Claims data include data for Medicare beneficiaries who filed claims.

Methodology: The claims and utilization data files contain extensive utilization information at various levels of summarization for a variety of providers and services. There are many types and levels of these files, including the National Claims History (NCH) files, the Standard Analytic Files (SAF), Medicare Provider and Analysis Review (MedPAR) files, Medicare enrollment files, and various other files.

The National Claims History (NCH) 100 Percent Nearline File contains all institutional and noninstitutional claims and provides records of every Medicare claim submitted, including adjustment claims. The Standard Analytical Files (SAFs) contain final action claims data in which all adjustments have been resolved. These files contain information collected by Medicare to pay for health care services provided to a Medicare beneficiary. SAFs are available for each institutional (inpatient, outpatient, skilled nursing facility, hospice, or home health agency) and noninstitutional (physician and durable medical equipment providers) claim type. The record unit of SAFs is the claim (some episodes of care may have more than one claim). SAF files include the Inpatient SAF, the Skilled Nursing Facility SAF, the Outpatient SAF, the Home Health Agency SAF, the Hospice SAF, the Clinical Laboratory SAF, and the Durable Medical Equipment SAF.

Medicare Provider and Analysis Review (MedPAR) files contain inpatient hospital and skilled nursing facility (SNF) final action stay records. Each MedPAR record represents a stay in an inpatient hospital or SNF. An inpatient “stay” record summarizes all services rendered to a beneficiary from the time of admission to a facility through discharge. Each MedPAR record may represent one claim or multiple claims, depending on the length of a beneficiary’s stay and the amount of inpatient services used throughout the stay.

The Denominator File contains demographic and enrollment information about each beneficiary enrolled in Medicare during a calendar year. The information in the Denominator File is “frozen” in March of the following calendar year. Some of the information contained in this file includes the beneficiary unique identifier, State and county codes, ZIP code, date of birth, date of death, sex, race, age, monthly entitlement indicators (for Medicare Part A, Medicare Part B, or Part A and Part B), reasons for entitlement, State buy-in indicators, and monthly managed care indicators (yes/no). The Denominator File is used to determine beneficiary demographic characteristics, entitlement, and beneficiary participation in Medicare Managed Care Organizations.

The Vital Status File contains demographic information about each beneficiary ever entitled to Medicare. Some of the information contained in this file includes the beneficiary unique identifier, State and county codes, ZIP code, date of birth, date of death, sex, race, and age. Often the Vital Status File is used to obtain recent death information for a cohort of Medicare beneficiaries.

The Group Health Plan (GHP) Master File contains data on beneficiaries who are currently enrolled or have ever been enrolled in a Managed Care Organization (MCO) under contract with CMS. Each record represents one beneficiary, and each beneficiary has one record. Some of the information contained in this file includes the Beneficiary Unique Identifier number, date of birth, date of death, State and county, and managed care enrollment information such as dates of membership and MCO contract number. The GHP Master File is used to identify the exact MCO in which beneficiaries were enrolled.

Issues Affecting Interpretation: Because Medicare managed care programs may not file claims, files based only on claims data will exclude care for persons enrolled in Medicare managed care programs. In addition, to maintain a manageable file size, some files are based on a sample of enrollees, rather than on all Medicare enrollees. Coding changes and interpretation of Medicare coverage rules have also changed over the life of the Medicare program.

For More Information: See the CMS Research Data Assistance Center (ResDAC) Web site at www.resdac.umn.edu/medicare/data_available.asp or the CMS Web site at http://cms.hhs.gov/data/default.asp. Also see Appendix II, Medicare.

### Medicare Current Beneficiary Survey (MCBS)

#### Centers for Medicare & Medicaid Services

Overview: The Medicare Current Beneficiary Survey (MCBS) produces nationally representative estimates of health status, health care use and expenditures, health insurance coverage, and socioeconomic and demographic characteristics of Medicare beneficiaries. It is used to estimate expenditures and sources of payment for all services used by Medicare beneficiaries, including co-payments, deductibles, and noncovered services; to ascertain all types of health insurance coverage and relate coverage to sources of payment; and to trace processes over time, such as changes in health status, spending down to Medicaid eligibility, and the effects of program changes.

Selected Content: The survey collects data on utilization of health services, health and functional status, health care expenditures, and health insurance and beneficiary information (such as income, assets, living arrangement, family assistance, and quality of life).

Data Years: The first round of interviewing was conducted from September through December 1991, and the survey has been continuously in the field since then. The data are designed to support both cross-sectional and longitudinal analyses.

Coverage: The MCBS is a continuous survey of a nationally representative sample of aged, institutionalized, and disabled Medicare beneficiaries.

Methodology: The longitudinal design of the survey allows each sample person to be interviewed three times a year for 4 years, whether he or she resides in the community or a facility or moves between the two settings, using the version of the questionnaire appropriate to the setting. Sample persons in the community are interviewed using computer-assisted personal interviewing (CAPI) survey instruments. Because long-term care facility residents often are in poor health, information about institutionalized patients is collected from proxy respondents such as nurses and other primary caregivers affiliated with the facility. The sample is selected from the Medicare enrollment files, with oversampling among disabled persons under age 65 and among persons 80 years of age and over.

Medicare claims are linked to survey-reported events to produce the Cost and Use file that provides complete expenditure and source of payment data on all health care services, including those not covered by Medicare. The Access to Care file contains information on beneficiaries’ access to health care, satisfaction with care, and usual source of care. The sample for this file represents the “always enrolled” population—those who participated in the Medicare program for the entire year. In contrast, the Cost and Use file represents the “ever enrolled” population, including those who enter Medicare during the year and those who died.

Sample Size and Response Rate: Each fall, about one-third of the sample is retired and roughly 6,000 new sample persons are included in the survey—the exact number chosen is based on projections of target samples of 12,000 persons with 3 years of cost and use information distributed appropriately across the sample cells. In the community, percentage response rates for initial interviews range in the mid- to high 80s; once respondents have completed the first interview, their participation in subsequent rounds is 95 percent or more. In recent rounds, data have been collected from approximately 15,000 to 19,000 beneficiaries, with the peaks occurring in Fall rounds because of the annual and HMO samples. Roughly 90 percent of the sample is made up of persons who live in the community, with the remaining persons living in long-term care facilities. Response rates for facility interviews approach 100 percent.

Issues Affecting Interpretation: Because only Medicare enrollees are included in the survey, the survey excludes a small proportion of persons age 65 and over who are not enrolled in Medicare, which should be noted when using the MCBS to make estimates of the entire population 65 and older in the United States.

##### Reference

Adler GS. (1994). A profile of the Medicare Current Beneficiary Survey. Health Care Financ Rev.
For More Information: See the MCBS Web site at www.cms.hhs.gov/mcbs/default.asp.

### Monitoring the Future Study (MTF)

#### National Institute on Drug Abuse

Overview: Monitoring the Future (MTF) is an ongoing study of the behaviors, attitudes, and values of American secondary school students, college students, and young adults.

Selected Content: Data collected include lifetime, annual, and 30-day prevalence of use of specific illegal drugs and substances, inhalants, tobacco, and alcohol. Data are also collected on usage levels, frequency of use, perceived risks associated with use, opinions about whether use is approved or disapproved by others, and opinions about availability of the substances.

Data Years: MTF has been conducted annually since 1975, initially with high school seniors; ongoing panel studies of representative samples from each graduating class have been conducted by mail since 1976; annual surveys of 8th and 10th graders were initiated in 1991.

Coverage: MTF surveys a sample of high school seniors, 10th graders, and 8th graders selected to be representative of all seniors, 10th graders, and 8th graders in public and private high schools in the continental United States.

Methodology: The survey design is a multistage random sample with stage one being selection of particular geographic areas, stage two selection of one or more schools in each area, and stage three selection of students within each school. Data are collected using self-administered questionnaires conducted in the classroom by representatives of the Institute for Social Research. Dropouts and students who are absent on the day of the survey are excluded (about 18 percent of high school seniors, about 12 percent of 10th graders, and about 10 percent of 8th graders in 2001). Recognizing that the dropout population is at higher risk for drug use, this survey was expanded to include similar nationally representative samples of 8th and 10th graders in 1991. Statistics that are published in the Dropout Rates in the United States: 2000 (published by the National Center for Educational Statistics, Pub. No. NCES 2002–114) stated that among persons 15–16 years of age, 2.9 percent have dropped out of school, and the dropout rate increases to 3.5 percent for persons 17 years of age, 6.1 percent for persons 18 years of age, and 9.6 percent for persons 19 years of age. Therefore, surveying 8th graders (where dropout rates are much lower than for high school seniors) should be effective for picking up students at higher risk for drug use.

Sample Size and Response Rates: In 2003 approximately 48,500 8th, 10th, and 12th graders in 392 schools were surveyed. The annual senior samples comprised roughly 15,200 seniors in 122 public and private high schools nationwide. The 10th-grade samples involved about 16,200 students in 129 schools, and the 8th-grade samples had approximately 17,000 students in 141 schools. Response rates were 83 percent, 88 percent, and 89 percent for 12th, 10th, and 8th graders and have been relatively constant across time. Absentees constitute virtually all of the nonresponding students.

Issues Affecting Interpretation: Estimates of substance use for youth based on the National Survey on Drug Use & Health (NSDUH) are not directly comparable with estimates based on the MTF and the Youth Risk Behavior Surveillance System (YRBSS). In addition to the fact that the MTF excludes dropouts and absentees, rates are not directly comparable across these surveys because of differences in populations covered, sample design, questionnaires, interview setting, and statistical approaches to make the survey estimates generalizable to the entire population. The NSDUH survey collects data in homes, whereas the MTF and YRBSS collect data in school classrooms. The NSDUH estimates are tabulated by age, while the MTF and YRBSS estimates are tabulated by grade, representing different ages as well as different populations.

##### References

Johnston LD, O’Malley PM, Bachman JG, Schulenberg JE. Monitoring the Future national results on adolescent drug use: Overview of key findings, 2003. NIH Pub. No. 04–5506. Bethesda, MD: National Institute on Drug Abuse. 2004.
Johnston LD, O’Malley PM, Bachman JG. Monitoring the Future national survey results on drug use, 1975–2002. Volume I: Secondary school students. NIH Pub. No. 03–5375. Bethesda, MD: National Institute on Drug Abuse. 2003 http://monitoringthefuture.org/pubs/monographs/vol1_2002.pdf.
Cowan CD. (2001). Coverage, Sample Design, and Weighting in Three Federal Surveys. Journal of Drug Issues.
For More Information: See the NIDA Web site at www.nida.nih.gov or the Monitoring the Future Web site at www.monitoringthefuture.org/.

### National Ambulatory Medical Care Survey (NAMCS)

#### Centers for Disease Control and Prevention

##### National Center for Health Statistics

Overview: The National Ambulatory Medical Care Survey (NAMCS) is a national survey designed to provide objective, reliable information about the provision and use of medical care services provided in office-based physician practices in the United States.

Selected Content: Data are collected on providers seen; reason for visit; diagnoses; drugs ordered, provided, or continued; and selected procedures and tests ordered or performed during the visit. Patient data include age, sex, race, and expected source of payment. Data are also collected on selected characteristics of physician practices.

Data Years: The NAMCS, which began in 1973, was conducted annually until 1981, once in 1985, and resumed an annual schedule in 1989.

Coverage: The scope of the survey covers patient encounters in the offices of non-Federally employed physicians classified by the American Medical Association or American Osteopathic Association as “office-based, patient care” physicians. Patient encounters with physicians engaged in prepaid practices—health maintenance organizations (HMOs), independent practice organizations (IPAs), and other prepaid practices—are included in NAMCS. Excluded are visits to hospital-based physicians, visits to specialists in anesthesiology, pathology, and radiology, and visits to physicians who are principally engaged in teaching, research, or administration. Telephone contacts and nonoffice visits are also excluded.

Methodology: A multistage probability design is employed. The first-stage sample consists of 84 primary sampling units (PSUs) in 1985 and 112 PSUs, beginning in 1989, selected from about 1,900 such units into which the United States has been divided. In each sample PSU, a sample of practicing non-Federal office-based physicians is selected from master files maintained by the American Medical Association and the American Osteopathic Association. The final stage involves systematic random samples of office visits during randomly assigned 7-day reporting periods. In 1985 the survey excluded Alaska and Hawaii. Starting in 1989 the survey included all 50 States and the District of Columbia.

The U.S. Census Bureau acts as the data collection agent for the NAMCS. Screening interviews are conducted by Census field representatives to obtain information about physicians’ office-based practices and to ensure that the practice is within the scope of the survey. Field representatives visit eligible physicians prior to their participation in the survey to provide them with survey materials and instruct them on how to sample patient visits and complete “Patient Record” forms. Participants are asked to complete forms for a systematic random sample of approximately 30 office visits occurring during a randomly assigned 1-week period, but increasingly Patient Record forms are abstracted by field representatives.

Sample data are weighted to produce national estimates. The estimation procedure used in the NAMCS has three basic components: inflation by the reciprocal of the probability of selection, adjustment for nonresponse, and ratio adjustment to fixed totals.

Sample Size and Response Rate: In 1999 a sample of 2,499 physicians was selected: 1,728 were in scope and 1,087 participated in the survey for a response rate of 63 percent. Data were provided on 20,760 visits. In the 2000 survey a sample of 3,000 physicians was selected: 2,049 were in scope and 1,388 participated for a response rate of 68 percent. Data were provided on 27,369 visits. In the 2002 survey, a sample of 3,150 physicians was selected: 2,095 were in scope and 1,492 participated for a response rate of 71 percent. Data were provided on 28,738 visits.

Issues Affecting Interpretation: Some items included on the survey have changed over time. Some physician practices are out of scope (e.g., single-specialty radiology practices), which affects the generalizability of results. Sample sizes vary by survey year. For some years it is suggested that analysts combine two or more years of data if they wish to examine relatively rare populations or events.

##### Reference

Cherry DK, Burt CW, Woodwell DA. National Ambulatory Medical Care Survey: 2001 summary. Advance data from vital and health statistics; no. 337. Hyattsville, MD: National Center for Health Statistics. 2003.
For More Information: See the NHCS section of the NCHS Web site at www.cdc.gov/nchs/nhcs.htm or the Ambulatory Health Care Data Web site at www.cdc.gov/nchs/about/major/ahcd/ahcd1.htm.

### National Compensation Survey

#### Bureau of Labor Statistics

Overview: The National Compensation Survey (NCS) provides comprehensive measures of occupational earnings, compensation cost trends, benefit incidence, and detailed plan provisions.

Selected Content: Detailed occupational earnings are collected for metropolitan and nonmetropolitan areas, and broad geographic regions and on a national basis. The Employment Cost Index (ECI) and Employer Costs for Employee Compensation (ECEC) are compensation measures derived from the NCS. ECI measures changes in labor costs. Average hourly employer cost for employee compensation is presented in the ECEC. National benefits data are presented for three broad occupational groupings: professional, technical, and related; clerical and sales; and blue-collar and service employees. Data are also available by goods- and service-producing occupations, union affiliation, and full- and part-time status.

Data Years: The NCS replaces three existing BLS surveys: Employment Cost Index (ECI), Occupational Compensation Survey Program (OCSP), and Employee Benefits Survey (EBS). The ECI and EBS were fully integrated into the NCS in 1999. Prior to 1999 the EBS were collected for small private establishments (those employing fewer than 100 workers) and from State and local governments (regardless of employment size). In odd-numbered years, data were collected for medium and large private establishments (those employing 100 workers or more). The ECI was created in the mid-1970s. The EBS was added to an existing data collection effort, the National Pay Survey, in the late 1970s. The Employer Cost for Employee Compensation product was developed in 1987.

Coverage: The NCS provides information for the nation, for 81 metropolitan areas and 73 nonmetropolitan counties representing the United States, and for the 9 census divisions (although not all areas have information for all occupations). It includes both full- and part-time workers who are paid a wage or salary. It excludes agriculture, fishing and forestry industries, private household workers, and the Federal government. The NCS only includes establishments with at least 50 workers.

Methodology: Conducted quarterly by The Bureau of Labor Statistics’ Office of Compensation and Working Conditions, the sample for the NCS is selected using a three-stage design. The first stage involves the selection of areas. The NCS sample consists of 154 metropolitan and nonmetropolitan areas that represent the Nation’s 326 metropolitan statistical areas and the remaining portions of the 50 States. In the second stage, establishments are systematically selected with probability of selection proportionate to their relative employment size within the industry. Use of this technique means that the larger an establishment’s employment, the greater its chance of selection.

The third stage of sampling is a probability sample of occupations within a sampled establishment. This step is performed by the BLS field economist during an interview with the respondent establishment in which selection of an occupation is based on probability of selection proportionate to employment in the establishment. Each occupation is classified under its corresponding major occupational group using the Occupational Classification System Manual (OCSM) and the Census Occupation Index, which are based on the 1990 U.S. Census.

Data collection is conducted by BLS field economists. Data are gathered from each establishment on the primary business activity of the establishment, types of occupations, number of employees, wages and salaries and benefits, hours of work, and duties and responsibilities. Wage data obtained by occupation and work level allows NCS to publish occupational wage statistics for localities, census divisions, and the Nation.

Sample Size and Response Rates: The NCS sample consists of 154 metropolitan and nonmetropolitan areas that represent the Nation’s 326 metropolitan statistical areas and the remaining portions of the 50 States. The 2003 NCS benefits incidence survey obtained data from 2,924 private industry establishments, representing nearly 103 million workers; of this number, nearly 79 million were full-time workers, and the remainder were part-time workers.

Issues Affecting Interpretation: Because the NCS merges separate surveys, trend analyses prior to 2000 should be interpreted with care. The industrial coverage, establishment size coverage, and geographic coverage for the EBS survey changed since 1990. All surveys conducted from 1979 to 1989 excluded part-time employees and establishments in Alaska and Hawaii. The surveys conducted from 1979 to 1986 covered only medium and large private establishments and excluded most of the service industries. Establishments that employed at least 50, 100, or 250 workers, depending on the industry, were included. The survey conducted in 1987 consisted of State and local governments with 50 or more employees. The surveys carried out in 1988 and 1989 included all private-sector establishments that employed 100 or more employees.

##### References

U.S. Department of Labor, Bureau of Labor Statistics, Employer Costs for Employee Compensation Summary—March, 2004, found at www.bls.gov/news.release/ecec.nr0.htm.
The National Compensation Survey: Compensation Statistics for the 21st Century, found at www.bls.gov/opub/cwc/archive/winter2000art1.pdf.
For More Information: See the National Compensation Survey Web site at www.bls.gov/ncs.

### National Health Accounts

#### Centers for Medicare & Medicaid Services

Overview: National Health Accounts provide estimates of how much money is spent on different types of health care-related services and programs in the United States.

Selected Content: National Health Expenditures measure spending for health care in the United States by type of service delivered (such as hospital care, physician services, nursing home care) and source of funding for those services (such as private health insurance, Medicare, Medicaid, and out-of-pocket spending).

Data Years: Expenditure estimates are available starting from 1960 in data files or in published articles.

Methodology: The American Hospital Association (AHA) data on hospital finances are the primary source for estimates relating to hospital care. The salaries of physicians and dentists on the staffs of hospitals, hospital outpatient clinics, hospital-based home health agencies, and nursing home care provided in the hospital setting are considered to be components of hospital care. Expenditures for home health care and for services of health professionals (for example, doctors, chiropractors, private duty nurses, therapists, and podiatrists) are estimated primarily using a combination of data from the U.S. Bureau of the Census Services Annual Survey and the quinquennial Census of Service Industries.

The estimates of retail spending for prescription drugs are based on household and industry data on prescription drug transactions. Expenditures for other medical nondurables and for vision products and other medical durables purchased in retail outlets are based on estimates of personal consumption expenditures prepared by the U.S. Department of Commerce’s Bureau of Economic Analysis, U.S. Bureau of Labor Statistics/Consumer Expenditure Survey; the 1987 National Medical Expenditure Survey and the 1996 Medical Expenditure Panel Survey conducted by the Agency for Healthcare Research and Quality; and spending by Medicare and Medicaid. Those durable and nondurable products provided to inpatients in hospitals or nursing homes, and those provided by licensed professionals or through home health agencies, are excluded here, but they are included with the expenditure estimates of the provider service category.

Nursing home expenditures cover care rendered in establishments providing inpatient nursing and health-related personal care through active treatment programs for medical and health-related conditions. These establishments cover skilled nursing and intermediate care facilities, including those for the mentally retarded. Spending estimates are primarily based on data from the U.S. Bureau of the Census Services Annual Survey and the quinquennial Census of Service Industries.

Expenditures for construction include those spent on the erection or renovation of hospitals, nursing homes, medical clinics, and medical research facilities, but not for private office buildings providing office space for private practitioners. Expenditures for noncommercial research (the cost of commercial research by drug companies is assumed to be imbedded in the price charged for the product; to include this item again would result in double counting) are developed from information gathered by the National Institutes of Health and the National Science Foundation.

Source of funding estimates likewise come from a multiplicity of sources. Data on the Federal health programs are taken from administrative records maintained by the servicing agencies. Among the sources used to estimate State and local government spending for health are the U.S. Bureau of the Census’ Government Finances and the National Academy of Social Insurance reports on State-operated workers’ compensation programs. Federal and State and local expenditures for education and training of medical personnel are excluded from these measures where they are separable. For the private financing of health care, data on the financial experience of health insurance organizations come from special Centers for Medicare & Medicaid Services analyses of private health insurers and from the Bureau of Labor Statistics’ survey on the cost of employer-sponsored health insurance and on consumer expenditures. Information on out-of-pocket spending from the U.S. Bureau of the Census Services Annual Survey; U.S. Bureau of Labor Statistics Consumer Expenditure Survey; the 1987 National Medical Expenditure Survey and the Medical Expenditure Panel Surveys conducted by the Agency for Healthcare Research and Quality; and from private surveys conducted by the American Hospital Association, American Medical Association, American Dental Association, and IMS Health, an organization that collects data from the pharmaceutical industry, is used to develop estimates of direct spending by customers.

##### Reference

Levit K, Smith C, Cowan C, Sensenig A, Catlin A. (2004). Health Spending Rebound Continues in 2002. Health Aff.
For More Information: See the Centers for Medicare & Medicaid Services National Health Accounts Web site at http://cms.hhs.gov/statistics/nhe.

#### State Health Expenditures

Overview: Estimates of personal health care spending by State are created using the same definitions of health care sectors used in producing the National Health Expenditures (NHE). These estimates are useful in measuring the role of health spending in States’ economies.

Selected Content: Health Accounts by State provide estimates of health care spending by type of establishment delivering care (such as hospitals, physicians and clinics, and nursing homes) and by medical products (such as prescription drugs, over-the-counter medicines and sundries, and durable medical products such as eyeglasses and hearing aids) purchased in retail outlets. Source of funding estimates by State are also provided for Medicare and Medicaid.

Data Years: Annual State health expenditures are available for 1980–98.

Methodology: The same data sources used in creating NHE are also used to create State estimates whenever possible. Additional sources are employed when surveys used to create valid national estimates lack sufficient sample size to create valid State-level estimates. State-level data are used to estimate State-by-State distribution of health spending, and NHE national totals for the specific type of service or source of funds are used to control the level of State-by-State distributions. This procedure implicitly assumes that national spending estimates can be created more accurately than State-specific expenditures.

The NHE data that were used as national totals for these State estimates were published in Health, United States, 2001, and differ from the sum of State estimates because national totals included expenditures for persons living in U.S. territories and for military and Federal civilian employees and their families stationed overseas. The sum of the State-level expenditures excludes health spending for those groups. Starting with Health, United States, 2002 NHE reflect new data and benchmark revisions incorporated after completion of the State estimates and incorporate a conceptual revision to exclude spending for persons living in U.S. territories and military and Federal civilian employees and their families living overseas.

Starting in Health, United States, 2002, State estimates are based on the location of the beneficiary’s residence. This differs from previous estimates published in Health, United States, which presented spending based on the health care provider’s location. State estimates were first constructed based on the provider’s location because data available to estimate spending by State primarily comes from providers and represents the State-of-provider location. However, the most useful unit for analyzing spending trends and differences are per capita units, which are based on spending estimates for the State in which people reside. Therefore, State-of-provider-based expenditures are adjusted to a State-of-residence basis using interstate border-crossing flow patterns that represent travel patterns across State borders for health care.

Data for the interstate border-crossing flow patterns are based on Medicare claims. Medicare is the only comprehensive source on which to base interstate flows of spending between State-of-provider and State-of-beneficiary residence. Data for non-Medicare payers (excluding Medicaid) are also based on Medicare flow patterns but are further adjusted for age-specific service mix variation in hospital and physician services. Medicaid services are not adjusted because it is assumed that care provided to eligible State residents is most often provided by in-State providers and further assumed that spending by Medicaid is identical on a residence and provider basis.

In addition to differences noted earlier, national totals for residence-based State health expenditures may differ slightly from national totals for provider-based expenditures because of inflows and outflows of health care spending to the U.S. territories. Because flow patterns are based on Medicare data, we are able to adjust for services that Medicare beneficiaries receive outside of the United States and for services received by Medicare beneficiaries in the United States who either live in the U.S. territories or in other countries. Similar adjustments for the non-Medicare, non-Medicaid population are not possible.

For More Information: See the Centers for Medicare & Medicaid Services National Health Expenditures Web site at http://cms.hhs.gov/statistics/nhe/#state.

### National Health Care Survey (NHCS)

#### Centers for Disease Control and Prevention

##### National Center for Health Statistics

Overview: The National Health Care Survey (NHCS) is a family of surveys that collect data from health care providers and establishments about the utilization of health services and characteristics of providers and their patients.

Selected Content: The components of the NHCS represent the major sectors of the U.S. health care system providing data on ambulatory, inpatient, and long-term care settings. This family of surveys includes the following components:

- National Ambulatory Medical Care Survey (NAMCS)
- National Hospital Ambulatory Medical Care Survey (NHAMCS)
- National Hospital Discharge Survey (NHDS)
- National Survey of Ambulatory Surgery (NSAS)
- National Home and Hospice Care Survey (NHHCS)
- National Nursing Home Survey (NHHS)

Methodology: Each survey in the family is based on a multistage sampling design that includes the health care facilities or providers and their records. Data are collected through abstraction of medical records, completion of encounter forms, compilation of data from State and professional associations, purchase of data from commercial abstraction services, and surveys of providers. Data from all survey components are collected from the establishment, and in no case is information received directly from the person receiving care.

For More Information: See the NHCS Web site at www.cdc.gov/nchs/nhcs.htm.

### National Health and Nutrition Examination Survey (NHANES)

#### Centers for Disease Control and Prevention

##### National Center for Health Statistics

Overview: The National Health and Nutrition Examination Survey (NHANES) program includes a series of cross-sectional nationally representative health examination surveys conducted in mobile examination units or clinics (MECs). In the first series of surveys, the National Health Examination Survey (NHES), data were collected on the prevalence of certain chronic diseases, the distributions of various physical and psychological measures, and measures of growth and development. In 1971 a nutrition surveillance component was added and the survey name changed to the National Health and Nutrition Examination Survey.

Selected Content: The NHANES surveys have collected data on chronic disease prevalence and conditions (including undiagnosed conditions) and risk factors such as obesity and smoking, serum cholesterol levels, hypertension, diet and nutritional status, immunization status, infectious disease prevalence, health insurance, and measures of environmental exposures. Other topics addressed include hearing, vision, mental health, anemia, diabetes, cardiovascular disease, osteoporosis, oral health, mental health, pharmaceuticals used, and physical fitness.

NHES I data were collected on the prevalence of certain chronic diseases as well as the distributions of various physical and psychological measures, including blood pressure and serum cholesterol levels. NHES II and NHES III focused on factors related to growth and development in children and youth.

In NHANES I, data were collected on indicators of the nutritional and health status of the American people through dietary intake data, biochemical tests, physical measurements, and clinical assessments for evidence of nutritional deficiency. Detailed examinations were given by dentists, ophthalmologists, and dermatologists, with an assessment of need for treatment. In addition, data were obtained for a subsample of adults on overall health care needs and behavior, and more detailed examination data were collected on cardiovascular, respiratory, arthritic, and hearing conditions. For NHANES II the nutrition component was expanded. In the medical area primary emphasis was placed on diabetes, kidney and liver functions, allergy, and speech pathology. The third National Health and Nutrition Examination Survey (NHANES III) also included data on antibodies, spirometry, and bone health.

Beginning in 1999 with continuous NHANES, new topics include cardiorespiratory fitness, physical functioning, lower extremity disease, full body scan (DXA) for body fat as well as bone density, and tuberculosis infection.

Data Years: Data have been collected from surveys conducted during 1960–62 (NHES I), 1963–65 (NHES II), 1966–70 (NHES III), 1971–74 (NHANES I), 1976–80 (NHANES II), 1982–84 (HHANES), and 1988–94 (NHANES III). Beginning in 1999, the survey has been conducted continuously.

Coverage: With the exception of the Hispanic Health and Nutrition Examination Survey (see Methodology, below), the NHES and NHANES provide estimates of the health status of the civilian, noninstitutionalized population of the United States. NHES II and NHES III examined probability samples of the Nation’s noninstitutionalized children ages 6–11 years and 12–17 years, respectively. The NHANES I target population was the civilian noninstitutionalized population 1–74 years of age residing in the coterminous United States, except for people residing on any of the reservation lands set aside for the use of American Indians.

The NHANES II target population was the civilian noninstitutionalized population 6 months–74 years of age residing in the United States, including Alaska and Hawaii.

In Hispanic Health and Nutrition Examination Survey (HHANES) three geographically and ethnically distinct populations were studied: Mexican Americans living in Texas, New Mexico, Arizona, Colorado, and California; Cuban Americans living in Dade County, Florida; and Puerto Ricans living in parts of New York, New Jersey, and Connecticut.

The NHANES III target population was the civilian noninstitutionalized population 2 months of age and over. The sample design provided for oversampling among children 2–35 months of age, persons 70 years of age and over, black Americans, and Mexican Americans.

Beginning in 1999 NHANES oversampled low-income persons, adolescents 12–19 years of age, persons 60 years of age and over, African Americans, and Mexican Americans. The sample is not designed to give a nationally representative sample for the total population of Hispanics residing in the United States.

Methodology: The NHANES includes clinical examinations, selected medical and laboratory tests, and self-reported data. The NHANES and previous surveys interviewed persons in their homes and conducted medical examinations, including laboratory analysis of blood, urine, and other tissue samples. Medical examinations and laboratory tests follow very specific protocols and are as standard as possible to ensure comparability across sites and providers. In addition to the MEC examinations, a small number of survey participants receive an abbreviated health examination in their homes if they are unable to come to the MEC.

For the first program or cycle of the NHES I, a highly stratified multistage probability sample was selected to represent the 111 million civilian noninstitutionalized adults 18–79 years of age in the United States at that time. The sample areas consisted of 42 primary sampling units (PSUs) from the 1,900 geographic units. NHES II and NHES III were also multistage stratified probability samples of clusters of households in land-based segments. NHES II and III used the same 40 PSUs.

For NHANES I the sample areas consisted of 65 PSUs. A subsample of persons 25–74 years of age was selected to receive the more detailed health examination. Groups at high risk of malnutrition were oversampled.

NHANES II used a multistage probability design that involved selection of PSUs, segments (clusters of households) within PSUs, households, eligible persons, and finally, sample persons. The sample design provided for oversampling among persons 6 months–5 years of age, 60–74 years of age, and those living in poverty areas.

HHANES was similar in content and design to NHANES I and II. The major difference between HHANES and the previous national surveys is that HHANES used a probability sample of three special subgroups of the population living in selected areas of the United States rather than a national probability sample. The three HHANES universes included approximately 84, 57, and 59 percent of the respective 1980 Mexican-, Cuban-, and Puerto Rican-origin populations in the continental United States.

The survey for the NHANES III was conducted from 1988 to 1994 and consisted of two phases of equal length and sample size. Phase 1 and Phase 2 comprised random samples of the U.S. population living in households. About 40,000 persons 2 months of age and over were selected and asked to complete an extensive interview and an examination. Participants were selected from households in 81 counties across the United States. Children aged 2 months to 5 years and persons 60 years of age and over were oversampled to provide precise descriptive information on the health status of selected population groups of the United States

Beginning in 1999, NHANES became a continuous, annual survey, which also allows increased flexibility in survey content. Since April 1999, NHANES collects data every year from a representative sample of the U.S. population, newborns and older, by in-home personal interviews and physical examinations in the MEC. The sample design is a complex, multistage, clustered design using unequal probabilities of selection. The first-stage sample frame for continuous NHANES during 1999–2001 was the list of PSUs selected for the design of the National Health Interview Survey (NHIS). Typically, an NHANES PSU is a county. For 2002, an independent sample of PSUs (based on current Census data) was selected. This independent design will be used for the period 2002–06. For 1999, because of delay in the start of data collection, 12 distinct PSUs were in the annual sample. For each year 2000–02, 15 PSUs were selected. The within-PSU design involves forming secondary sampling units that are nested within census tracts, selecting dwelling units within secondary units, and then selecting sample persons within dwelling units. The final sample person selection involves differential probabilities of selection according to demographic variables sex (male or female), race/ethnicity (Mexican American, black, all others), and age. Because of the differential probabilities of selection, dwelling units are screened for potential sample persons. Sample weights are available and should be used in estimation of descriptive statistics. The complex design features should be used in estimating standard errors for the descriptive estimates.

The estimation procedure used to produce national statistics for all NHANES involved inflation by the reciprocal of the probability of selection, adjustment for nonresponse, and poststratified ratio adjustment to population totals. Sampling errors also were estimated to measure the reliability of the statistics.

Sample Size and Response Rates: NHES I sampled 7,710 adults. The examination response rate was 86.5 percent. NHES II sampled 7,417 children and reported a response rate of 96 percent for the questionnaire sample and 73 percent for the examination sample. NHES III sampled 7,514 youth and reported a response rate of 90 percent.

A sample of 28,043 persons was selected for NHANES I. Household interviews were completed for more than 96 percent of the persons selected, and about 75 percent (20,749) were examined. A sample of 27,801 persons was selected for NHANES II; 73.1 percent (20,322 persons) were examined.

In the HHANES 9,894 persons in the Southwest were selected (75 percent or 7,462 were examined); in Dade County 2,244 persons were selected (60 percent or 1,357 were examined); and in the Northeast 3,786 persons were selected (75 percent or 2,834 were examined). Over the 6-year survey period of NHANES III, 39,695 persons were selected, the household interview response rate was 86 percent, and the medical examination response rate was 78 percent.

In the sample selection for NHANES 1999–2000, there were 22,839 dwelling units screened. Of these, 6,005 households had at least one eligible sample person identified for interviewing. A total of 12,160 eligible sample persons were identified. The overall response rate in NHANES 1999–2000 for those interviewed was 81.9 percent (9,965 of 12,160), and the response rate for those examined was 76.3 percent (9,282 of 12,160). For NHANES 2001–02 there were 13,156 persons selected in the sample, of which 83.9 percent (11,039) were interviewed and 79.7 percent (10,480) of the 13,156 selected completed the health examination component of the survey.

Issues Affecting Interpretation: Data elements, lab tests performed, and the technological sophistication of medical examination and laboratory equipment have changed over time. Therefore, trend analyses should carefully examine how specific data elements were collected across the different NHANES and NHES surveys.

##### References

Gordon T, Miller HW. Cycle I of the Health Examination Survey: Sample and response, United States, 1960–62. National Center for Health Statistics. Vital Health Stat 11(1). 1974.
Plan, operation, and response results of a program of children’s examinations. National Center for Health Statistics. Vital Health Stat 1(5). 1967.
Schaible WL. Quality control in a National Health Examination Survey. National Center for Health Statistics. Vital Health Stat 2(44). 1972.
Miller HW. Plan and operation of the Health and Nutrition Examination Survey, United States, 1971–73. National Center for Health Statistics. Vital Health Stat 1(10a) and 1(10b). 1977 and 1978.
Engel A, Murphy RS, Maurer K, Collins E. Plan and operation of the NHANES I Augmentation Survey of Adults 25–74 years, United States, 1974–75. National Center for Health Statistics. Vital Health Stat 1(14). 1978.
McDowell A, Engel A, Massey JT, Maurer K. Plan and operation of the second National Health and Nutrition Examination Survey, 1976–80. National Center for Health Statistics. Vital Health Stat 1(15). 1981.
Maurer K. Plan and operation of the Hispanic Health and Nutrition Examination Survey, 1982–84. National Center for Health Statistics. Vital Health Stat 1(19). 1985.
Ezzati TM, Massey JT, Waksberg J, et al. Sample design: Third National Health and Nutrition Examination Survey. National Center for Health Statistics. Vital Health Stat 2(113). 1992.
Plan and operation of the Third National Health and Nutrition Examination Survey, 1988–94. National Center for Health Statistics. Vital Health Stat 1(32). 1994.
For More Information: See the NHANES Web site at www.cdc.gov/nchs/nhanes.htm.

### National Health Interview Survey (NHIS)

#### Centers for Disease Control and Prevention

##### National Center for Health Statistics

Overview: The National Health Interview Survey (NHIS) monitors the health of the U.S. population through the collection and analysis of data on a broad range of health topics. A major strength of this survey lies in the ability to display health measures by many demographic and socioeconomic characteristics.

Selected Content: The NHIS obtains information on illnesses, injuries, activity limitation, chronic conditions, health insurance coverage, utilization of health care, and other health topics. Demographic data include gender, age, education, race/ethnicity (reported by respondent or proxy), place of birth, income, and place of residence. Other data collected include risk factors such as lack of exercise, smoking, alcohol consumption, and use of prevention services such as vaccinations, mammography, and pap smears. Special modules and supplements focus on different issues each year and have included topics such as HIV/AIDS, aging, cancer screening, prevention, alternative and complementary medicine, and many other topics.

Data Years: The NHIS has been conducted annually since 1957 with a major redesign every 10–15 years.

Coverage: The NHIS covers the civilian noninstitutionalized population of the United States. Excluded are patients in long-term care facilities, persons on active duty with the Armed Forces (although their dependents are included), and U.S. nationals living in foreign countries.

Methodology: The NHIS is a cross-sectional household interview survey. Sampling and interviewing are continuous throughout each year. The sampling plan follows a multistage area probability design that permits the representative sampling of households. The sampling plan was last redesigned in 1995. Information for only the current sampling plan covering the design years of 1995–2004 is presented. The first stage consists of a sample of 358 primary sampling units (PSUs) drawn from approximately 1,900 geographically defined PSUs that cover the 50 States and the District of Columbia. A PSU consists of a county, a small group of contiguous counties, or a metropolitan statistical area.

Within a PSU, two types of second-stage units are used: area segments and permit area segments. Area segments are defined geographically and contain an expected eight or twelve addresses. Permit area segments cover geographical areas containing housing units built after the 1990 census. The permit area segments are defined using updated lists of building permits issued in the PSU since 1990 and contain an expected four addresses. Within each segment all occupied households at the sample addresses are targeted for interview.

The total NHIS sample of PSUs is subdivided into four separate panels, or subdesigns, such that each panel is a representative sample of the U.S. population. This design feature has a number of advantages, including flexibility for the total sample size. The households selected for interview each week in the NHIS are a probability sample representative of the target population.

The NHIS that was fielded from 1982–96 consisted of two parts: (1) a set of basic health and demographic items (known as the Core questionnaire), and (2) one or more sets of questions on current health topics (known as Supplements). The Core questionnaire remained the same over that time period whereas the current health topics changed depending on data needs.

The NHIS questionnaire revision first implemented in 1997 has three parts or modules: a Basic module, a Periodic module, and a Topical module. The Basic module corresponds to the core questionnaire before revision. It remains largely unchanged from year to year and allows for trend analysis and for data from more than 1 year to be pooled to increase sample size for analytic purposes. The Basic module contains three components: the Family Core, the Sample Adult Core, and the Sample Child Core. The Family Core component collects information on everyone in the family and allows the NHIS to serve as a sampling frame for additional integrated surveys as needed. Information collected on the Family Core for all family members includes household composition and sociodemographic characteristics, tracking information, information for matches to administrative data bases, health insurance coverage, and basic indicators of health status and utilization of health care services.

From each family in the NHIS, one sample adult and, for families with children under 18 years of age, one sample child are randomly selected to participate in the Sample Adult Core and the Sample Child Core questionnaires. Because some health issues are different for children and adults, these two questionnaires differ in some items but both collect basic information on health status, use of health care services, health conditions, and health behaviors.

Sample Size and Response Rates: Since 1997 the sample numbered about 100,000 persons with about 30,000 persons participating in the sample adult and about 15,000 persons in the sample child questionnaire. The household response rate for the ongoing portion of the survey (Basic module) has been between 94 and 98 percent over the years. In recent years the total household response rate was about 90 percent. Response rates for special health topics (supplements) have generally been lower. For example, the response rate was 80 percent for the 1994 Year 2000 Supplement, which included questions about cigarette smoking and use of such preventive services as mammography. Since 1997 the final response rate for the sample adult supplement was 70–80 percent and 78–84 percent for the sample child supplement.

Issues Affecting Interpretation: In 1997 the questionnaire was redesigned and some basic concepts were changed and other concepts were measured in different ways. For some questions there was a change in the reference period. Also in 1997 the collection methodology changed from paper and pencil questionnaires to computer-assisted personal interviewing (CAPI). Because of the major redesigns of the questionnaire in 1997, most trend tables in Health, United States begin with 1997 data.

##### References

Massey JT, Moore TF, Parsons VL, Tadros W. Design and estimation for the National Health Interview Survey, 1985–94. National Center for Health Statistics. Vital Health Stat 2(110). 1989.
National Center for Health Statistics. National Health Interview Survey: Research for the 1995–2004 redesign. Vital Health Stat 2(126). 1999.
Botman SL, Moore TF, Moriarity CL, Parsons VL. Design and estimation for the National Health Interview Survey, 1995–2004. National Center for Health Statistics. Vital Health Stat 2(130). 2000.
For More Information: See the NHIS Web site at www.cdc.gov/nchs/nhis.htm.

### National Health Provider Inventory (NHPI)

#### Centers for Disease Control and Prevention

##### National Center for Health Statistics

Overview: The National Health Provider Inventory (NHPI) is an inventory of nursing homes, home health agencies, and hospices. The NHPI and its predecessor inventories served as sampling frames for the NCHS National Nursing Home Survey and National Home and Hospice Care Survey.

Selected Content: Information collected included facility ownership, size, services provided, geographic location, and some resident or client characteristics.

Data Years: The NHPI was conducted in 1991 and has not been repeated.

Coverage: The NHPI included nursing homes, board and care homes, home health agencies, and hospices.

Methodology: The National Master Facility Inventories (NMFIs), forerunners of the National Health Provider Inventory (NHPI), were a series of inventories of inpatient health facilities in the United States conducted by NCHS. The inventories included hospitals, nursing and related-care homes, and other custodial care facilities. The last NMFI was conducted in 1982. In 1986 the inventory was changed to the Inventory of Long-Term Care Places (ILTCP) and included nursing and related-care homes and facilities for the mentally retarded. In 1991 the inventory was changed to NHPI.

### National Home and Hospice Care Survey (NHHCS)

#### Centers for Disease Control and Prevention

##### National Center for Health Statistics

Overview: The National Home and Hospice Care Survey (NHHCS) collects data on the characteristics and care provided by home health care agencies and hospices as well as characteristics of patients receiving these services.

Selected Content: The NHHCS provides information on home health and hospice care from two perspectives—that of the provider of services and that of the recipient. Data collected at the home health care and hospice agency level include number of clients served, ownership and affiliations, certification status, and services provided. At the patient level, data are collected on demographic characteristics, diagnoses, living arrangements, caregiver status, enrollment date, discharge disposition (for discharge sample), selected therapies and treatments provided, aids and special devices used, activities of daily living (ADL) assistance received from the agency, vision and hearing impairments, continence, payment source, and care charges.

Data Years: Initiated in 1992, the NHHCS was also conducted in 1993, 1994, 1996, 1998, and 2000.

Coverage: The survey covers agencies and the current patients and discharges from agencies that provide home health and hospice care services in the United States. Agencies may be freestanding health facilities or units of larger organizations, such as hospitals or nursing homes. Agencies providing only durable medical equipment are excluded. Only agencies providing home health or hospice care services to patients at the time of the survey are eligible to participate.

Methodology: The sample design for the 1992 and 1994 NHHCS was a stratified three-stage probability design.

Primary sampling units were selected at the first stage, agencies were selected at the second stage, and up to six current patients and six discharges were selected at the third stage. The sample design for the 1996, 1998, and 2000 NHHCS was a two-stage probability design in which agencies were selected at the first stage and current patients and discharges were selected at the second stage. Current patients were those on the rolls of the agency as of midnight the day before the survey. Discharges were selected to estimate the number of discharges from the agency during the 12 months before the survey. Agency characteristics were obtained through interviews with the agency administrators and staff. Sample patients and discharges were selected, and questionnaires were completed by interviewing the staff member most familiar with the care provided to the patient. Respondents were requested to refer to the medical records for the patient.

Estimates based on the NHHCS are derived by a multistage estimation procedure that produces essentially unbiased national estimates and has three principle components: (a) inflation by the reciprocals of the probabilities of sample selection; (b) adjustment for nonresponse; and (c) ratio adjustment to fixed totals. The data from the surveys are adjusted for three types of nonresponse: (a) an in-scope sample agency did not respond; (b) an agency did not complete the sampling lists used to select the patient or discharge samples; and (c) the agency did not complete the questionnaire for the sample patient or discharge.

Sample Size and Response Rates: The original sampling frame consisted of all home health care agencies and hospices identified in the 1991 National Health Provider Inventory (NHPI). The 1992 sample contained 1,500 agencies. These agencies were revisited during the 1993 survey (excluding agencies that had been found to be out of scope for the survey). In 1994 in-scope agencies identified in the 1993 survey were revisited, along with 100 newly identified agencies added to the sample. In 1996 the universe was again updated and a new sample of 1,200 agencies was drawn. In 1998 a sample of 1,350 agencies was selected from a universe of home health agencies and hospices obtained from various national organizations and other sources. In 2000, 1,800 agencies were sampled from the universe that was obtained from SMG Home Healthcare Market Database and the membership list of the National Hospice and Palliative Care Organization. The response rates during the 1992–2000 survey years have been greater than 92 percent at the agency level, mid-90 to mid-80 percent for current patients, and low 90 to low 80 percent for discharges.

Issues Affecting Interpretation: Characteristics of agencies and current patients reflect the situation on a given day when the survey was being conducted. Because frequent short-term users are less likely to be enrolled with the agency on any given day than long-term users, the current patient component tends to underestimate those patients with a very short length of service. The discharge component is designed to estimate the number of discharges that occur over a 12-month period. Estimates of discharges may underestimate those patients who tend to receive care for longer periods of time. Caution should be made in comparing estimates from the resident and discharge samples. Finally, various survey items have been added or modified over the survey years, which may preclude comparisons from previous years or trend analyses.

##### References

Haupt BJ. Development of the National Home and Hospice Care Survey. National Center for Health Statistics. Vital Health Stat 1(33). 1994.
Haupt BJ. The National Home and Hospice Care Survey: 1992 Summary. National Center for Health Statistics. Vital Health Stat 13(117). 1994.
Jones A, Strahan G. The National Home and Hospice Care Survey: 1994 Summary. National Center for Health Statistics. Vital Health Stat 13(126). 1997.
Haupt BJ, Jones A. National Home and Hospice Care Survey: Annual Summary, 1996. National Center for Health Statistics. Vital Health Stat 13(141). 1999.
Haupt BJ. Characteristics of hospice care discharges and their length of service: United States, 2000. National Center for Health Statistics. Vital Health Stat 13(154). 2003.
For More Information: See the National Health Care Survey (NHCS) Web site at www.cdc.gov/nchs/nhcs.htm or the National Home and Hospice Care Survey Web site at www.cdc.gov/nchs/about/major/nhhcsd/nhhcsd.htm.

### National Hospital Ambulatory Medical Care Survey (NHAMCS)

#### Centers for Disease Control and Prevention

##### National Center for Health Statistics

Overview: The National Hospital Ambulatory Medical Care Survey (NHAMCS) collects data on the utilization and provision of medical care services provided in hospital emergency and outpatient departments.

Selected Content: Data are collected on providers seen; reason for visit; diagnoses; drugs ordered, provided, or continued; and selected procedures and tests performed during the visit. Patient data include age, sex, race, and expected source of payment. Data are also collected on selected characteristics of hospitals included in the survey.

Data Years: Annual data collection began in 1992.

Coverage: The survey is a representative sample of visits to emergency departments (EDs) and outpatient departments (OPDs) of non-Federal, short-stay, or general hospitals. Telephone contacts are excluded.

Methodology: A four-stage probability sample design is used in NHAMCS, involving samples of primary sampling units (PSUs), hospitals within PSUs, clinics within OPDs, and patient visits within clinics. The first stage sample of the NHAMCS consists of 112 PSUs selected from 1,900 such units comprising the United States. Within PSUs, 600 general and short-stay hospitals were sampled and assigned to one of 16 panels. In any given year, 13 panels are included. Each panel is assigned to a 4-week reporting period during the calendar year.

In the NHAMCS outpatient department survey, a clinic is defined as an administrative unit of the OPD in which ambulatory medical care is provided under the supervision of a physician. Clinics where only ancillary services, such as radiology, laboratory services, physical rehabilitation, renal dialysis, and pharmacy, are provided, or other settings in which physician services are not typically provided, are considered out of scope. If a hospital OPD has five or fewer in-scope clinics, all are included in the sample. For hospital OPDs with more than five clinics, a systematic sample of clinics proportional to size is included in the survey.

The U.S. Census Bureau acts as the data collection agent for the NHAMCS. Census field representatives contact sample hospitals to determine whether they have a 24-hour ED and/or an OPD that offers physician services. Visits to eligible EDs and OPDs are systematically sampled over the 4-week reporting period such that about 100 ED encounters and about 200 OPD encounters are selected. Hospital staff are asked to complete “Patient Record” forms for each sampled visit, but Census field representatives typically abstract data for more than half of these visits.

Sample data are weighted to produce national estimates. The estimation procedure used in the NHAMCS has three basic components: inflation by the reciprocal of the probability of selection, adjustment for nonresponse, and ratio adjustment to fixed totals.

Sample Size and Response Rates: In any given year, the hospital sample consists of approximately 500 hospitals, of which 80 percent have EDs and about half have eligible OPDs. Typically, about 900 clinics are selected from participating hospital OPDs. In 1999 the number of patient record forms (PRFs) completed for EDs was 21,103, and for OPDs it was 29,487. In 2000 the number of PRFs completed for EDs was 25,622 and for OPDs 27,510. In 2002 the number of PRFs completed for EDs was 37,337 and for OPDs 35,586. In 1999 the hospital response rate for NHAMCS was 93 percent for EDs and 86 percent for OPDs. In 2000 the hospital response rate was 94 percent for EDs and 88 percent for OPDs. In 2002, the hospital response rate was 94 percent for EDs and 87 percent for OPDs. The participation rate for EDs has ranged from 93 to 97 percent. The participation rate for OPDs has ranged from 86 to 95 percent.

Issues Affecting Interpretation: For analyses that present visit rates per population, the civilian noninstitutionalized population is used as the denominator. However, visits to hospital EDs or OPDs can also include persons who reside in institutional settings.

##### Reference

McCaig LF, McLemore T. Plan and operation of the National Hospital Ambulatory Medical Care Survey. National Center for Health Statistics. Vital Health Stat 1(34). 1994.
For More Information: See the National Health Care Survey (NHCS) Web site at www.cdc.gov/nchs/nhcs.htm or the Ambulatory Health Care Web site at www.cdc.gov/nchs/about/major/ahcd/ahcd1.htm.

### National Hospital Discharge Survey (NHDS)

#### Centers for Disease Control and Prevention

##### National Center for Health Statistics

Overview: The National Hospital Discharge Survey (NHDS) collects and produces national estimates on characteristics of inpatient stays in non-Federal short-stay hospitals in the United States.

Selected Content: Patient information collected includes demographics, length of stay, diagnoses, and procedures. Hospital characteristics collected include region, ownership, and bed size.

Data Years: The NHDS has been conducted annually since 1965.

Coverage: The survey design covers the 50 States and the District of Columbia. Included in the survey are hospitals with an average length of stay of less than 30 days for all inpatients, general hospitals, and children’s general hospitals. Excluded are Federal, military, and Department of Veterans Affairs hospitals, as well as hospital units of institutions (such as prison hospitals), and hospitals with fewer than six beds staffed for patient use. All discharged patients from in-scope hospitals are included in the survey; however, newborns are not included in Health, United States.

Methodology: The design implemented in 1965 continued through 1987, and a redesign with a new sample of hospitals fielded in 1988 is currently in place. The sample for the 1965 NHDS was selected in 1964 from a frame of short-stay hospitals listed in the National Master Facility Inventory. A two-stage stratified sample design was used, with hospitals stratified according to bed size and geographic region. Sample hospitals were selected with probabilities ranging from certainty for the largest hospitals to 1 in 40 for the smallest hospitals. Within each participating hospital, a systematic random sample was selected from a daily listing sheet of discharges. Within hospital sampling rates for discharges varied inversely with the probability of hospital selection, so the overall probability of selecting a discharge was approximately the same across the sample.

Data collection was conducted by means of manual abstraction of patient information from sampled medical records. Sample selection and transcription of information from inpatient medical records to NHDS survey forms were performed by hospital staff, representatives of NCHS, or both. In 1985, a second data collection procedure was introduced. The procedure involved the purchase of computer data tapes from commercial abstracting services that contained automated discharge data for some hospitals participating in the NHDS. This procedure was used in approximately 17 percent of the sample hospitals for 1985–87. Discharges on these computer files were subjected to the NHDS sampling specifications as well as the computer edits and estimation procedures. Two data collection methods, manual and automated, continue to be used in the NHDS.

A redesign of the NHDS was implemented for the 1988 survey. Under the redesign hospitals were selected using a modified three-stage stratified design. Units selected at the first stage consisted of either hospitals or geographic areas. The geographic areas were Primary Sample Units (PSUs) used for the 1985–94 National Health Interview Survey, which are geographic areas such as counties or townships. Hospitals within PSUs were then selected at the second stage. Strata at this stage were defined by geographic region, PSU size, abstracting service status, and hospital specialty-size groups. Within these strata, hospitals were selected with probabilities proportional to their annual number of discharges. At the third stage, a sample of discharges was selected by a systematic random sampling technique. The sampling rate was determined by the hospital’s sampling stratum and the type of data collection system (manual or automated) used. Discharge records from hospitals submitting data via commercial abstracting services and selected State data systems (approximately 40 percent of sample hospitals) were arrayed, by primary diagnoses, patient sex and age group, and date of discharge, before sampling. The NHDS hospital sample is updated every 3 years by continuing the sampling process among hospitals that become eligible for the survey during the intervening years and by deleting hospitals that were no longer eligible. This process was conducted in 1991, 1994, 1997, and 2000.

The basic unit of estimation for NHDS is a sampled discharge. The basic estimation procedure involves inflation by the reciprocal of the probability of selection. There are adjustments for nonresponding hospitals and discharges; a postratio adjustment to fixed totals is employed.

Sample Size and Response Rate: In 2002, 504 hospitals were selected: 474 were within scope, 445 participated (94 percent), and approximately 327,000 medical records were abstracted.

Issues Affecting Interpretation: In 1988 the NHDS was redesigned. Caution is required in interpreting trend data from this period as estimates of change may be an artifact of changes in the design rather than true changes in hospital use. There are also annual modifications to the ICD–9–CM affecting diagnoses data. See related Appendix II, ICD–9–CM.

Hospital utilization rates per 1,000 population were computed using estimates of the civilian population of the United States as of July 1 of each year. Rates for 1990 through 1999 use postcensal estimates of the civilian population based on the 1990 census adjusted for net underenumeration using the 1990 National Population Adjustment Matrix from the U.S. Bureau of the Census. When intercensal estimates of the civilian population become available, discharge rates for 1990–99 will be revised. The estimates for 2000 and beyond that appear in Health, United States, 2003 and later editions were calculated using estimates of the civilian population based on census 2000, and therefore are not strictly comparable with rates calculated for the 1990s. See related Population Census and Population Estimates in Appendix I.

##### References

DeFrances CJ, Hall MJ. 2002 National Hospital Discharge Summary. Advance data from vital and health statistics; no. 342. Hyattsville, MD: National Center for Health Statistics. 2004.
Dennison C, Pokras R. Design and operation of the National Hospital Discharge Survey: 1988 redesign. National Center for Health Statistics. Vital Health Stat 1(39). 2000.
Haupt BJ, Kozak LJ. Estimates from two survey designs: National Hospital Discharge Survey. National Center for Health Statistics. Vital Health Stat 13(111). 1992.
For More Information: See the National Health Care Survey Web site at www.cdc.gov/nchs/nhcs.htm or the National Hospital Discharge Survey Web site at www.cdc.gov/nchs/about/major/hdasd/nhds.htm.

### National Immunization Survey (NIS)

#### Centers for Disease Control and Prevention

##### National Center for Health Statistics and National Immunization Program

Overview: The National Immunization Survey (NIS) program is a continuing nationwide telephone sample survey to track vaccination coverage rates for children 19–35 months of age.

Selected Content: Data collected include vaccination status and timing for diphtheria, tetanus toxoids, and pertussis vaccine (DTP/DT/DTaP); Polio vaccine; Measles, mumps, and rubella vaccine (MMR); Haemophilius influenzae type b vaccine (Hib); Hepatitis B vaccine; Varicella vaccine; Pneumococcal conjugate vaccine (PCV); and Combined series (4:3:1:3) by race/ethnicity, poverty status, location of residence, geographic division, State, and selected urban areas.

Data Years: Annual data collection was initiated beginning with data year 1994. Data collection for Varicella began in July 1996; data collection for PCV began in July 2001.

Coverage: Children 19–35 months of age in the civilian noninstitutionalized population are represented in this survey. Estimates of vaccine-specific coverage are available for the Nation, States, and 28 urban areas considered to be high risk for undervaccination.

Methodology: The NIS is a nationwide telephone sample survey of households with age-eligible children. The NIS uses a two-phase sample design. First, a random-digit dialing (RDD) sample of telephone numbers is drawn. When households with age-eligible children are contacted, the interviewer collects information on the vaccinations received by all age-eligible children. In the second phase, the interviewer collects information on the vaccination providers. All vaccination providers are contacted by mail. Providers’ responses are combined with information obtained from households to provide a more accurate estimate of vaccination coverage levels. Final estimates are adjusted for households without telephones.

Sample Size and Response Rates: In 2002, vaccination data were collected for 31,693 children aged 19–35 months. In 2002 the overall response rate was 67 percent. Vaccination information from providers was obtained for 69 percent of all children who were eligible for provider follow-up in 2002.

Issues Affecting Interpretation: For the 1998 data year, a new estimation procedure was implemented to obtain vaccination coverage rates from the provider data. For consistency, this procedure was applied to NIS data for the years 1995–97. Published estimates of vaccination coverage based on NIS data for years prior to 1998 (e.g., estimates published in MMWR articles) may differ slightly from estimates published in Health, United States and on the NIS Web site for the same NIS data. All public-use data files include the sampling weight for the new estimation procedure.

##### References

National, State, and urban area vaccination levels among children aged 19–35 months—United States, 2002. MMWR 2003;52(31):728.
Zell ER, Ezzati-Rice TM, Battaglia PM, Wright RA. (2000). National Immunization Survey: The methodology of a Vaccination Surveillance System. Public Health Rep.
For More Information: See the NIS Web site: www.cdc.gov/nis.

### National Medical Expenditure Survey (NMES)—See Medical Expenditure Panel Survey

### National Notifiable Disease Surveillance System (NNDSS)

#### Centers for Disease Control and Prevention

Overview: This system provides weekly provisional information on the occurrence of diseases defined as notifiable by the Council of State and Territorial Epidemiologists.

Selected Content: Data include incidence of reportable diseases using uniform case definitions.

Data Years: The first annual summary of The Notifiable Diseases in 1912 included reports of 10 diseases from 19 States, the District of Columbia, and Hawaii. By 1928, all States, the District of Columbia, Hawaii, and Puerto Rico were participating in national reporting of 29 specified diseases. At their annual meeting in 1950, the State and Territorial Health Officers authorized a conference of State and territorial epidemiologists whose purpose was to determine which diseases should be reported to PHS. In 1961, CDC assumed responsibility for the collection and publication of data concerning nationally notifiable diseases.

Coverage: Notifiable disease reports are received from health departments in the 50 States, five territories, New York City, and the District of Columbia. Policies for reporting notifiable disease cases can vary by disease or reporting jurisdiction, depending on case status classification (i.e., confirmed, probable, or suspect).

Methodology: CDC, in partnership with the Council of State and Territorial Epidemiologists (CSTE), operates the National Notifiable Diseases Surveillance System (NNDSS). Notifiable disease surveillance is conducted by public health practitioners at local, State, and national levels to support disease prevention and control activities. The system also provides annual summaries of the data. CSTE and CDC annually review the status of national infectious disease surveillance and recommend additions or deletions to the list of nationally notifiable diseases based on the need to respond to emerging priorities. For example, Q fever and tularemia became nationally notifiable in 2000. However, reporting nationally notifiable diseases to CDC is voluntary. Reporting is currently mandated by law or regulation only at the local and State level. Therefore, the list of diseases that are considered notifiable varies slightly by State. For example, reporting of cyclosporiasis to CDC is not done by some States in which this disease is not notifiable to local or State authorities.

State epidemiologists report cases of notifiable diseases to CDC, which tabulates and publishes these data in the Morbidity and Mortality Weekly Report (MMWR) and the Summary of Notifiable Diseases, United States (entitled Annual Summary before 1985.

Issues Affecting Interpretation: These data must be interpreted in light of reporting practices. Some diseases that cause severe clinical illness (for example, plague and rabies) are most likely reported accurately if diagnosed by a clinician. However, persons who have diseases that are clinically mild and infrequently associated with serious consequences (for example, salmonellosis) might not seek medical care from a health care provider. Even if these less severe diseases are diagnosed, they are less likely to be reported.

The degree of completeness of data reporting also is influenced by the diagnostic facilities available, the control measures in effect, public awareness of a specific disease, and the interests, resources, and priorities of State and local officials responsible for disease control and public health surveillance. Finally, factors such as changes in case definitions for public health surveillance, introduction of new diagnostic tests, or discovery of new disease entities can cause changes in disease reporting that are independent of the true incidence of disease.

##### Reference

Centers for Disease Control and Prevention. Summary of Notifiable Diseases, United States, 2002. MMWR 2004;51(53).
For More Information: See the NNDSS Web site at www.cdc.gov/epo/dphsi/nndsshis.htm.

### National Nursing Home Survey (NNHS)

#### Centers for Disease Control and Prevention

##### National Center for Health Statistics

Overview: The National Nursing Home Survey (NNHS) provides information on characteristics of nursing homes and their residents and staff.

Selected Content: The NNHS provides information on nursing homes from two perspectives—that of the provider of services and that of the recipient. Data about the facilities include characteristics such as bed size, ownership, affiliation, Medicare/Medicaid certification, specialty units, services offered, number and characteristics of staff, expenses, and charges. Data about the current residents and discharges include demographic characteristics, health status, level of assistance needed with activities of daily living, vision and hearing impairment, continence, services received, sources of payment, and discharge disposition (for discharges).

Data Years: NCHS conducted six NNHS, the first survey from August 1973 to April 1974; the second from May to December 1977; the third from August 1985 to January 1986; the fourth from July to December 1995; the fifth from July to December 1997; and the sixth from July to December 1999. The next NNHS, which has undergone a major redesign, is scheduled to be conducted during calendar year 2004.

Coverage: The initial NNHS, conducted in 1973–74, included the universe of nursing homes that provided some level of nursing care and excluded homes providing only personal or domiciliary care. The 1977 NNHS encompassed all types of nursing homes, including personal care and domiciliary care homes. The 1985 NNHS was designed to be similar to the 1973–74 survey in that it excluded personal or domiciliary care homes. However in 1985, an unknown number of residential care facilities were present in the sampling frame. These facilities were identified in the 1986 inventory survey and can be removed from the estimate of facilities and beds for 1985. The 1995, 1997, and 1999 NNHS also included only nursing homes that provided some level of nursing care and excluded homes providing only personal or domiciliary care, similar to the 1985 and 1973–74 surveys.

Data were collected from nursing homes in all 50 States and the District of Columbia (DC) in the 1995–1999 surveys, but in 1973–74, 1977, and 1985, data were only collected in the 48 contiguous States and the District of Columbia. Data on current residents were collected in all surveys; data on discharges were collected in 1977, 1985, 1997, and 1999. Expense data were collected in 1977, 1985, and 1995. Data on characteristics of staff were collected in 1973–74, 1977, and 1985.

Methodology: The survey uses a stratified two-stage probability design. The first stage is the selection of facilities, and the second stage is the selection of residents and discharges. Up to six current residents and six discharges are selected. Information on the facility is collected through a personal interview with the administrator or staff designated by the administrator. Resident data were provided by staff familiar with the care provided to the resident. Staff relied on the medical record and personal knowledge of the resident. In addition to employee data that were collected during the interview with the administrator, in several years staffing data were collected via a self-administered questionnaire. Discharge data were based on information recorded in the medical record.

Current residents are those on the facility’s roster as of the night before the survey. Included are all residents for whom beds are maintained even though they may be away on an overnight leave or in the hospital. Discharges are those who are formally discharged from care by the facility during a designated month randomly selected for each facility before data collection. Both live and deceased discharges are included. Residents were counted more than once if they were discharged more than once during the reference period.

Statistics for the NNHS are derived by a multistage estimation procedure that provides essentially unbiased national estimates and has three major components: (a) inflation by the reciprocals of the probabilities of sample selection; (b) adjustment for nonresponse; and (c) ratio adjustment to fixed totals. The surveys are adjusted for four types of nonresponse: (1) when an eligible nursing facility did not respond; (2) when the facility failed to complete the sampling lists; (3) when the facility did not complete the facility questionnaire but did complete the questionnaire for residents in the facility; and (4) when the facility did not provide information to complete the questionnaire for the sample resident or discharge.

Sample Size and Response Rates: In 1973–74 the sample of 2,118 homes was selected from the 1971 National Master Facility Inventory (NMFI) and from those that opened for business in 1972. For the 1977 NNHS the sample of 1,698 facilities was selected from nursing homes in the sampling frame, which consisted of all homes listed in the 1973 NMFI and those opening for business between 1973 and December 1976. The sample for the 1985 survey consisted of the 1,220 facilities selected from the 1982 NMFI, data for homes identified in the 1982 Complement Survey of the NMFI, data on hospital-based nursing homes obtained from the Health Care Financing Administration (now known as the Centers for Medicare & Medicaid Services), and data on nursing homes open for business between 1982 and June 1, 1984. The 1995 sample of 1,500 homes was selected from a sampling frame consisting of nursing homes from the 1991 National Health Provider Inventory (NHPI) and updated lists from the Agency Reporting System (ARS). ARS was an ongoing system designed to periodically update the NHPI and consisted primarily of lists or directories of facilities from State agencies, Federal agencies, and national voluntary organizations. For the 1997 survey, data were obtained from about 1,488 nursing homes from a sampling frame consisting of nursing homes listed on the 1991 NHPI that was updated with a current listing of nursing facilities supplied by the Health Care Finance Administration and other national organizations. The facility frame for the 1999 NNHS consisted of all nursing homes identified in the 1997 NNHS and updated with current nursing facilities listed by the Centers for Medicare & Medicaid Services and other national organizations. The 1999 sample consisted of 1,496 nursing homes. In 1995, 1997, and 1999, facility-level response rates were over 93 percent

Issues Affecting Interpretation: Samples of discharges and residents contain different populations with different characteristics. The resident sample is more likely to contain long-term nursing home residents and, conversely, to underestimate short nursing home stays. Because short-term residents are less likely to be on the nursing home rolls on a given night, they are less likely to be sampled. Estimates of discharges underestimate long nursing home stays. In addition, analysts should ensure that the underlying populations are similar across survey years—for example, whether the survey includes personal or domiciliary care homes.

##### References

Meiners MR. Selected operating and financial characteristics of nursing homes, United States, 1973–74 National Nursing Home Survey. National Center for Health Statistics. Vital Health Stat 13(22). 1975.
Van Nostrand JF, Zappolo A, Hing E, et al. The National Nursing Home Survey, 1977 summary for the United States. National Center for Health Statistics. Vital Health Stat 13(43). 1979.
Hing E, Sekscenski E, Strahan G. The National Nursing Home Survey: 1985 summary for the United States. National Center for Health Statistics. Vital Health Stat 13(97). 1989.
Strahan G. An overview of nursing homes and their current residents: Data from the 1995 National Nursing Home Survey. Advance data from vital and health statistics; no. 280. Hyattsville, MD: National Center for Health Statistics. 1997.
The National Nursing Home Survey: 1997 summary. National Center for Health Statistics. Vital Health Stat 13(147). 2000.
The National Nursing Home Survey: 1999 summary. National Center for Health Statistics. Vital Health Stat 13(152). 2002.
For More Information: See the National Health Care Survey Web site at www.cdc.gov/nchs/nhcs.htm and the NNHS Web site at www.cdc.gov/nchs/about/major/nnhsd/nnhsd.htm.

### National Survey on Drug Use & Health (NSDUH)

#### Substance Abuse and Mental Health Services Administration

Overview: The National Survey on Drug Use & Health (NSDUH), formerly called the National Household Survey on Drug Abuse (NHSDA), collects data on substance abuse and dependence, mental health problems, and receipt of substance abuse and mental health treatment.

Selected Content: NSDUH reports on the prevalence, patterns and consequences of drug and alcohol use and abuse in the general U.S. civilian noninstitutionalized population age 12 and over. Data are collected on the use of illicit drugs, the nonmedical use of licit drugs, and use of alcohol and tobacco products. The survey is conducted annually and is designed to produce drug and alcohol use incidence and prevalence estimates. Data are also collected periodically on special topics of interest such as criminal behavior, treatment, mental health, and attitudes about drugs.

Data Years: The NHSDA survey has been conducted since 1971. In 1999 the NHSDA underwent a major redesign affecting the method of data collection, sample design, sample size, and oversampling. In 2002 the survey underwent a name change to NSDUH as well as additional improvements and modifications to the survey.

Coverage: The survey is representative of persons 12 years of age and over in the civilian noninstitutionalized population in the United States. This includes civilians living on military bases and persons living in noninstitutionalized group quarters, such as college dormitories, rooming houses, and shelters. Persons excluded from the survey include homeless people who do not use shelters, active military personnel, and residents of institutional group quarters, such as jails and hospitals.

Methodology: The data collection method is in-person interviews conducted with a sample of individuals at their place of residence. Prior to 1999, the NSDUH used a paper-and-pencil interviewing (PAPI) methodology. Since 1999, the interview has been carried out with computer assisted interviewing (CAI) methodology. The survey uses a combination of computer-assisted personal-interviewing (CAPI), conducted by the interviewer for some basic demographic information, and audio computer-assisted self-interviewing (ACASI), for most of the questions. ACASI provides a highly private and confidential means of responding to questions to increase the level of honest reporting of illicit drug use and other sensitive behavior. The 2002 NSDUH employed a 50-State sample design with an independent, multistage area probability sample for each of the 50 States and the District of Columbia to support the development of both national and State-level estimates. Each State was stratified into regions (48 regions in each of 8 large States, 12 regions in each of 42 small States and the District of Columbia). At the first stage of sampling, 8 area segments were selected in each region, for a total of 7,200 sample units nationally. Approximately one-third of the total sample was dedicated to youths aged 12–17 years, one-third to young adults aged 18–25 years, and one-third to adults aged 26 years and over.

Sample Size and Response Rate: Nationally, 136,349 addresses were screened for the 2002 survey, and 68,126 completed interviews were obtained. The survey was conducted from January to December 2002. Weighted response rates for household screening and for interviewing were 90.7 and 78.9 percent, respectively.

Issues Affecting Interpretation: Several improvements to the survey were implemented in 2002. In addition to the name change, respondents were offered a $30 incentive payment for participation in the survey starting in 2002, and quality control procedures for data collection were enhanced in 2001 and 2002. Because of these improvements and modifications, estimates from the 2002 NSDUH should not be compared with estimates from the 2001 or earlier versions of the survey to examine changes over time. The data collected in 2002 represent a new baseline for tracking trends in substance use and other measures. Estimates of substance use for youth based on the NSDUH are not directly comparable with estimates based on Monitoring the Future (MTF) and Youth Risk Behavior Surveillance System (YRBSS). In addition to the fact that the MTF excludes dropouts and absentees, rates are not directly comparable across these surveys, because of differences in populations covered, sample design, questionnaires, interview setting, and statistical approaches to make the survey estimates generalizable to the entire population. The NSDUH survey collects data in homes, whereas the MTF and YRBSS collect data in school classrooms. The NSDUH estimates are tabulated by age, while the MTF and YRBSS estimates are tabulated by grade, representing different ages as well as different populations.

##### References

Substance Abuse and Mental Health Services Administration. 2003 Results from the 2002 National Survey on Drug Use and Health: National Findings. NHSDA Series: H-22, DHHS Pub. No. (SMA) 03–3836. Rockville, MD: Department of Health and Human Services. 2003.
Cowan CD. (2001). Coverage, Sample Design, and Weighting in Three Federal Surveys. Journal of Drug Issues.
For More Information: See the SAMHSA Web site at www.samhsa.gov.

### National Survey of Family Growth (NSFG)

#### Centers for Disease Control and Prevention

##### National Center for Health Statistics

Overview: The National Survey of Family Growth (NSFG) provides national data on factors affecting birth and pregnancy rates, adoption, and maternal and infant health.

Selected Content: Data elements include sexual activity, marriage, divorce and remarriage, unmarried cohabitation, contraception and sterilization, infertility, breastfeeding, pregnancy loss, low birthweight, and use of medical care for family planning and infertility.

Data Years: Five cycles of the survey have been completed: 1973, 1976, 1982, 1988, and 1995.

Coverage: Data from the National Survey of Family Growth (NSFG) are based on samples of women ages 15–44 years in the civilian noninstitutionalized population of the United States. The first and second cycles (1973 and 1976) excluded most women who had never been married. The third, fourth, and fifth cycles (1982, 1988, and 1995) included all women ages 15–44 years

Methodology: Interviews are conducted in person by professional female interviewers using a standardized questionnaire. In all cycles black women were sampled at higher rates than white women so that detailed statistics for black women could be produced.

In order to make national estimates from the sample for the millions of women ages 15–44 years in the United States, data for the interviewed sample women were (a) inflated by the reciprocal of the probability of selection at each stage of sampling (for example, if there was a 1 in 5,000 chance that a woman would be selected for the sample, her sampling weight was 5,000); (b) adjusted for nonresponse; and (c) poststratified, or forced to agree with benchmark population values based on data from the Current Population Survey of the U.S. Bureau of the Census .

Sample Size and Response Rates: For Cycle 1, from 101 PSUs, 10,879 women 15–44 years of age were selected, 9,797 of these were interviewed. In Cycle 2, from 79 PSUs, 10,202 eligible women were identified; of these, 8,611 were interviewed. In Cycle 3 household screener interviews were completed in 29,511 households (95.1 percent). Of the 9,964 eligible women identified, 7,969 were interviewed. In Cycle 4, 10,566 eligible women ages 15–44 years were sampled. Interviews were completed with 8,450 women. The response rate for the 1990 telephone reinterview was 68 percent of those responding to the 1988 survey and still eligible for the 1990 survey. In Cycle 5, of the 13,795 eligible women in the sample, 10,847 were interviewed.

##### References

French DK. National Survey of Family Growth, Cycle I: Sample design, estimation procedures, and variance estimation. National Center for Health Statistics. Vital Health Stat 2(76). 1978.
Grady WR. National Survey of Family Growth, Cycle II: Sample design, estimation procedures, and variance estimation. National Center for Health Statistics. Vital Health Stat 2(87). 198l.
Bachrach CA, Horn MC, Mosher WD, Shimizu I. National Survey of Family Growth, Cycle III: Sample design, weighting, and variance estimation. National Center for Health Statistics. Vital Health Stat 2(98). 1985.
Judkins DR, Mosher WD, Botman SL. National Survey of Family Growth: Design, estimation, and inference. National Center for Health Statistics. Vital Health Stat 2(109). 1991.
Goksel H, Judkins DR, Mosher WD. (1992). Nonresponse adjustments for a telephone follow-up to a National In-Person Survey. Journal of Official Statistics.
Kelly JE, Mosher WD, Duffer AP, Kinsey SH. Plan and operation of the 1995 National Survey of Family Growth. Vital Health Stat 1(36). 1997.
Potter FJ, Iannacchione VG, Mosher WD, Mason RE, Kavee JD. Sampling weights, imputation, and variance estimation in the 1995 National Survey of Family Growth. Vital Health Stat 2(124). 1998.
For More Information: See the NCHS Web site at www.cdc.gov/nchs/nsfg.htm.

### National Survey of Substance Abuse Treatment Services (N-SSATS)

#### Substance Abuse and Mental Health Services Administration

Overview: The National Survey of Substance Abuse Treatment Services (N-SSATS) collects data on the location, characteristics, and use of alcoholism and drug abuse treatment facilities and services throughout the 50 States, the District of Columbia, and other U.S. jurisdictions.

Selected Content: N-SSATS solicits data concerning facility and client characteristics for a specific reference day (October 1 in 1998 and 2000, March 29 in 2002, and March 31 in 2003) including number of individuals in treatment, substance of abuse (alcohol, drugs, or both), and types of services. In 1979 the National Institute on Alcohol Abuse and Alcoholism began cosponsoring the survey and began to cover alcohol treatment as well as drug treatment.

Data Years: The N-SSATS has evolved over time, going through various redesigns and changes in the responsible agency. The first survey to include most of the data elements that form the core of the N-SSATS was conducted by the National Institute on Drug Abuse in 1976. The survey has been conducted annually with a few exceptions. In 1992 the survey became the purview of the newly created Substance Abuse and Mental Health Services Administration. SAMHSA conducted the survey from 1995 to 1999 under the name the Uniform Facility Data Set survey. In 2000 the survey was redesigned and named the N-SSATS. The N-SSATS was conducted in 2000 and 2002–03. In 1999 a more limited version was conducted that collected information only about facilities and not about clients.

Coverage: Treatment facilities contacted through N-SSATS are identified from the Inventory of Substance Abuse Treatment Services (I-SATS) that lists all known substance abuse treatment facilities. The N-SSATS includes facilities that treat only substance abuse, as well as specialty substance abuse units operating within larger mental health facilities (for example, community mental health centers), general health (for example, hospitals), social service (for example, family assistance centers), and criminal justice (for example, probation departments) agencies. Public and private facilities are included.

Methodology: SAMHSA mails facility survey forms directly to the facilities and conducts follow-up interviews by telephone. Data collection was centralized in 1996. Since 1997, advance notification of facilities, improved methods to update contact information, and aggressive telephone follow-up has resulted in high response rates. In 1999 the survey was conducted entirely by telephone. In 2002 and 2003 respondents also were offered the option of completing the survey via the Internet.

Sample Size and Response Rate: The N-SSATS is a census of all known substance abuse treatment facilities. Response rates to the surveys were 91, 94, 95, and 97 percent in 1998, 2000, 2002, and 2003, respectively.

Issues Affecting Interpretation: More intense efforts at locating facilities and different exclusions in various years have contributed to fluctuations in numbers of facilities and clients. In 1999 enhanced reporting resulted in a 13 percent increase in facilities. In 2000 solo practitioners were excluded, contributing to a 12 percent decline in facilities and a 4 percent decline in clients. In 2002 enhanced reporting resulted in a 2 percent increase in facilities and a 14 percent increase in clients. Solo practitioners continued to be excluded in 2002 and 2003. Facilities located in jails, prisons, and detention centers, that is, facilities treating only incarcerated clients, have been excluded since 1999.

For More Information: See the OAS statistical information section of the SAMHSA Web site at www.oas.samhsa.gov.

### National Vital Statistics System (NVSS)

#### Centers for Disease Control and Prevention

##### National Center for Health Statistics

Overview: The National Vital Statistics System (NVSS) collects and publishes official national statistics on births, deaths, fetal deaths, and prior to 1996, marriages and divorces occurring in the United States based on U.S. Standard Certificates. Fetal deaths are classified and tabulated separately from other deaths. Detailed descriptions of the five Vital Statistics files (birth file, mortality file, multiple cause of death file, linked birth/infant death data set, and compressed mortality file) are presented separately below.

Data Years: The death registration area for 1900 consisted of 10 States, the District of Columbia, and a number of cities located in nonregistration States; it covered 40 percent of the continental U.S. population. The birth registration area was established in 1915 with 10 States and the District of Columbia. The birth and death registration areas continued to expand until 1933, when they included all 48 States and the District of Columbia. Alaska and Hawaii were added to both registration areas in 1959 and 1960, the years in which they gained statehood.

Coverage: The NVSS collects and presents U.S. resident data for the aggregate of 50 States, New York City, and the District of Columbia, as well as for each individual State and the District of Columbia. Vital events occurring in the United States to non-U.S. residents and vital events occurring abroad to U.S. residents are excluded.

Methodology: NCHS’s Division of Vital Statistics obtains information on births and deaths from the registration offices of each of the 50 States, New York City, the District of Columbia, Puerto Rico, the U.S. Virgin Islands, Guam, American Samoa, and Northern Mariana Islands. Until 1972 microfilm copies of all death certificates and a 50 percent sample of birth certificates were received from all registration areas and processed by NCHS. In 1972 some States began sending their data to NCHS through the Cooperative Health Statistics System (CHSS). States that participated in the CHSS program processed 100 percent of their death and birth records and sent the entire data file to NCHS on computer tapes. Currently, data are sent to NCHS through the Vital Statistics Cooperative Program (VSCP), following the same procedures as CHSS. The number of participating States grew from 6 in 1972 to 46 in 1984. Starting in 1985 all 50 States and the District of Columbia participated in VSCP.

U.S. Standard Certificates—U.S. Standard Live Birth and Death Certificates and Fetal Death Reports are revised periodically, allowing evaluation and addition, modification, and deletion of items. Beginning with 1989 revised standard certificates replaced the 1978 versions. The 1989 revision of the birth certificate included items to identify the Hispanic parentage of newborns and to expand information about maternal and infant health characteristics. The 1989 revision of the death certificate included items on educational attainment and Hispanic origin of decedents, as well as changes to improve the medical certification of cause of death. Standard certificates recommended by NCHS are modified in each registration area to serve the area’s needs. However, most certificates conform closely in content and arrangement to the standard certificate, and all certificates contain a minimum data set specified by NCHS. Following 1989, the next revisions of vital records went into effect in some States beginning in 2003, but full implementation in all States will be phased in over several years.

##### Birth File

Overview: Vital statistics natality data are a fundamental source of demographic, geographic, and medical and health information on all births occurring in the United States. This is one of the few sources of comparable health-related data for small geographic areas over an extended time period. The data are used to present the characteristics of babies and their mothers, track trends such as birth rates for teens, and compare natality trends with other countries.

Selected Content: The natality file includes characteristics about the baby such as sex, birth weight, weeks of gestation; demographic information about the parents such as age, race, Hispanic origin, parity, educational attainment, marital status, and State of residence; medical and health information such as prenatal care based on hospital records; and behavioral risk factors for the birth such as mother’s tobacco use during pregnancy.

Data Years: The birth registration area began in 1915 with 10 States and the District of Columbia.

Methodology: In the United States, State laws require birth certificates to be completed for all births. The registration of births is the responsibility of the professional attendant at birth, generally a physician or midwife. The birth certificate must be filed with the local registrar of the district in which the birth occurs. Each birth must be reported promptly—the reporting requirements vary from State to State, ranging from 24 hours after the birth to as much as 10 days.

Federal law mandates national collection and publication of birth and other vital statistics data. The National Vital Statistics System is the result of cooperation between NCHS and the States to provide access to statistical information from birth certificates. Standard forms for the collection of the data and model procedures for the uniform registration of the events are developed and recommended for State use through cooperative activities of the States and NCHS. NCHS shares the costs incurred by the States in providing vital statistics data for national use.

Issues Affecting Interpretation: The number of States reporting information on maternal education, Hispanic origin, marital status, and tobacco use during pregnancy has increased over the years. Interpretation of trend data should take into consideration expansion of reporting areas and immigration. See Appendix II for methodological and reporting area changes for the following birth certificate items: Age (maternal age); Education (maternal education); Hispanic origin; Marital status; Prenatal care; Race; and Tobacco use.

###### Reference

National Center for Health Statistics, Vital Statistics of the United States, Vol. I Natality, Technical Appendix.
For More Information: See the Birth Data Web site at www.cdc.gov/nchs/births.htm.

##### Mortality File

Overview: Vital statistics mortality data are a fundamental source of demographic, geographic, and cause-of-death information. This is one of the few sources of comparable health-related data for small geographic areas over an extended time period. The data are used to present the characteristics of those dying in the United States, to determine life expectancy, and to compare mortality trends with other countries.

Selected Content: The mortality file includes demographic information on age, sex, race, Hispanic origin, State of residence, and educational attainment, and medical information on cause of death.

Data Years: The death registration area began in 1900 with 10 States and the District of Columbia.

Methodology: By law, the registration of deaths is the responsibility of the funeral director. The funeral director obtains demographic data for the death certificate from an informant. The physician in attendance at the death is required to certify the cause of death. Where death is from other than natural causes, a coroner or medical examiner may be required to examine the body and certify the cause of death. Data for the entire United States refer to events occurring within the United States; data for geographic areas are by place of residence. See Appendix II for methodological and reporting area changes for the following death certificate items: Education; Hispanic origin; and Race.

Issues Affecting Interpretation: International Classification of Diseases (ICD), by which cause of death is coded and classified, is revised approximately every 10 to 15 years. Revisions of the ICD may cause discontinuities in trend data by cause of death. Comparing death rates by cause of death across ICD revisions should be conducted with caution and with reference to the comparability ratio. (See Appendix II, Comparability ratio.) The death certificate has been revised periodically. A revised U.S. Standard Certificate of Death was recommended for State use beginning on January 1, 1989. Among the changes were the addition of a new item on educational attainment and Hispanic origin of decedent and changes to improve the medical certification of cause of death.

###### References

Grove RD, Hetzel AM. Vital statistics rates in the United States, 1940–60. Washington, DC: Government Printing Office. 1968.
National Center for Health Statistics, Vital Statistics of the United States, Vol. II Mortality Part A, Technical Appendix, available at www.cdc.gov/nchs/datawh/statab/pubd/ta.htm.
For More Information: See the Mortality Data Web site at www.cdc.gov/nchs/about/major/dvs/mortdata.htm.

##### Multiple Cause-of-Death File

Overview: Multiple cause-of-death data reflect all medical information reported on death certificates and complement traditional underlying cause-of-death data. Multiple-cause data give information on diseases that are a factor in death whether or not they are the underlying cause of death; on associations among diseases; and on injuries leading to death.

Selected Content: In addition to the same demographic variables listed for the mortality file, the multiple cause-of-death file includes record axis and entity axis cause-of-death data (see Methodology section).

Data Years: Multiple cause-of-death data files are available for every data year since 1968.

Methodology: NCHS is responsible for compiling and publishing annual national statistics on causes of death. In carrying out this responsibility, NCHS adheres to the World Health Organization Nomenclature Regulations. These Regulations require that (1) cause of death be coded in accordance with the applicable revision of the International Classification of Diseases (ICD) (see Appendix II, table IV and ICD); and (2) underlying cause of death be selected in accordance with international rules. Traditionally, national mortality statistics have been based on a count of deaths, with one underlying cause assigned for each death.

Starting with data year 1968, electronic files exist with multiple cause-of-death information. These files contain codes for all diagnostic terms and related codable information recorded on the death certificate. These codes make up the entity axis and are the input for a software program called TRANSAX. The TRANSAX program eliminates redundant entity axis codes and combines other entity axis codes to create the best set of ICD codes for a record. The output of the TRANSAX program is the record axis. Record axis data are generally used for research and analysis of multiple or nonunderlying cause of death. Because the function of the TRANSAX program is not to select a single underlying cause of death, record axis data may or may not include the underlying cause. Tabulations of underlying and nonunderlying cause of death in table 48 (selected occupational diseases) are compiled by searching both underlying cause of death and record axis data.

###### Reference

Multiple Causes of Death in the United States. Monthly Vital Statistics Report. Vol. 32, No. 10 Supplement (2). February 17, 1984.
For More Information: See the mortality multiple cause-of-death data file page at www.cdc.gov/nchs/products/elec_prods/subject/mortmcd.htm.

##### Linked Birth/Infant Death Data Set

Overview: National linked files of live births and infant deaths are used for research on infant mortality.

Selected Content: The linked birth/infant death data set includes all variables on the natality file, including racial and ethnic information, as well as variables on the mortality file, including cause of death and age at death.

Data Years: National linked files of live births and infant deaths were first produced for the 1983 birth cohort. Birth cohort linked file data are available for 1983–91 and period linked file data for 1995–2001. National linked files do not exist for 1992–94.

Methodology: To create the linked data files, death certificates are linked with corresponding birth certificates for infants who die in the United States before their first birthday. Linkage is about 97–98 percent complete. The linkage makes available for analysis of infant mortality extensive information from the birth certificate about the pregnancy, maternal risk factors, infant characteristics, and health items at birth.

Starting with data year 1995, more timely linked file data are produced in a period data format preceding the release of the corresponding birth cohort format. Other changes to the data set starting with 1995 data include addition of record weights to correct for the 2.2–2.5 percent of records that could not be linked and for the addition of an imputation for not stated birthweight. The 1995–2001 weighted mortality rates are from less than 1 percent to 4.1 percent higher than unweighted rates for the same period. The 1995–2001 weighted mortality rates with imputed birthweight are less than 1 percent to 6.3 percent higher than unweighted rates with imputed birthweight for the same period.

Issues Affecting Interpretation: Period linked file data starting with 1995 are not strictly comparable with birth cohort data for 1983–91. While birth cohort linked files have methodological advantages, their production incurs substantial delays in data availability, since it is necessary to wait until the close of a second data year to include all infant deaths to the birth cohort.

###### Reference

Mathews TJ, Menacker F, MacDorman MF. (2003). Infant mortality statistics from the 2001 period linked birth/infant death data set. Natl Vital Stat Rep.
For More Information: See the NCHS Linked Birth and Infant Death Data Web site at www.cdc.gov/nchs/linked.htm.

##### Compressed Mortality File

Overview: The Compressed Mortality File (CMF) is a county-level national mortality and population database.

Selected Content: The Compressed Mortality database contains mortality data derived from the detailed mortality files of the National Vital Statistics System and U.S. Census Bureau estimates of U.S. national, State, and county resident populations. Number of deaths, crude death rates, and age-adjusted death rates can be obtained by place of residence (total U.S., State, and county), age group, race (white, black, and other), sex, year of death, and underlying cause of death.

Data Years: The CMF spans the years 1968–2001. On CDC WONDER, data are available starting with 1979, corresponding with the initial year that ICD–9 was used for coding cause of death.

Methodology: In Health, United States, the CMF is used to compute death rates by urbanization level of decedent’s county of residence. Counties are categorized according to level of urbanization based on an NCHS-modified version of the 1993 rural-urban continuum codes for metropolitan and nonmetropolitan counties developed by the Economic Research Service, U.S. Department of Agriculture. See Appendix II, Urbanization.

For More Information: Contact D. Ingram, Office of Analysis and Epidemiology, National Center for Health Statistics, 3311 Toledo Road, Room 6226, Mailstop P-08, Hyattsville, MD 20782; or see the CDC Wonder Web site at http://wonder.cdc.gov/mortSQL.html.

### Online Survey Certification and Reporting Database (OSCAR)

#### Centers for Medicare & Medicaid Services

Overview: The Online Survey Certification and Reporting (OSCAR) is an administrative database containing detailed information on all Medicare and Medicaid certified institutional health care providers, including all currently and previously certified Medicare and Medicaid nursing homes in the United States and Territories. (Data for the Territories are not shown in this report). The purpose of the nursing home survey certification process is to ensure that nursing facilities meet the current Centers for Medicare & Medicaid Services (CMS) care requirements and thus can be reimbursed for services furnished to Medicare and Medicaid beneficiaries.

Selected Content: OSCAR contains information on facility and patient characteristics and health deficiencies issued by the government during State surveys.

Data Years: OSCAR has been maintained by CMS, formerly the Health Care Financing Administration (HCFA), since 1992. OSCAR is an updated version of the Medicare and Medicaid Automated Certification System that had been in existence since 1972.

Coverage: All nursing homes in the United States that receive Medicare or Medicaid payments are included. Nursing homes that are intermediate care facilities for the mentally retarded and Department of Veterans Affairs nursing homes are excluded.

Methodology: Information on the number of beds and other facility characteristics comes from HCFA form 671, and information on residents and resident characteristics is collected on HCFA form 672. A nursing home representative fills out the forms, and they are submitted to CMS. The information provided on HCFA forms 671 and 672 can be audited at any time.

All certified nursing homes are inspected by representatives of the State survey agency (generally the department of health) at least once every 15 months. Therefore, a complete census must be based on a 15-month reporting cycle rather than a 12-month cycle. Some nursing homes are inspected twice or more often during any given reporting cycle. To avoid overcounting, the data must be edited and duplicates removed. Data editing and compilation were performed by Cowles Research Group and published in the group’s Nursing Home Statistical Yearbook series.

##### References

Cowles CM, 1995; 1996; 1997 Nursing Home Statistical Yearbook. Anacortes, WA: Cowles Research Group (CRG). 1995; 1997; 1998.
Cowles CM, 1998; 1999; 2000; 2001 Nursing Home Statistical Yearbook. Washington, DC: American Association of Homes and Services for the Aging (AAHSA). 1999; 2000; 2001; 2002.
HCFA: OSCAR Data Users Reference Guide, 1995, available from CMS, Health Standards and Quality Bureau, HCFA/HSQB S2 11–07, 7500 Security Boulevard, Baltimore, MD 21244.
For More Information: See the CMS Web site at www.cms.hhs.gov or the CRG Web site at www.longtermcareinfo.com/crg or the AAHSA Web site at www.aahsa.org.

### Population Census and Population Estimates

#### Bureau of the Census

##### Decennial Census

The census of population (decennial census) has been held in the United States every 10 years since 1790. The decennial census has enumerated the resident population as of April 1 of the census year ever since 1930. Data on sex, race, age, and marital status are collected from 100 percent of the enumerated population. More detailed information such as income, education, housing, occupation, and industry are collected from a representative sample of the population.

##### Race Data on the 1990 Census

The question on race on the 1990 census was based on the Office of Management and Budget’s (OMB) “1977 Statistical Policy Directive 15, Race and Ethnicity Standards for Federal Statistics and Administrative Reporting.” This document specified rules for the collection, tabulation, and reporting of race and ethnicity data within the Federal statistical system. The 1977 standards required Federal agencies to report race-specific tabulations using four single-race categories: American Indian or Alaska Native, Asian or Pacific Islander, black, and white. Under the 1977 standards, race and ethnicity were considered to be two separate and distinct concepts. Thus, persons of Hispanic origin may be of any race.

##### Race Data on the 2000 Census

The question on race on the 2000 census was based on OMB’s 1997 “Revisions of the Standards for the Classification of Federal Data on Race and Ethnicity” (see Appendix II, Race). The 1997 Standards incorporated two major changes in the collection, tabulation, and presentation of race data. First, the 1997 standards increased from four to five the minimum set of categories to be used by Federal agencies for identification of race: American Indian or Alaska Native, Asian, black or African American, Native Hawaiian or Other Pacific Islander, and white. Second, the 1997 standards included the requirement that Federal data collection programs allow respondents to select one or more race categories when responding to a query on their racial identity. This provision means that there are potentially 31 race groups, depending on whether an individual selects one, two, three, four, or all five of the race categories. The 1997 standards continue to call for use, when possible, of a separate question on Hispanic or Latino ethnicity and specify that the ethnicity question should appear before the question on race. Thus, under the 1997 standards, as under the 1977 standards, Hispanics may be of any race.

##### Modified Decennial Census Files

For several decades the Census Bureau has produced modified decennial census files. These modified files incorporate adjustments to the 100 percent April 1 count data for 1) errors in the census data discovered subsequent to publication, 2) misreported age data, and 3) nonspecified race.

For the 1990 census, the Census Bureau modified the age, race, and sex data on the census and produced the Modified Age Race Sex (MARS) file. The differences between the population counts on the original census file and the MARS file are primarily a result of modification of the race data. Of the 248.7 million persons enumerated in 1990, 9.8 million persons did not specify their race (over 95 percent were of Hispanic origin). For the 1990 MARS file, these persons were assigned the race reported by a nearby person with an identical response to the Hispanic origin question.

For the 2000 census, the Census Bureau modified the race data on the census and produced the Modified Race Data Summary File. For this file, persons who reported “Some other race” as part of their race response were assigned to one of the 31 race groups, which are the single- and multiple-race combinations of the five race categories specified in the 1997 race and ethnicity standards. Persons who did not specify their race were assigned to one of the 31 race groups using imputation. Of the 18.5 million persons who reported “Some other race” as part of their race response, or who did not specify their race, 16.8 million (90.4 percent) were of Hispanic origin.

##### Bridged-Race Population Estimates for Census 2000

Race data on the 2000 census are not comparable with race data on other data systems that are continuing to collect data using the 1977 standards on race and ethnicity during the transition to full implementation of the 1997 standards. For example, most of the States in the Vital Statistics Cooperative Program will revise their birth and death certificates to conform to the 1997 standards after 2000. Thus, population estimates for 2000 and beyond with race categories comparable to the 1977 categories are needed so that race-specific birth and death rates can be calculated. To meet this need, NCHS, in collaboration with the U.S. Census Bureau, developed methodology to bridge the 31 race groups in Census 2000 to the four single-race categories specified under the 1977 standards.

The bridging methodology was developed using information from the 1997–2000 National Health Interview Survey (NHIS) The NHIS provides a unique opportunity to investigate multiple-race groups because since 1982, the NHIS has allowed respondents to choose more than one race but has also asked respondents reporting multiple races to choose a “primary” race. The bridging methodology developed by NCHS involved the application of regression models relating person-level and county-level covariates to the selection of a particular primary race by the multiple-race respondents. Bridging proportions derived from these models were applied by the U.S. Census Bureau to the Census 2000 Modified Race Data Summary File. This application resulted in bridged counts of the April 1, 2000, resident single-race populations for four racial groups, American Indian or Alaska Native, Asian or Pacific Islander, black, and white.

For More Information about bridged-race population estimates, see Ingram DD, Parker JD, Schenker N, et al. United States Census 2000 population with bridged race categories. National Center for Health Statistics. Vital Health Stat 2(135). 2003; and the NCHS Web site for U.S. Census Populations with Bridged Race Categories www.cdc.gov/nchs/about/major/dvs/popbridge/popbridge.htm.

##### Postcensal Population Estimates

Postcensal population estimates are estimates made for the years following a census, before the next census has been taken. National postcensal population estimates are derived by updating the resident population enumerated in the decennial census using a components of population change approach. The following formula is used to update the decennial census counts:

1. decennial census enumerated resident population
2. + births to U.S. resident women,
3. − deaths to U.S. residents,
4. + net international migration,
5. + net movement of U.S. Armed Forces and U.S. civilian citizens

State postcensal estimates are based on similar data and on a variety of other data series, including school statistics from State departments of education and parochial school systems. The postcensal estimates are consistent with official decennial census figures and do not reflect estimated decennial census underenumeration.

The Census Bureau has produced a postcensal series of estimates of the July 1 resident population of the United States based on Census 2000 by applying the components of change methodology to the Modified Race Data Summary File. These postcensal estimates have race data for 31 race groups, in accordance with the 1997 race and ethnicity standards. So that the race data for the 2000-based postcensal estimates would be comparable with race data on vital records, the Census Bureau applied the NHIS bridging methodology to the 31-race group postcensal population estimates to obtain postcensal estimates for the four single-race categories (American Indian or Alaska Native, Asian or Pacific Islander, black, and white). Bridged-race postcensal population estimates are available at www.cdc.gov/nchs/about/major/dvs/popbridge/popbridge.htm.

Note that before the bridged-race April 1, 2000, population counts and the bridged-race 2000-based postcensal estimates were available, the Census Bureau extended their postcensal series of estimates based on the 1990 census (with the four single-race categories needed to compute vital rates) to July 1, 2001. NCHS initially calculated vital rates for 2000 using 1990-based July 1, 2000 postcensal population estimates and vital rates for 2001 using 1990-based July 1, 2001 postcensal estimates. Vital rates for 2000 have been revised using the bridged-race April 1, 2000, population counts, and vital rates for 2001 have been revised using the 2000-based bridged-race July 1, 2001, postcensal population estimates.

##### Intercensal Population Estimates

The further from the census year on which the postcensal estimates are based, the less accurate are the postcensal estimates. With the completion of the decennial census at the end of the decade, intercensal estimates for the preceding decade were prepared to replace the less accurate postcensal estimates. Intercensal population estimates take into account the census of population at the beginning and end of the decade. Thus intercensal estimates are more accurate than postcensal estimates as they correct for the “error of closure” or difference between the estimated population at the end of the decade and the census count for that date. The “error of closure” at the national level was quite small for the 1960s (379,000). However, for the 1970s it amounted to almost 5 million; for the 1980s, 1.5 million; and for the 1990s, about 6 million. The error of closure differentially affects age, race, sex, and Hispanic origin subgroup populations as well as the rates based on these populations. Vital rates that were calculated using postcensal population estimates are routinely revised when intercensal estimates become available because the intercensal estimates correct for the error of closure.

Intercensal estimates for the 1990s with race data comparable to the 1977 standards have been derived so that vital rates for the 1990s could be revised to reflect census 2000. Calculation of the intercensal population estimates for the 1990s was complicated by the incomparability of the race data on the 1990 and 2000 censuses. The Census Bureau, in collaboration with National Cancer Institute and NCHS, derived race-specific intercensal population estimates for the 1990s using the 1990 MARS file as the beginning population base and the bridged-race population estimates for April 1, 2000, as the ending population base. Bridged-race intercensal population estimates are available at www.cdc.gov/nchs/about/major/dvs/popbridge/popbridge.htm.

##### Special Population Estimates

Special population estimates are prepared for the education reporting area for mortality statistics because educational attainment of decedent is not reported by all 50 States. The Housing and Household Economics Statistics Division of the U.S. Bureau of the Census currently produces unpublished estimates of populations by age, race, sex, and educational attainment for NCHS. These population estimates are based on the Current Population Survey, adjusted to resident population controls. The control totals used for July 1, 1994–96 are 1990-based population estimates for 45 reporting States and the District of Columbia (DC); for July 1, 1997–2000, 1990-based postcensal population estimates for 46 reporting States and DC; and for July 1, 2001–02, 2000-based postcensal population estimates for 47 reporting States and DC. See Appendix II, Education.

For More Information: See the U.S. Bureau of the Census Web site at www.census.gov/.

### Sexually Transmitted Disease (STD) Surveillance

#### Centers for Disease Control and Prevention

##### National Center of HIV, STD, and TB Prevention

Overview: Surveillance information on incidence and prevalence of sexually transmitted diseases (STDs) is used to inform public and private health efforts to control these diseases.

Selected Content: Case reporting data are available for nationally notifiable chanchroid, chlamydia, gonorrhea, and syphilis; surveillance of other STDs, such as genital herpes simplex virus (HSV), genital warts or other human papillomavirus infections, and trichomoniasis are based on estimates of office visits in physicians’ office practices provided by the National Disease and Therapeutic Index (NDTI).

Data Years: STD national surveillance data have been collected since 1941.

Coverage: Case reports of STDs are reported to CDC by STD surveillance systems operated by State and local STD control programs and health departments in 50 States, the District of Columbia, selected cities, 3,139 U.S. counties, outlying areas comprised of U.S. dependencies and possessions, and independent nations in free association with the United States. Data from outlying areas are not included in Health, United States.

Methodology: Information is obtained from the following sources of data: (1) case reports from STD project areas; (2) prevalence data from the Regional Infertility Prevention Program, the National Job Training Program (formerly the Job Corps), the Jail STD Prevalence Monitoring Projects, the adolescent Women Reproductive Health Monitoring Project, the Men Who Have Sex With Men (MSM) Prevalence Monitoring Project, and the Indian Health Service; (3) sentinel surveillance of gonococcal antimicrobial resistance from the Gonococcal Isolate Surveillance Project (GISP); and (4) national sample surveys implemented by federal and private organizations. STD data are submitted to CDC on a variety of hard-copy summary reporting forms (monthly, quarterly, and annually) and in electronic summary or individual case-specific (line-listed) formats via the National Electronic Telecommunications System for Surveillance (NETSS).

Issues Affecting Interpretation: Because of incomplete diagnosis and reporting, the number of STD cases reported to CDC undercounts the actual number of cases occurring among the U.S. population.

###### Reference

Centers for Disease Control and Prevention. Sexually Transmitted Disease Surveillance, 2002. Atlanta, GA: Department of Health and Human Services. 2003.
For More Information: See the STD Prevention Web site at: www.cdc.gov/std/stats/.

### Surveillance, Epidemiology, and End Results Program (SEER)

#### National Cancer Institute

Overview: The Surveillance, Epidemiology, and End Results (SEER) program tracks incidence of persons diagnosed with cancer during the year as well as follow-up information on all previously diagnosed patients until death.

Selected Content: SEER registries routinely collect data on patient demographics, primary tumor site, morphology, stage at diagnosis, first course of treatment, and follow-up for vital status.

Data Years: Case ascertainment for SEER began on January 1, 1973, and has continued for more than 30 years.

Coverage: SEER cancer registries were initiated in 1973 in Connecticut, Iowa, New Mexico, Utah, Hawaii, and Detroit and San Francisco-Oakland. Registries were added as follows: in 1974–75, Atlanta and Seattle-Puget Sound; in 1978, 10 predominantly black rural counties in Georgia; in 1980, American Indians in Arizona; New Orleans, Louisiana (1974–77, rejoined 2001); New Jersey (1979–89, rejoined 2001); and Puerto Rico (1973–89); in 1992, Alaska Native populations in Alaska and Hispanics in Los Angeles County and San Jose-Monterey; in 2001, Kentucky, Greater California, New Jersey, and Louisiana. The SEER Program currently collects and publishes cancer incidence and survival data from 14 population-based cancer registries and three supplemental registries covering approximately 26 percent of the U.S. population.

The following combination of SEER registries are commonly used for statistical analyses and are used for analysis of cancer survival rates in Health, United States: the SEER 9 registries of Atlanta, Connecticut, Detroit, Hawaii, Iowa, New Mexico, San Francisco-Oakland, Seattle-Puget Sound, and Utah. Analysis of cancer incidence covers residents in the following SEER 12 registries: the SEER 9 registries plus Los Angeles, San Jose-Monterey, and the Alaska Native Tumor Registry.

Methodology: A cancer registry (or tumor registry) collects and stores data on cancers diagnosed in a specific hospital or medical facility (hospital-based registry) or in a defined geographic area (population-based registry). A population-based registry is generally composed of a number of hospital-based registries. In SEER registry areas, trained coders abstract medical records using the International Classification of Diseases for Oncology, Third Edition (ICD-O-3), which provides a coding system for onset and stage of specific cancers. The third edition, implemented in 2001, is the first complete review and revision of the text and guidelines since its original publication in 1988.

Population estimates used to calculate incidence rates are obtained from the U.S. Bureau of the Census. NCI uses estimation procedures as needed to obtain estimates for years and races not included in data provided by the U.S. Bureau of the Census. Life tables used to determine normal life expectancy when calculating relative survival rates were obtained from NCHS and in-house calculations. Separate life tables are used for each race-sex-specific group included in the SEER Program.

Issues Affecting Interpretation: Because of the addition of registries over time, analysis of long-term incidence and survival trends is limited to those registries that have been in SEER for similar lengths of time. Analysis of Hispanic, American Indian and Alaska Native data is limited to shorter trends. Rates presented in this report may differ somewhat from previous reports because of revised population estimates and the addition and deletion of small numbers of incidence cases.

##### Reference

Ries LAG, Eisner MP, Kosary CL, et al. (eds). SEER Cancer Statistics Review 1975–2001. Bethesda, MD: National Cancer Institute. 2004 available at http://seer.cancer.gov/csr/1975_2001.
For More Information: See the SEER Web site at www.seer.cancer.gov.

### Survey of Mental Health Organizations (SMHO)

#### Substance Abuse and Mental Health Services Administration (SAMHSA)

Overview: The Survey of Mental Health Organizations and General Hospital Mental Health Services (SMHO/GHMHS) collects data on number and characteristics of specialty mental health organizations in the United States.

Selected Content: The inventory collects basic information such as types of mental health organizations, ownership, number of additions and residents, and number of beds. The sample survey is a more detailed questionnaire that covers types of services provided, revenues and expenditures, staffing, and many items addressed to managed behavioral health care.

Data Years: The Inventory of Mental Health Organizations (IMHO/GHMHS) was conducted biannually from 1986 until 1994. The SMHO replaced the IMHO/GHMHS in 1998. The SMHO and the inventory used as its sampling frame have been conducted biannually starting in 1998.

Coverage: Organizations included are State and county mental hospitals, private psychiatric hospitals, non-Federal general hospitals with separate psychiatric services, Department of Veterans Affairs medical centers, residential treatment centers for emotionally disturbed children, freestanding outpatient psychiatric clinics, partial care organizations, freestanding day-night organizations, and multiservice mental health organizations not elsewhere classified.

Methodology: The IMHO was an inventory of all mental health organizations. Its core questionnaire included versions designed for specialty mental health organizations and another for non-Federal general hospitals with separate psychiatric services. The data system was based on questionnaires mailed every other year to mental health organizations in the United States. In 1998 the IMHO was replaced by the SMHO. The SMHO is made up of two parts. A complete inventory is done by postcard gathering a limited amount of information. The inventory is used as a sampling frame for the SMHO, which contains most of the information from the IMHO core questionnaire as well as new items about managed behavioral health care.

Sample Size and Response Rate: In Phase 1, all 10,083 organizations were inventoried. A complete enumeration was needed to define the sampling frame for the Sample Survey. In Phase II, general hospitals without separate mental health units, community residential organizations and managed behavioral health care organizations were dropped from the sampling frame, which leaves 4,659 organizations. From this number, approximately 1,602 organizations were drawn to permit both national and State estimates. The response rate was over 90 percent.

Issues Affecting Interpretation: Revisions to definitions of providers include phasing out Community Mental Health Centers as a category after 1981–82; increasing the number of multiservice mental health organizations from 1981 to 1986; increasing the number of psychiatric outpatient clinics in 1981–82, but decreasing the number in 1983–84, 1986, 1990, and 1992; and increasing the number of partial care services in 1983–84. These changes should be noted when interyear comparisons for the affected organizations and service types are made. The increase in the number of general hospitals with separate psychiatric services was partially a result of a more concerted effort to identify these organizations. Forms had been sent only to those hospitals previously identified as having a separate psychiatric service. Beginning in 1980–81, a screener form was sent to general hospitals not previously identified as providing a separate psychiatric service to determine whether they had such a service.

##### Reference

Center for Mental Health Services. Mental Health, United States, 2000. Manderscheid R, Henderson MJ, eds. DHHS Pub. No. (SMA) 01–3537. Washington, DC: Department of Health and Human Services. 2001.
For More Information: See the Center for Mental Health Services Web site at www.samhsa.gov/centers/cmhs/cmhs.html.

### Survey of Occupational Injuries and Illnesses (SOII)

#### Bureau of Labor Statistics

Overview: The Survey of Occupational Injuries and Illnesses (SOII) is a Federal/State program that collects statistics used to identify problems with workplace safety and develop programs to improve workplace safety.

Selected Content: Data include the number of injuries and illnesses by industry. The case and demographic data provide additional details on workers injured, the nature of the disabling condition, and the event and source producing that condition for those cases that involve one or more days away from work.

Data Years: The Bureau of Labor Statistics (BLS) has conducted an annual survey since 1971.

Coverage: The data represent persons employed in private industry establishments in the United States. The survey excludes the self-employed, farms with fewer than 11 employees, private households, Federal government agencies, and State and local government agencies.

Methodology: Survey estimates of occupational injuries and illnesses are based on a scientifically selected probability sample of establishments, rather than a census of all establishments. An independent sample is selected for each State and the District of Columbia that represents industries in that jurisdiction. BLS includes all the State samples in the national sample.

Establishments included in the survey are instructed in a mailed questionnaire to provide summary totals of all entries for the previous calendar year to its Log and Summary of Occupational Injuries and Illnesses (OSHA No. 200 form). In addition, from the selected establishments, approximately 550,000 injuries and illnesses with days away from work are sampled to obtain demographic and detailed case characteristic information. An occupational injury is any injury such as a cut, fracture, sprain, or amputation that results from a work-related event or from a single instantaneous exposure in the work environment. An occupational illness is any abnormal condition or disorder other than one resulting from an occupational injury, caused by exposure to factors associated with employment. It includes acute and chronic illnesses or diseases that may be caused by inhalation, absorption, ingestion, or direct contact. Prior to 2002, injury and illness cases involved days away from work, days of restricted work activity, or both (lost workday cases). Starting in 2002, injury and illness cases may involve days away from work, job transfer, or restricted work activity. Restriction may involve shortened hours, a temporary job change, or temporary restrictions on certain duties (for example, no heavy lifting) of a worker’s regular job.

Sample Size and Response Rates: Employer reports were collected from about 182,800 private industry establishments in 2002. The response rate is about 92 percent.

Issues Affecting Interpretation: The number of injuries and illnesses reported in any given year can be influenced by the level of economic activity, working conditions and work practices, worker experience and training, and number of hours worked. Long-term latent illnesses caused by exposure to carcinogens are believed to be understated in the survey’s illness measures. In contrast, new illnesses such as contact dermatitis and carpal tunnel syndrome are easier to relate directly to workplace activity.

Effective January 1, 2002, the Occupational Safety and Health Administration (OSHA) revised its requirement for recording occupational injuries and illnesses. Because of the revised recordkeeping rule, the estimates from the 2002 survey are not comparable with those from previous years. See www.osha-slc.gov/recordkeeping/index.html for details about the revised recordkeeping requirements.

Data for the mining industry and for railroad activities are provided by Department of Labor’s Mine Safety and Health Administration and Department of Transportation’s Federal Railroad Administration. Neither of these agencies adopted the revised OSHA recordkeeping requirements for 2002. Therefore, estimates for these industries for 2002 are not comparable with estimates for other industries but are comparable with estimates for prior years. Excluded from the survey are self-employed individuals; farmers with fewer than 11 employees; private households; Federal Government agencies; and employees in State and local government agencies. Starting in 1988, establishments were classified in industry categories based on the 1987 Standard Industrial Classification (SIC) Manual, as defined by the Office of Management and Budget. Prior to 1988, establishments were classified according to the 1972 edition, 1977 supplement. See Appendix II, Industry.

##### Reference

Bureau of Labor Statistics. Workplace Injuries and Illnesses in 2002, Washington, DC: Department of Labor. December 2003.
For More Information: See the BLS occupational safety and health Web site at www.bls.gov/iif/home.htm.

### Youth Risk Behavior Survey (YRBS)

#### Centers for Disease Control and Prevention

##### National Center for Chronic Disease Prevention and Health Promotion

Overview: The national Youth Risk Behavior Survey (YRBS) monitors health risk behaviors among students in grades 5–12 that contribute to morbidity and mortality in both adolescence and adulthood.

Selected Content: Data are collected on tobacco use, dietary behaviors, physical activity, alcohol and other drug use, sexual behaviors that contribute to unintended pregnancy and sexually transmitted diseases including HIV infection, and behaviors that contribute to unintentional injuries and violence.

Data Years: The national YRBS of high school students was conducted in 1990, 1991, 1993, 1995, 1997, 1999, 2001, and 2003.

Coverage: Data are representative of high school students in public and private schools in the United States.

Methodology: The national YRBS school-based surveys employ a three-stage cluster sample design to produce a nationally representative sample of students in grades 5–12 attending public and private high schools. The first-stage sampling frame contains primary sampling units (PSUs) consisting of large counties or groups of smaller, adjacent counties. The PSUs are then stratified based on degree of urbanization and relative percentage of black and Hispanic students in the PSU. The PSUs are selected from these strata with probability proportional to school enrollment size. At the second sampling stage, schools are selected with probability proportional to school enrollment size. To enable separate analysis of data for black and Hispanic students, schools with substantial numbers of black and Hispanic students are sampled at higher rates than all other schools. The third stage of sampling consists of randomly selecting one or two intact classes of a required subject from grades 5–12 at each chosen school. All students in the selected classes are eligible to participate in the survey. A weighting factor is applied to each student record to adjust for nonresponse and for the varying probabilities of selection, including those resulting from the oversampling of black and Hispanic students.

Sample Size and Response Rate: The sample size for the 2001 YRBS was 13,601. The school response rate was 75 percent and the student response rate was 83 percent, for an overall response rate of 63 percent.

Issues Affecting Interpretation: National YRBS data are subject to at least two limitations. First, these data apply only to adolescents who attend regular high school. These students may not be representative of all persons in this age group because those who have dropped out of high school or attend an alternative high school are not surveyed. Second, the extent of underreporting or overreporting cannot be determined, although the survey questions demonstrate good test-retest reliability.

Estimates of substance use for youth based on the YRBS differ from the National Survey on Drug Use & Health (NSDUH) and Monitoring the Future (MTF). Rates are not directly comparable across these surveys because of differences in populations covered, sample design, questionnaires, interview setting, and statistical approaches to make the survey estimates generalizable to the entire population. The NSDUH survey collects data in homes, whereas the MTF and YRBS collect data in school classrooms. The NSDUH estimates are tabulated by age, while the MTF and YRBS estimates are tabulated by grade, representing different ages as well as different populations.

###### References

CDC. Youth risk behavior surveillance—United States, 1999. CDC surveillance summaries, MMWR 2000;49 (SS-05).
CDC. Youth risk behavior surveillance—United States, 2001. CDC surveillance summaries, MMWR 2002;51 (SS-04).
Cowan CD. (2001). Coverage, Sample Design, and Weighting in Three Federal Surveys. Journal of Drug Issues.
For More Information: See the Division of Adolescent and School Health Web site at www.cdc.gov/nccdphp/dash/.

## Private and Global Sources

### Alan Guttmacher Institute Abortion Provider Survey

The Alan Guttmacher Institute, a not-for-profit organization focused on reproductive health research, policy analysis, and public education, conducts periodic surveys of abortion providers to provide nationally representative statistics on abortion incidence.

Number of induced abortions; number, types, and locations of providers; and types of procedures performed are presented by State and region. Health, United States presents the total for each data year. Thirteen provider surveys have been conducted for selected data years 1973 to midyear 2001. Data were collected from clinics, physicians, and hospitals identified as potential providers of abortion services. Mailed questionnaires were sent to all potential providers, with two additional mailings and telephone follow-up for nonresponse. No surveys were conducted in 1983, 1986, 1989, 1990, 1993, 1994, 1997, or 1998. For 1999–2000, a version of the survey questionnaire was created for each of the three major categories of providers, modeled on the survey questionnaire used for AGI’s data collection in 1997. All surveys asked the number of induced abortions performed at the provider’s location. State health statistics agencies were contacted, requesting all available data reported by providers to each State health agency on the number of abortions performed in the survey year. For States that provided data to AGI, the health agency figures were used for providers who did not respond to the survey. Estimates of the number of abortions performed by some providers were ascertained from knowledgeable sources in the community.

Of the 2,442 potential providers surveyed for 1999–2000, 1,931 performed abortions between January 1999 and June 2001. Of abortions reported for data year 2000, 77 percent were reported by providers, 10 percent came from health department data, 11 percent were estimated by knowledgeable sources, and 2 percent were projections or other estimates.

The number of abortions estimated by AGI through the mid-to late-1980s was about 20 percent higher than the number reported to the Centers for Disease Control and Prevention (CDC). Between 1989 and 1997 the AGI estimates were about 12 percent higher than those reported by CDC.

Beginning in 1998, health departments of four States did not report abortion data to CDC. The four reporting areas (the largest of which is California) that did not report abortions to CDC in 1998 accounted for 18 percent of all abortions tallied by AGI’s 1995–96 survey. FDA approval of Mifepristone (medical abortion) in September of 2000 accounted for a small proportion (approx 6 percent) of abortions performed in nonhospital facilities during the first half of 2001.

#### Reference

Finer LB, Henshaw SK. (2003). Abortion incidence and services in the United States in 2000. Perspect Sex Reprod Health.
For More Information: See the AGI Web site at www.guttmacher.org. The Agency address is The Alan Guttmacher Institute, 120 Wall Street, New York, NY 10005.

### American Association of Colleges of Pharmacy

The American Association of Colleges of Pharmacy (AACP) compiles data on the Colleges of Pharmacy, including information on student enrollment and types of degrees conferred. Data are collected through an annual survey; the response rate is 100 percent.

For More Information: See Profile of Pharmacy Students. The American Association of Colleges of Pharmacy, 1426 Prince Street, Alexandria, VA; or the AACP Web site at www.aacp.org.

### American Association of Colleges of Podiatric Medicine

The American Association of Colleges of Podiatric Medicine (AACPM) compiles data on the Colleges of Podiatric Medicine, including information on the schools and enrollment. Data are collected annually through written questionnaires. The response rate is 100 percent.

For More Information: Write to The American Association of Colleges of Podiatric Medicine, 1350 Piccard Drive, Suite 322, Rockville, MD 20850–4307; or see the AACPM Web site at www.aacpm.org.

### American Dental Association

The Division of Educational Measurement of the American Dental Association (ADA) conducts annual surveys of predoctoral dental educational institutions. The questionnaire, mailed to all dental schools, collects information on student characteristics, financial management, and curricula.

For More Information: See the American Dental Association, 1999–2000 Survey of Predoctoral Dental Educational Institutions or the ADA Web site at www.ada.org.

### American Hospital Association Annual Survey of Hospitals

Data from the American Hospital Association (AHA) annual survey are based on questionnaires sent to all AHA-registered and nonregistered hospitals in the United States and its associated areas. U.S. Government hospitals located outside the United States are excluded. Overall, the average response rate over the past 5 years has been approximately 83 percent. For nonreporting hospitals and for the survey questionnaires of reporting hospitals on which some information was missing, estimates are made for all data except those on beds, bassinets, and facilities. Data for beds and bassinets of nonreporting hospitals are based on the most recent information available from those hospitals. Data for facilities and services are based only on reporting hospitals.

Estimates of other types of missing data are based on data reported the previous year, if available. When unavailable, estimates are based on data furnished by reporting hospitals similar in size, control, major service provided, length of stay, and geographic and demographic characteristics.

For More Information: Write to the AHA Annual Survey of Hospitals, Health Forum, LLC, an American Hospital Association Company, One North Franklin Street, Chicago, IL 60606; or see the AHA Web site at www.aha.org.

### American Medical Association Physician Masterfile

A masterfile of physicians has been maintained by the American Medical Association (AMA) since 1906. The Physician Masterfile contains data on almost every physician in the United States, both members and nonmembers of the AMA, and on those graduates of American medical schools temporarily practicing overseas. The file also includes graduates of international medical schools who are in the United States and who meet education standards for primary recognition as physicians.

A file is initiated on each individual upon entry into medical school or, in the case of international graduates, upon entry into the United States. Between 1965 and 1985 a mail questionnaire survey was conducted every 4 years to update the file information on professional activities, self-designated area of specialization, and present employment status. Since 1985 approximately one-third of all physicians are surveyed each year.

For More Information: See Division of Survey and Data Resources, American Medical Association, Physician Characteristics and Distribution in the U.S., 2002–2003 ed. Chicago, IL. 2002; or the AMA Web site at www.ama-assn.org.

### Association of American Medical Colleges

The Association of American Medical Colleges (AAMC) collects information on student enrollment in medical schools through the annual Liaison Committee on Medical Education questionnaire, the fall enrollment questionnaire, and the American Medical College Application Service (AMCAS) data system. Other data sources are the institutional profile system, the premedical students questionnaire, the minority student opportunities in medicine questionnaire, the faculty roster system, data from the Medical College Admission Test, and one-time surveys developed for special projects.

For More Information: See the Association of American Medical Colleges, Statistical Information Related to Medical Education, Washington, DC. 2001; or the AAMC Web site at www.aamc.org.

### Association of Schools and Colleges of Optometry

The Association of Schools and Colleges of Optometry (ASCO) compiles data on various aspects of optometric education including data on schools and enrollment. Questionnaires are sent annually to all schools and colleges of optometry. The response rate is 100 percent.

For More Information: Write to Annual Survey of Optometric Educational Institutions, Association of Schools and Colleges of Optometry, 6110 Executive Blvd., Suite 510, Rockville, MD 20852; or see the ASCO Web site at www.opted.org.

### Association of Schools of Public Health

The Association of Schools of Public Health (ASPH) compiles data on schools of public health in the United States and Puerto Rico. Questionnaires are sent annually to all member schools. The response rate is 100 percent.

Unlike health professional schools that emphasize specific clinical occupations, schools of public health offer study in specialty areas such as biostatistics, epidemiology, environmental health, occupational health, health administration, health planning, nutrition, maternal and child health, social and behavioral sciences, and other population-based sciences.

For More Information: Write to Association of Schools of Public Health, 1101 15th Street, NW, Suite 910, Washington, DC 20005; or see the ASPH Web site at www.asph.org.

### European Health for All Database

#### World Health Organization Regional Office for Europe

The WHO Regional Office for Europe (WHO/Europe) provides country-specific and topic-specific health information via the Internet for people who influence health policy in the WHO European Region and the media.

WHO/Europe collects statistics on health and makes them widely available through

- The European health for all database (HFA-DB), which contains data on about 600 health indicators collected from national counterparts in 51 European countries, and data from other WHO technical programs and some international organizations.
- Highlights on health in countries in the WHO European Region that give an overview of the health situation in each country in comparison with other countries. Highlights complement the public health reports produced by a number of member States in the region.
- Health status overview for countries of central and eastern Europe that are candidates for accession to the European Union (Bulgaria, the Czech Republic, Estonia, Hungary, Latvia, Lithuania, Poland, Romania, Slovakia, and Slovenia).

WHO/Europe helps countries strengthen their national health information systems, particularly by supporting

- the development of national health indicator databases
- the exchange of experience on national public health reports between countries; a database of public health reports is maintained and available for consultation and networking
- implementation of international classifications and definitions in countries
- regional networks of health information professionals

For More Information: See the European health for all database at http://hfadb.who.dk/hfa/.

### InterStudy National Health Maintenance Organization Census

From 1976 to 1980 the Office of Health Maintenance Organizations conducted a census of health maintenance organizations (HMOs). Since 1981 InterStudy has conducted the census. A questionnaire is sent to all HMOs in the United States asking for updated enrollment, profit status, and Federal qualification status. New HMOs are also asked to provide information on model type. When necessary, information is obtained, supplemented, or clarified by telephone. For nonresponding HMOs State-supplied information or the most current available data are used.

In 1985 a large increase in the number of HMOs and enrollment was partly attributable to a change in the categories of HMOs included in the census: Medicaid-only and Medicare-only HMOs have been added. Component HMOs, which have their own discrete management, can be listed separately, whereas previously the oldest HMO reported for all of its component or expansion sites, even when the components had different operational dates or were different model types.

For More Information: See The InterStudy Competitive Edge. InterStudy Publications, St. Paul, MN. 2002; or the InterStudy Web site at www.hmodata.com.

### National League for Nursing

The division of research of the National League for Nursing (NLN) conducts The Annual Survey of Schools of Nursing in October of each year. Questionnaires are sent to all graduate nursing programs (master’s and doctoral), baccalaureate programs designed exclusively for registered nurses, basic registered nursing programs (baccalaureate, associate degree, and diploma), and licensed practical nursing programs. Data on enrollments, first-time admissions, and graduates are completed for all nursing education programs. Response rates of approximately 80 percent are achieved for other areas of inquiry.

For More Information: See the National League for Nursing, Nursing Data Review 1997, New York, NY. 1997; or the NLN Web site at www.nln.org.

### Organization for Economic Cooperation and Development Health Data

The Organization for Economic Cooperation and Development (OECD) provides annual data on statistical indicators on health and economic policies collected from 30 member countries since the 1960s. The international comparability of health expenditure estimates depends on the quality of national health accounts in OECD member countries. In recent years the OECD health accounts have become an informal standard for reporting on health care systems. Additional limitations in international comparisons include differing boundaries between health care and other social care, particularly for the disabled and elderly, and underestimation of private expenditures on health.

The OECD was established in 1961 with a mandate to promote policies to achieve the highest sustainable economic growth and a rising standard of living among member countries. The Organization now comprises 30 member countries: Australia, Austria, Belgium, Canada, Czech Republic, Denmark, Finland, France, Germany, Greece, Hungary, Iceland, Ireland, Italy, Japan, Korea, Luxembourg, Mexico, Netherlands, New Zealand, Norway, Poland, Portugal, Slovak Republic, Spain, Sweden, Switzerland, Turkey, the United Kingdom, and the United States.

As part of its mission, the OECD has developed a number of activities in relation to health and health care systems. The main aim of OECD work on health policy is to conduct cross-national studies of the performance of OECD health systems and to facilitate exchanges between member countries of their experiences of financing, delivering, and managing health services. To support this work, each year the OECD compiles cross-country data in OECD Health Data, one of the most comprehensive sources of comparable health-related statistics. OECD Health Data is an essential tool to carry out comparative analyses and draw lessons from international comparisons of diverse health care systems. This international database now incorporates the first results arising from the implementation of the OECD manual, A System of Health Accounts (2000), which provide a standard framework for producing a set of comprehensive, consistent, and internationally comparable data on health spending. The OECD collaborates with other international organizations such as the WHO.

For More Information: See the OECD Web site at www.oecd.org/health.

### United Nations Demographic Yearbook

The Statistical Office of the United Nations prepares the Demographic Yearbook, a comprehensive collection of international demographic statistics.

Questionnaires are sent annually and monthly to more than 220 national statistical services and other appropriate government offices. Data forwarded on these questionnaires are supplemented, to the extent possible, by data taken from official national publications and by correspondence with the national statistical services. To ensure comparability, rates, ratios, and percents have been calculated in the statistical office of the United Nations.

Lack of international comparability among estimates arises from differences in concepts, definitions, and time of data collection. The comparability of population data is affected by several factors, including (a) definitions of the total population, (b) definitions used to classify the population into its urban and rural components, (c) difficulties relating to age reporting, (d) extent of over- or underenumeration, and (e) quality of population estimates. The completeness and accuracy of vital statistics data also vary from one country to another. Differences in statistical definitions of vital events may also influence comparability.

International demographic trend data are available on a CD-ROM entitled United Nations, 2000. Demographic Yearbook—Historical Supplement 1948–97. CD-ROM Special Issue. United Nations publication sales number E/F.99.XIII.12.

For More Information: See the United Nations, Demographic Yearbook 2000, United Nations, New York, 2002; or the United Nations Web site at www.un.org or their Web site locator at www.unsystem.org.

### World Health Statistics Annual

#### World Health Organization

The World Health Organization (WHO) prepares the World Health Statistics Annual, an annual volume of information on vital statistics and causes of death designed for use by the medical and public health professions. Each volume is the result of a joint effort by the national health and statistical administrations of many countries, the United Nations, and WHO. United Nations estimates of vital rates and population size and composition, where available, are reprinted directly in the Statistics Annual. For those countries for which the United Nations does not prepare demographic estimates, primarily smaller populations, the latest available data reported to the United Nations and based on reasonably complete coverage of events are used.

Information published on infant mortality is based entirely on official national data either reported directly or made available to WHO.

Selected life table functions are calculated from the application of a uniform methodology to national mortality data provided to WHO, to enhance their value for international comparisons. The life table procedure used by WHO may often lead to discrepancies with national figures published by countries, because of differences in methodology or degree of age detail maintained in calculations.

The international comparability of estimates published in the World Health Statistics Annual is affected by the same problems as is the United Nations Demographic Yearbook. Cross-national differences in statistical definitions of vital events, in the completeness and accuracy of vital statistics data, and in the comparability of population data are the primary factors affecting comparability.

For More Information: See the World Health Organization, World Health Statistics Annual 2000, World Health Organization, Geneva, 2002; World Health Statistics 1997–99 at www.who.int/whosis; or the WHO Web site at www.who.int.