# Acknowledgments

Overall responsibility for planning and coordinating the content of this volume rested with the Office of Analysis and Epidemiology, National Center for Health Statistics (NCHS), under the direction of Amy B. Bernstein and Diane M. Makuc.

Production of Health, United States, 2004 highlights, trend tables, and appendixes was managed by Kate Prager. Trend tables were prepared by Amy B. Bernstein, Alan J. Cohen, Margaret A. Cooke, La-Tonya D. Curl, Catherine R. Duran, Sheila Franco, Virginia M. Freid, Ji-Eun Lee, Andrea P. MacKay, Mitchell B. Pierre, Jr., Rebecca A. Placek, Kate Prager, Laura A. Pratt, and Henry Xia, with assistance from Stephanie Gray. Appendix II tables and the index were assembled by Anita L. Powell. Production planning and coordination of trend tables were managed by Rebecca A. Placek. Administrative and word processing assistance were provided by Carole J. Hunt, Lillie C. Featherstone, and Brenda L. Wolfrey.

Production of the Chartbook on Trends in the Health of Americans was managed by Virginia M. Freid. Production of the Special Feature on Drugs was managed by Amy B. Bernstein. Data and analysis for specific charts were provided by Margaret A. Cooke, Sheila Franco, Qiuping Gu, Deborah D. Ingram, Ellen A. Kramarow, Andrea P. MacKay, Patricia N. Pastor, Ryne Paulose, and Kate Prager. Graphs were drafted by La-Tonya D. Curl and data tables were prepared by Rebecca A. Placek. Technical assistance and programming were provided by Lara Akinbami, Liming Cai, Alan J. Cohen, Catherine R. Duran, Ji-Eun Lee, Mitchell B. Pierre, Jr., and Henry Xia and by Gregory Spencer of the U.S. Census Bureau.

Technical assistance and review of the Special Feature on Drugs and National Drug Code Therapeutic Class recodes were provided by Michael C. Evans, Gianna C. Rigoni, Judy A. Staffa, and Anne E. Trontell of the Food and Drug Administration, Center for Drug Evaluation and Research.

Publications management and editorial review were provided by Thelma W. Sanders. Oversight review for publications and electronic products were provided by Linda L. Bean. The designer was Sarah Hinkle. Production was done by Jacqueline M. Davis and Zung T. Le. Printing was managed by Patricia L. Wilson and Joan D. Burton, Office of Information Servces.

Electronic access through the NCHS Internet site and CD-ROM were provided by Christine J. Brown, Jacqueline M. Davis, Dorothy Day, Zung T. Le, Sharon L. Ramirez, Thelma W. Sanders, and Patricia L. Wilson.

Data and technical assistance were provided by staff of the following NCHS organizations: Division of Health Care Statistics: Irma E. Arispe, Catharine W. Burt, Donald K. Cherry, Marni J. Hall, Lola Jean Kozak, Karen L. Lipkind, Linda F. McCaig, Robert Pokras, Robin E. Remsburg, Susan M. Schappert, Judith Shinogle, and Genevieve W. Strahan; Division of Health Examination Statistics: Lisa Broitman, Vicki Burt, Margaret D. Carroll, Lester R. Curtin, Bruce Dye, Jeffrey Hughes, Clifford L. Johnson, Cynthia Ogden, and Ryne Paulose; Division of Health Interview Statistics: Patricia F. Adams, Veronica E. Benson, Barbara Bloom, Viona I. Brown, Margaret L. Cejku, Pei-Lu Chiu, Robin A. Cohen, Richard H. Coles, Marcie Cynamon, Cathy C. Hao, Kristina Kotulak-Hays, Susan S. Jack, Jane B. Page, John R. Pleis, Eve Powell-Griner, Charlotte A. Schoenborn, Mira L. Shanks, Anne K. Stratton, and Luong Tonthat; Division of Vital Statistics: Robert N. Anderson, Elizabeth Arias, Thomas D. Dunn, Brady E. Hamilton, Kenneth D. Kochanek, Marian F. MacDorman, Joyce A. Martin, T.J. Mathews, Arialdi M. Minino, William D. Mosher, Sherry L. Murphy, Gail A. Parr, Manju Sharma, Stephanie J. Ventura, and Jim Weed; Office of Analysis and Epidemiology: Mark L. Eberhardt, Lois A. Fingerhut, Deborah D. Ingram, Elizabeth W. Jackson, Richard J. Klein, Patricia A. Knapp, Suzanne Proctor, Erin Reidy, and Thomas C. Socey; and Office of International Statistics: Juan Rafael Albertorio-Diaz and Francis C. Notzon.

Additional data and technical assistance were also provided by the following organizations of the Centers for Disease Control and Prevention: Epidemiology Program Office: Samuel L. Groseclose and Patsy A. Hall; National Center for Chronic Disease Prevention and Health Promotion: Joy Herndon, Sherry Everett Jones, Laura K. Kann, Steve Kinchen, Shari L. Shanklin, and Lilo T. Strauss; National Center for HIV, STD, and TB Prevention: Melinda Flock, Allyn Nakashima, and Luetta Schneider; National Immunization Program: Lawrence Barker and Emmanuel Maurice; by the following organizations within the Department of Health and Human Services: Agency for Health Care Research and Quality: David Kashihara and Steven Machlin; Centers for Medicare & Medicaid Services: Cathy A. Cowan, Frank Eppig, Denise F. Franz, David A. Gibson, Deborah W. Kidd, Helen C. Lazenby, Katharine R. Levit, Anna Long, Joanne S. Mack, Anne B. Martin, and Carter S. Warfield; Health Resources and Services Administration: Evelyn Christian; National Institutes of Health: James D. Colliver, Catherine C. Cowie, and Lynn A. G. Ries; Office of the Secretary, DHHS: Mitchell Goldstein; Substance Abuse and Mental Health Services Administration: Joanne Atay, Judy K. Ball, Joseph C. Gfroerer, Ronald Manderscheid, and Deborah Trunzo; and by the following governmental and nongovernmental organizations: Bureau of the Census: Joseph Dalaker and Bernadette D. Proctor; Bureau of Labor Statistics: Alan Blostin, Kay Ford, Daniel Ginsburg, Elizabeth Rogers, John Stinson, and Peggy Suarez; Department of Veterans Affairs: Michael F. Grindstaff; Alan Guttmacher Institute: Rebecca Wind; American Association of Colleges of Podiatric Medicine: Carol E. Gill; Association of Schools of Public Health: Mah-Sere K. Sow;Cowles Research Group: C. McKeen Cowles; InterStudy: Richard Hamer; and National League for Nursing: Linbania Jacobson and Kathy A. Kaufman.