# Preface

Health, United States, 2004 is the 28th report on the health status of the Nation and is submitted by the Secretary of the Department of Health and Human Services to the President and Congress of the United States in compliance with Section 308 of the Public Health Service Act. This report was compiled by the National Center for Health Statistics (NCHS), Centers for Disease Control and Prevention (CDC). The National Committee on Vital and Health Statistics served in a review capacity.

The Health, United States series presents national trends in health statistics. Each report includes highlights, a chartbook, trend tables, extensive appendixes, and an index. An Executive Summary presents major findings.

## Chartbook

The third Chartbook on Trends in the Health of Americans updates and expands information from last year’s chartbook. In addition to assessing the Nation’s health by presenting trends and current information on selected determinants and measures of health status, the 2004 chartbook includes a feature on drugs, which documents changes that have occurred in drug practice and utilization patterns. Among the drugs presented in the special feature are asthma drugs, antidepressant drugs, cholesterol-lowering drugs, and nonsteroidal anti-inflammatory drugs. Other changes include the addition of information on frequency of cigarette smoking by high school students, conditions causing activity limitation among children, and leading causes of death for the total population. Determinants of health considered in the chartbook include demographic factors, health insurance coverage, health behaviors and risk factors, and preventive health care. Measures of health status include mortality and limitations of activity resulting from chronic health conditions. Many measures are shown separately for persons of different ages because of the strong effect of age on health. Selected figures also highlight differences in determinants and measures of health status by such characteristics as sex, race, and Hispanic origin.

## Trend Tables

The chartbook section is followed by 153 trend tables organized around four major subject areas: health status and determinants, health care utilization, health care resources, and health care expenditures. A major criterion used in selecting the trend tables is availability of comparable national data over a period of several years. The tables present data for selected years to highlight major trends in health statistics. Earlier editions of Health, United States may present data for additional years that are not included in the current printed report. Where possible, these additional years of data are available in Excel spreadsheet files on the Health, United States Web site. Tables with additional data years are listed in Appendix III.

## Racial and Ethnic Data

Many tables in Health, United States present data according to race and Hispanic origin consistent with Department-wide emphasis on expanding racial and ethnic detail when presenting health data. Trend data on race and ethnicity are presented in the greatest detail possible after taking into account the quality of data, the amount of missing data, and the number of observations. New standards for Federal data on race and ethnicity are described in Appendix II under Race.

## Changes in This Edition

Each volume of Health, United States is prepared to maximize its usefulness as a standard reference source while maintaining its continuing relevance. Comparability is fostered by including similar trend tables in each volume. Timeliness is maintained by adding new tables each year to reflect emerging topics in public health and improving the content of ongoing tables. New to Health, United States, 2004 is a table on prevalence of diabetes (table 55) based on the National Health and Nutrition Examination Survey (NHANES), a table on serious psychological distress (table 58) based on the National Health Interview Survey, two tables on drug use—one on use of prescription drugs in the past month (table 86) based on NHANES data and one on drugs recorded during visits to office-based physicians and hospital outpatient departments (table 87) based on the National Ambulatory Medical Care Survey and the National Hospital Ambulatory Medical Care Survey Hospital Outpatient Department component, and a table on the supply of Medicare-certified providers and suppliers (table 114) based on data from the Centers for Medicare & Medicaid Services. Table 97 was revised to better reflect recent changes in types of procedures performed on hospital inpatients, based on the National Hospital Discharge Survey.

In another change, unrounded resident population estimates for 10-year age groups by sex, race, and Hispanic origin are now available in the spreadsheet version of table 1 and can be accessed through the Health, United States Web site described below under Electronic Access. Previously, population estimates were presented rounded in thousands.

## Appendixes

Appendix I describes each data source used in the report and provides references for further information about the sources. Appendix I has been reformatted to present more standard information on each data source. Data sources are listed alphabetically within two broad categories: Government Sources and Private and Global Sources.

Appendix II is an alphabetical listing of terms used in the report. It also presents standard populations used for age adjustment (tables I, II, and III); ICD codes for causes of death shown in Health, United States from the Sixth through Tenth Revisions and the years when the Revisions were in effect (tables IV and V); comparability ratios between ICD–9 and ICD–10 for selected causes (table VI); ICD–9–CM codes for external cause-of-injury, diagnostic, and procedure categories (tables VII, IX, and X); industry codes from the Standard Industrial Classification Manual (table VIII); National Drug Code (NDC) Therapeutic Class recodes of generic analgesic drugs (table XI); and sample tabulations of NHIS data comparing the 1977 and 1997 Standards for Federal data on race and Hispanic origin (tables XII and XIII).

Appendix III lists tables for which additional years of trend data are available electronically in Excel spreadsheet files on the Health, United States Web site and CD-ROM, described below under Electronic Access.

## Index

The Index to Trend Tables is a useful tool for locating data by topic. Tables are cross-referenced by such topics as Child and adolescent health; Women’s health; Men’s health; State data; American Indian, Asian, Black, and Hispanic origin populations; Education; Poverty status; Disability; and Metropolitan/nonmetropolitan data.

## Electronic Access

Health, United States may be accessed on the World Wide Web at www.cdc.gov/nchs/hus.htm. From the Health, United States Web site, one may also register for the Health, United States electronic mailing list to receive announcements about release dates and notices of updates to tables.

Health, United States, 2004, the chartbook, and each of the 153 individual trend tables are available as separate Acrobat .pdf files on the Web. Individual tables are downloadable as Excel spreadsheet files. Both .pdf and spreadsheet files for selected tables will be updated on the Web if more current data become available near the time when the printed report is released. Readers who register for the electronic mailing list will be notified of these table updates. Previous editions of Health, United States and chartbooks, starting with the 1993 edition, also may be accessed from the Health, United States Web site.

Health, United States is also available on CD-ROM, where it can be viewed, searched, printed, and saved using Adobe Acrobat software on the CD-ROM.

## Copies of the Report

Copies of Health, United States, 2004 and the CD-ROM may be purchased from the Government Printing Office through links to GPO on the National Center for Health Statistics Web site, Printed Publications page.

## Questions?

For answers to questions about this report, contact:

Information Dissemination Staff National Center for Health Statistics Centers for Disease Control and Prevention 3311 Toledo Road, Fifth Floor Hyattsville, Maryland 20782 Phone: 1–866-441-NCHS E-mail: nchsquery@cdc.gov Internet: www.cdc.gov/nchs