# Statistical Brief #91 Diagnostic Groups with Rapidly Increasing Costs, by Payer, 2001–2007

## Introduction

Inpatient care comprises the largest portion of health care spending in the United States.^1^ As health care costs continue to rise and the population ages, policy makers are increasingly concerned about the growing burden of hospital-based medical care expenses on the government, tax payers, consumers, and employers. Identifying the conditions that generate the most rapid increases in hospital costs can inform the discussion of medical care costs.

This Statistical Brief presents data from the Healthcare Cost and Utilization Project (HCUP) and identifies which ten conditions generated the most rapidly increasing hospital costs between 2001 and 2007. Hospital costs tend to reflect the actual costs of production (excluding physician expenses). Information is presented for four payer groups: Medicare, Medicaid, private insurance, and self-pay (uninsured). All differences between estimates provided in the text are statistically significant at the 0.05 level or better. Costs for 2001 were adjusted to 2007 dollars using the overall Consumer Price Index (CPI).

## Findings

Highlights

- From 2001 to 2007, inflation-adjusted hospital costs grew by 24.6 percent to $343 billion. There was a 17.2 percent rise in mean costs per stay and a 6.3 percent increase in the number of hospital discharges; however, not all payers experienced these increases equally.
- Although discharges incurred for private insurance demonstrated the largest increase in mean cost per stay (20.8 percent), there was a decline in the number of stays incurred for private insurance (2.9 percent). In contrast, while the average cost per hospitalization incurred for Medicaid and the uninsured grew more slowly (about 14 percent), it was coupled with dramatic growth in the number of total hospital stays (20.1 and 29.9 percent, respectively).
- Among the ten conditions with the most rapidly increasing hospital inpatient costs, blood infection demonstrated the largest growth in aggregate costs (174.1 percent) and the highest aggregate cost ($12.3 billion in 2007).
- For seven of the top ten conditions with rapidly growing costs, the growth in aggregate costs for stays incurred for uninsured more than doubled from 2001 to 2007 (105.6 to 228.1 percent increase).
- Degenerative joint disease was the most expensive condition among the top growers incurred for private insurance in 2007 ($4.6 billion); total hospitalization costs for this condition more than doubled from 2001 to 2007.

During the seven-year period from 2001 to 2007, inflation-adjusted hospital costs grew by 24.6 percent to $343 billion (table 1). From 2001 to 2007, there was a 17.2 percent rise in mean costs per stay and a 6.3 percent increase in the number of hospital discharges. Increases varied by payer and stemmed from changes in inpatient costs and hospitalization rates. For example, although discharges incurred for private insurance demonstrated the largest increase in mean cost per stay (20.8 percent), there was a decline in the number of stays incurred for private insurance (2.9 percent). In contrast, the average cost per hospitalization incurred for Medicaid and the uninsured grew relatively slowly (about 14 percent), but it was coupled with dramatic growth in the number of total hospital stays (20.1 and 29.9 percent, respectively).

Table 1 Change in hospital stays and costs by payer, 2001–2007

Primary Expected Payer | Total costs (2007) | Mean cost per stay (2007) | Total hospital stays (2007) | Percentage change in:
Primary Expected Payer | Total costs (2007) | Mean cost per stay (2007) | Total hospital stays (2007) | Total costs (2001–2007)^*^ | Mean cost per stay (2001–2007) | Total hospital stays (2001–2007)
Medicare | $155,863,779,000 | $10,838 | 14,381,700 | 22.5 | 16.9 | 4.8
Medicaid | $50,415,753,000 | $6,579 | 7,663,000 | 37.1 | 14.1 | 20.1
Private insurance | $107,484,034,000 | $7,834 | 13,719,700 | 17.3 | 20.8 | −2.9
Uninsured | $16,481,474,000 | $7,134 | 2,310,200 | 48.5 | 14.3 | 29.9
Total (All Payers) | $343,313,877,000 | $8,682 | 39,542,000 | 24.6% | 17.2% | 6.3%

* 2001 costs were adjusted to 2007 dollars using the overall Consumer Price Index.

There are an additional 1.4 million discharges with “other” as the primary expected payer. “Other” payer includes Workers’ Compensation, TRICARE, CHAMPUS, CHAMPVA, Title V, and other government programs.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2001 and 2007

### Hospital stays for common conditions with the most rapidly increasing hospital inpatient costs

The top ten principal conditions that generated the most rapid increases in total hospital costs from 2001 to 2007 are shown in table 2. The aggregate costs of stays for these ten conditions ($48.6 billion) accounted for 14.2 percent of the costs of all hospitalizations in 2007. Of note, several chronic conditions with high aggregate costs and frequent hospitalization—including heart disease, cancer, stroke, and diabetes,—were not among the top 10 conditions with the most increases in total aggregate costs.

Table 2 Common conditions with the most rapidly increasing hospital inpatient costs, 2001–2007

Principal CCS Diagnosis | Total costs (2007) | Total hospital stays (2007) | Percentage change in:
Principal CCS Diagnosis | Total costs (2007) | Total hospital stays (2007) | Total costs (2001–2007)^*^ | Total hospital stays (2001–2007)
Blood infection (septicemia) | $12,336,477,000 | 675,400 | 174.1 | 97.1
Intestinal infection | $1,657,390,000 | 235,900 | 148.7 | 69.5
Acute kidney failure | $4,022,154,000 | 400,000 | 148.3 | 177.6
Diseases of white blood cells | $791,691,000 | 67,400 | 95.6 | 40.2
Respiratory insufficiency, arrest, failure | $7,778,034,000 | 385,800 | 90.1 | 93.1
Degenerative joint disease (osteoarthritis) | $11,800,160,000 | 814,900 | 85.0 | 62.5
Previous C-section | $2,405,022,000 | 561,700 | 73.3 | 56.6
Poisoning by other medications and drugs | $820,034,000 | 138,600 | 67.4 | 22.0
Skin and subcutaneous tissue infections | $3,643,917,000 | 604,100 | 65.5 | 54.5
Brain injury | $3,345,606,000 | 189,800 | 64.9 | 35.6
Total for top 10 conditions * | $48,600,484,000 | 4,073,700 | 104.5% | 71.2%

* 2001 costs were adjusted to 2007 dollars using the overall Consumer Price Index.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2001 and 2007

The overall aggregate costs for the ten conditions grew by 104.5 percent between 2001 and 2007. Among the ten conditions with the most rapidly increasing hospital inpatient costs, blood infection demonstrated the largest growth in aggregate costs (174.1 percent) and the highest aggregate cost ($12.3 billion in 2007). From 2001 to 2007, the number of stays with a principal diagnosis of blood infection nearly doubled (97.1 percent; 675,400 stays in 2007). Total costs for hospitalizations due to intestinal infection and acute kidney failure increased similarly (148 percent), but the number of stays for these two conditions differed; stays for intestinal infection grew by 69.5 percent and those for acute kidney failure grew 177.6 percent.

Among the ten conditions with the most rapidly increasing hospital costs, degenerative joint disease (osteoarthritis) accounted for the greatest number of stays (814,900) and the second highest aggregate costs ($11.8 billion) in 2007.

### Hospital stays for conditions with the most rapidly increasing hospital inpatient costs, by payer

Table 3 presents the 2001 to 2007 growth in number of stays and total costs for the top ten conditions by payer.

Table 3 Common conditions with the most rapidly increasing hospital inpatient costs, by expected primary payer, 2001–2007

Principal CCS Diagnosis | Medicare-covered stays | | | Medicaid-covered stays | | | Privately insured stays | | | Uninsured stays
Principal CCS Diagnosis | Total costs (2007) | Percentage change in: | | Total costs (2007) | Percentage change in: | | Total costs (2007) | Percentage change in: | | Total costs (2007) | Percentage change in:
Principal CCS Diagnosis | Total costs (2007) | Total costs (2001–2007)^*^ | Total hospital stays (2001–2007) | Total costs (2007) | Total costs (2001–2007)^*^ | Total hospital stays (2001–2007) | Total costs (2007) | Total costs (2001–2007)^*^ | Total hospital stays (2001–2007) | Total costs (2007) | Total costs (2001–2007)^*^ | Total hospital stays (2001–2007)
Blood infection (septicemia) | $8,042,095,000 (65.2%) | 172.4 | 97.4 | $1,495,334,000 (12.1%) | 192.4 | 96.7 | $2,126,870,000 (17.2%) | 152.5 | 83.3 | $369,400,000 (3.0%) | 228.1 | 161.3
Intestinal infection | $1,005,133,000 (60.6%) | 204.7 | 142.2 | $167,021,000 (10.1%) | 103.2 | 38.8 | $391,223,000 (23.6%) | 79.5 | 21.6 | $57,941,000 (3.5%) | 138.0 | 66.5
Acute kidney failure | $2,728,034,000 (67.8%) | 153.6 | 180.9 | $385,473,000 (9.6%) | 160.4 | 176.1 | $685,966,000 (17.1%) | 118.7 | 153.9 | $133,361,000 (3.3%) | 179.2 | 229.9
Diseases of white blood cells | $259,810,000 (32.8%) | 84.1 | 37.9 | $114,596,000 (14.5%) | 127.2 | 64.9 | $369,589,000 (46.7%) | 90.2 | 31.3 | $19,811,000 (2.5%) | 126.2 | 75.4
Respiratory insufficiency, arrest, failure | $4,868,177,000 (62.6%) | 92.4 | 93.5 | $1,051,069,000 (13.5%) | 93.0 | 97.7 | $1,374,290,000 (17.7%) | 66.9 | 72.1 | $259,078,000 (3.3%) | 154.1 | 178.2
Degenerative joint disease (osteoarthritis) | $6,502,722,000 (55.1%) | 67.5 | 47.7 | $283,110,000 (2.4%) | 66.8 | 43.8 | $4,582,120,000 (38.8%) | 120.3 | 92.7 | $69,848,000 (0.6%) | 75.5 | 68.7
Previous C-section | $22,395,000 (0.9%) | 260.4^†^ | 296.0^†^ | $996,215,000 (41.4%) | 95.1 | 79.2 | $1,233,469,000 (51.3%) | 55.7 | 38.2 | $93,742,000 (3.9%) | 124.5 | 109.2
Poisoning by other medications and drugs | $224,816,000 (27.4%) | 89.4 | 43.4 | $180,754,000 (22.0%) | 66.8 | 17.8 | $222,264,000 (27.1%) | 37.8 | −0.3 | $146,388,000 (17.9%) | 79.7 | 38.7
Skin and subcutaneous tissue infections | $1,498,116,000 (41.1%) | 49.5 | 32.3 | $589,969,000 (16.2%) | 81.3 | 86.5 | $971,188,000 (26.7%) | 61.1 | 46.7 | $389,118,000 (10.7%) | 105.6 | 108.6
Brain injury | $945,035,000 (28.2%) | 97.5 | 67.7 | $538,541,000 (16.1%) | 88.2 | 37.3 | $1,207,564,000 (36.1%) | 40.4 | 11.1 | $357,746,000 (10.7%) | 35.0 | 30.2

* 2001 costs were adjusted to 2007 dollars using the overall Consumer Price Index.

† Stays with a principal diagnosis of previous C-section remained few in number (1,400 in 2001 and 5,500 in 2007) and had the lowest total costs ($22.4 million in 2007).

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2001 and 2007

Across all payers, total aggregate costs more than doubled for stays due to blood infection and acute kidney failure. Total costs for stays due to intestinal infection also experienced rapid growth, particularly for Medicare-covered patients (204.7 percent). The number of stays for intestinal infection incurred for Medicare grew dramatically (142.2 percent) compared to growth in the number of uninsured, Medicaid-covered, or privately insured stays for intestinal infection. Degenerative joint disease was the most expensive condition incurred for private insurance ($4.6 billion) with a 120.3 percent increase in total costs for this condition from 2001 to 2007.

For seven of the top ten conditions, the growth in aggregate costs for stays incurred for uninsured more than doubled from 2001 to 2007 (range: 105.6 to 228.1 percent increase). The total costs for uninsured stays with a principal diagnosis of kidney failure increased 179.2 percent to $133.3 million in 2007. Relative to other payers, uninsured stays accounted for the smallest proportion of total aggregate costs for each of the top ten conditions. For four of the top ten conditions—blood infection, acute kidney failure, respiratory insufficiency, arrest, or failure, and skin and subcutaneous skin infections—the uninsured demonstrated greater increases in growth in total costs and number of hospital stays than the other three payer groups.

Payer differences in demographic mix and service coverage are evident for several of the top ten conditions with the most rapidly increasing hospital costs. For example, more than half of the total costs for five of the top ten conditions with the most rapidly increasing hospital costs was for Medicare patients: acute kidney failure (67.8 percent), blood infection (65.2 percent), respiratory insufficiency, arrest, or failure (62.6 percent), intestinal infection (60.6 percent), and degenerative joint disease (55.1 percent). Degenerative joint disease, which typically becomes more common and debilitating with age, generated the second highest amount of cost for Medicare ($6.5 billion) in 2007.

Private insurance was the primary expected payer for approximately half of all stays with a principal diagnosis of previous C-section (51.3 percent) and demonstrated a 55.7 percent growth in total costs for this diagnosis from 2001 to 2007. Medicaid was the primary expected payer for 41.4 percent of previous C-section stays and demonstrated a 95.1 percent growth in total costs for this diagnosis.

Figure 1 shows the percentage contribution to growth in total costs for conditions with the most rapidly increasing hospital inpatient costs from 2001 to 2007 by payer. Growth in costs incurred for Medicare contributed to more than half (55 percent) of the $24.8 billion increase in total costs for the top ten conditions across all payers. Figure 2 shows that the growth in stays incurred for Medicare accounted for about half of the combined growth in total stays for these conditions with rapidly growing costs (1.7 million stays).

Figure 1 Percentage contribution to change in total costs for conditions with the most rapidly increasing hospital inpatient costs, by payer, 2001–2007

Dollar amounts in parentheses represent the inflation-adjusted increase in total costs from 2001 to 2007. Percentages less than 5 percent are not labeled. “Other” payer includes Workers’ Compensation, TRICARE, CHAMPUS, CHAMPVA, Title V, and other government programs.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2001–2007

Top 10 conditions ($24.8 billion), Medicare 55%; Medicaid, 12%; Private Insurance, 25%; Uninsured, NA%; Other, NA% Blood infection ($7.8 billion), Medicare 65%; Medicaid, 13%; Private Insurance, 16%; Uninsured, NA%; Other, NA% Intestinal infection ($990 million), Medicare 68%; Medicaid, 9%; Private Insurance, 17%; Uninsured, NA%; Other, NA% Acute kidney failure ($2.4 billion), Medicare 69%; Medicaid, 10%; Private Insurance, 16%; Uninsured, NA%; Other, NA% Diseases of white blood cells ($387 billion), Medicare 31%; Medicaid, 17%; Private Insurance, 45%; Uninsured, NA%; Other, 5% Respiratory insufficiency, arrest, failure ($3.7 billion), Medicare 63%; Medicaid, 14%; Private Insurance, 15%; Uninsured, NA%; Other, NA% Degenerative joint disease ($5.4 billion), Medicare 48%; Medicaid, NA%; Private Insurance, 46%; Uninsured, NA%; Other, NA% Previous C-section ($1.0 billion), Medicare NA%; Medicaid, 48%; Private Insurance, 43%; Uninsured, 5%; Other, NA% Poisoning by other medications and drugs ($330 million), Medicare 32%; Medicaid, 22%; Private Insurance, 18%; Uninsured, 20%; Other, 8% Skin and subcutaneous tissue infections ($1.4 billion), Medicare 34%; Medicaid, 18%; Private Insurance, 26%; Uninsured, 14%; Other, 8% Brain injury ($1.3 billion), Medicare 35%; Medicaid, 19%; Private Insurance, 26%; Uninsured, 7%; Other, 12% Dollar amounts in parentheses represent the inflation-adjusted increase in total costs from 2001 to 2007. Percentages less than 5 percent are not labeled. “Other” payer includes Workers’ Compensation, TRICARE, CHAMPUS, CHAMPVA, Title V, and other government programs.

Figure 2 Percentage contribution to growth in inpatient stays for conditions with the most rapidly increasing hospital inpatient costs, by payer, 2001–2007

Number of stays in parentheses represent the increase in total stays from 2001 to 2007. Percentages less than 5 percent are not labeled. “Other” payer includes Workers’ Compensation, TRICARE, CHAMPUS, CHAMPVA, Title V, and other government programs.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2001–2007

Top 10 conditions (1.7 million stays), Medicare 50%; Medicaid, 15%; Private Insurance, 26%; Uninsured, NA%; Other, NA% Blood infection (332,800 stays), Medicare 69%; Medicaid, 9%; Private Insurance, 15%; Uninsured, NA%; Other, NA% Intestinal infection (96,700 stays), Medicare 70%; Medicaid, 9%; Private Insurance, 13%; Uninsured, NA%; Other, NA% Acute kidney failure (255,900 stays), Medicare 70%; Medicaid, 8%; Private Insurance, 16%; Uninsured, NA%; Other, NA% Diseases of white blood cells (19,300 stays), Medicare 33%; Medicaid, 20%; Private Insurance, 37%; Uninsured, NA%; Other, 5% Respiratory insufficiency, arrest, failure (186,000 stays), Medicare 66%; Medicaid, 11%; Private Insurance, 15%; Uninsured, 5%; Other, NA% Degenerative joint disease (313,400 stays), Medicare 47%; Medicaid, NA%; Private Insurance, 48%; Uninsured, NA%; Other, NA% Previous C-section (202,900 stays), Medicare NA%; Medicaid, 51%; Private Insurance, 39%; Uninsured, 6%; Other, NA% Poisoning by other medications and drugs (25,000 stays), Medicare 40%; Medicaid, 18%; Private Insurance, 31%; Uninsured, 11%; Skin and subcutaneous tissue infections (213,000 stays), Medicare 24%; Medicaid, 22%; Private Insurance, 27%; Uninsured, 18%; Other, 8% Brain injury (50,000 stays), Medicare 53%; Medicaid, 11%; Private Insurance, 13%; Uninsured, 11%; Other, 11% Number of stays in parentheses represent the increase in total costs from 2001 to 2007. Percentages less than 5 percent are not labeled. “Other” payer includes Workers’ Compensation, TRICARE, CHAMPUS, CHAMPVA, Title V, and other government programs.

## Data Source

The estimates in this Statistical Brief are based upon data from the HCUP Nationwide Inpatient Sample (NIS), 2001 and 2007.

## Definitions

### Procedures and Clinical Classifications Software (CCS)

The principal procedure is the procedure that was performed for definitive treatment rather than one performed for diagnostic or exploratory purposes (i.e., the procedure that was necessary to take care of a complication). If two procedures appear to meet this definition, the procedure most related to the principal diagnosis was selected as the principal procedure.

CCS categorizes procedure codes into clinically meaningful categories.^2^ This “clinical grouper” makes it easier to quickly understand patterns of procedure use.

### Types of hospitals included in HCUP

HCUP is based on data from community hospitals, defined as short-term, non-Federal, general and other hospitals, excluding hospital units of other institutions (e.g., prisons). HCUP data include OB-GYN, ENT, orthopedic, cancer, pediatric, public, and academic medical hospitals. They exclude long-term care, rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals, but these types of discharges are included if they are from community hospitals.

### Unit of analysis

The unit of analysis is the hospital discharge (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the hospital multiple times in one year will be counted each time as a separate “discharge” from the hospital.

### Costs and charges

Total hospital charges were converted to costs using HCUP Cost-to-Charge Ratios based on hospital accounting reports from the Centers for Medicare and Medicaid Services (CMS).^3^ Costs will tend to reflect the actual costs of production, while charges represent what the hospital billed for the case. For each hospital, a hospital-wide cost-to-charge ratio is used because detailed charges are not available across all HCUP States. Hospital charges reflect the amount the hospital charged for the entire hospital stay and does not include professional (physician) fees. For the purposes of this Statistical Brief, costs are reported to the nearest hundreds.

### Payer

Payer is the expected primary payer for the hospital stay. To make coding uniform across all HCUP data sources, payer combines detailed categories into more general groups:

– Medicare includes fee-for-service and managed care Medicare patients.
– Medicaid includes fee-for-service and managed care Medicaid patients. Patients covered by the State Children’s Health Insurance Program (SCHIP) may be included here. Because most state data do not identify SCHIP patients specifically, it is not possible to present this information separately.
– Private insurance includes Blue Cross, commercial carriers, and private HMOs and PPOs.
– Other includes Worker’s Compensation, TRICARE/CHAMPUS, CHAMPVA, Title V, and other government programs.
– Uninsured includes an insurance status of “self-pay” and “no charge.”

When more than one payer is listed for a hospital discharge, the first-listed payer is used.

## For More Information

For more information about HCUP, visit www.hcup-us.ahrq.gov.

For additional HCUP statistics, visit HCUPnet, our interactive query system, at www.hcup.ahrq.gov.

For information on other hospitalizations in the U.S., download HCUP Facts and Figures: Statistics on Hospital-based Care in the United States in 2007, located at http://www.hcup-us.ahrq.gov/reports.jsp.

For a detailed description of HCUP, more information on the design of the NIS, and methods to calculate estimates, please refer to the following publications:

Steiner, C., Elixhauser, A., Schnaier, J. The Healthcare Cost and Utilization Project: An Overview. Effective Clinical Practice 5(3):143–51, 2002.

Introduction to the HCUP Nationwide Inpatient Sample, 2007. Online. June 16, 2009. U.S. Agency for Healthcare Research and Quality. http://www.hcup-us.ahrq.gov/db/nation/nis/NIS_2007_INTRODUCTION.pdf

Houchens, R., Elixhauser, A. Final Report on Calculating Nationwide Inpatient Sample (NIS) Variances, 2001. HCUP Methods Series Report #2003-2. Online. June 2005 (revised June 6, 2005). U.S. Agency for Healthcare Research and Quality. http://www.hcup-us.ahrq.gov/reports/CalculatingNISVariances200106092005.pdf

Houchens R.L., Elixhauser A. Using the HCUP Nationwide Inpatient Sample to Estimate Trends. (Updated for 1988–2004). HCUP Methods Series Report #2006–05 Online. August 18, 2006. U.S. Agency for Healthcare Research and Quality. http://www.hcup-us.ahrq.gov/reports/2006_05_NISTrendsReport_1988-2004.pdf

1 Hartman M, Martin A, McDonnell P, Catlin A. National Health Spending in 2007: Slower Drug Spending Contributes to Lowest Rate of Overall Growth Since 1998. Health Affairs. 28(1): 246–261, January 2009.

2 HCUP CCS. Healthcare Cost and Utilization Project (HCUP). June 2009. U.S. Agency for Healthcare Research and Quality, Rockville, MD. www.hcup-us.ahrq.gov/toolssoftware/ccs/ccs.jsp

3 HCUP Cost-to-Charge Ratio Files (CCR). Healthcare Cost and Utilization Project (HCUP). 2001–2007. U.S. Agency for Healthcare Research and Quality, Rockville, MD. www.hcup-us.ahrq.gov/db/state/costtocharge.jsp