# Statistical Brief #86 Hospital-Based Ambulatory Surgery, 2007

## Introduction

Ambulatory surgery (AS), or outpatient surgery, is a planned surgical episode where the patient requires hospital care for less than 24 hours. Outpatient procedures account for a growing proportion of surgeries performed in U.S. hospitals because AS increasingly substitutes for inpatient surgery for many procedures.^1^ Nationally, 63 percent of all surgeries in 2005 did not require an overnight hospital stay and were considered outpatient, compared with 51 percent in 1990 and only 16 percent in 1980.^2,3^

Two major factors explain this overall growth in ambulatory surgeries. First, advances in surgical technology and anesthesia have made surgery easier on patients and increased the demand for outpatient procedures. Second, in an effort to reduce rising health care costs, health care payment policies have encouraged AS. For example, the Medicare program adopted an outpatient prospective payment system authorizing payment for surgical services in a variety of settings, such as a physician’s office, a hospital outpatient department, or an ambulatory surgical center. A comparison of AS data to inpatient surgery data is essential for understanding utilization patterns and costs for specific surgical procedures.

This Statistical Brief presents data from the Healthcare Cost and Utilization Project (HCUP) State Ambulatory Surgery Databases (SASD) and State Inpatient Databases (SID). These databases provide information on hospital-based ambulatory and inpatient surgeries performed in short-term, acute-care hospitals in the 28 states that provided AS data to HCUP in 2007. These 28 states encompass about two-thirds of the U.S. population. These statistics exclude procedures performed in freestanding AS centers because these centers are not included in many State AS data sources.

This report compares the utilization of ambulatory surgery procedures in hospitals to inpatient procedures in 28 states that provide data sources for both hospital-based ambulatory and inpatient surgery. The analysis is limited to major invasive procedures requiring anesthesia services or sedation, but excludes procedures that are performed infrequently in ambulatory surgery settings, procedures that are adjunct to the principal procedure, dental procedures, obstetrical procedures, and procedures that are done predominantly in outpatient settings outside of hospitals.^4^ This report provides information about the distribution of inpatient versus outpatient surgical procedures by body system, as well as the most common surgical procedures performed in an outpatient setting. In addition, ambulatory and inpatient volume, procedure rates, and hospital charge information are compared for each procedure. Unless otherwise noted, estimates are based on all-listed procedures. All differences between estimates provided in the text are statistically significant at the 0.05 level or better.

## Findings

Highlights

- In the 28 states evaluated, nearly 58 percent of surgical encounters in hospitals were performed on outpatients.
- There were nearly 5,600 ambulatory surgery (AS) visits per 100,000 population compared with almost 4,100 inpatient surgical visits per 100,000.
- The mean charge for AS was lower than for inpatient surgery—$6,100 versus $39,900. The aggregate charge across the 28 states for AS was about one-fifth of total inpatient charges—$55.6 billion versus $259 billion.
- Procedures related to the digestive system accounted for 40 percent of all AS.
- Procedures done on the eye, ear, and nose/mouth/pharynx were predominantly outpatient. Roughly two-thirds of surgical procedures on the skin, digestive system, and urinary system were outpatient.
- Colonoscopy and biopsy was the most commonly performed AS procedure in 2007, followed by upper GI endoscopy, lens and cataract procedures, diagnostic cardiac catheterization, and debridement of wound.
- Major procedures that were performed less frequently on an outpatient basis, but with significant numbers include PTCA, appendectomy, open prostatectomy, oophorectomy, hysterectomy, hip fracture/ dislocation repair, lower extremity amputation, and spinal fusion.

### Characteristics of ambulatory surgery procedures performed in community hospitals

Based on data from the 28 states examined for this report, nearly 10.8 million ambulatory surgery (AS) visits took place in 2007, totaling $55.6 billion in aggregate charges (table 1). These visits resulted in over 12.4 million procedures (1.2 procedures per AS visit). This compares to 7.9 million inpatient stays that involved 11.0 million surgical procedures (1.4 procedures per hospital stay). Overall, 57.7 percent of procedures performed in hospitals were ambulatory in nature. In 2007, this translated to approximately 5,600 hospital-based AS visits per 100,000 population, compared with 4,100 inpatient procedure stays per 100,000 population.

Table 1 The characteristics of ambulatory and inpatient surgeries performed in community hospitals in 28 states, 2007

Characteristics | Ambulatory surgeries | Inpatient surgeries
Total visits/stays for surgeries (percentage of all surgical encounters) | 10,797,700 (57.7%) | 7,918,400 (42.3%)
Visits/stays per 100,000 population * | 5,600 | 4,100
Total number of surgeries (percentage of all surgical procedures) | 12,426,800 (53.0%) | 11,007,500 (47.0%)
Average number of surgeries per visit/stay | 1.2 | 1.4
Total (aggregate) charge (percentage of total charges for surgical encounters) | $55.6 billion (17.7%) | $258.9 billion (82.3%)
Mean charge per visit/stay^**^ | $6,100 | $39,900
Percentage of visits/stays by type of community hospital^†^:
Large hospitals | 57.5% | 64.4%
Metropolitan hospitals | 83.8% | 90.0%
Teaching hospitals | 44.0% | 52.8%
Non-federal government hospitals | 12.7% | 12.5%
Private not-for-profit hospitals | 76.3% | 76.5%
Private for-profit hospitals | 11.0% | 11.0%

* Based on state population estimates from the U.S. Census Bureau.

** Mean charges are for hospital-based ambulatory and inpatient surgical visits and stays. Inpatient surgical stays are typically more expensive because of longer lengths of stay and the use of multiple procedures.

† Hospital characteristics related to bed size, location, and teaching status are not mutually exclusive.

Source: Agency for Healthcare Research and Quality, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, State Inpatient Databases and State Ambulatory Surgery Databases, 2007, from the following 28 states: CA, CO, CT, FL, GA, HI, IA, IN, KS, KY, MD, ME, MI, MN, MO, NC, NE, NH, NJ, NY, OH, OK, SC, SD, TN, UT, VT, and WI.

The mean charge for hospital-based AS procedures was considerably lower than the charge for inpatient hospital stays that included procedures—$6,100 versus $39,900. Aggregate charges across the 28 states were about one-fifth of the national bill for inpatient—$55.6 billion versus $259 billion. Most hospital-based AS procedures were performed in large, metropolitan, private not-for-profit hospitals. However, compared with inpatient procedures, AS was more likely to be performed in smaller hospitals, outside metropolitan areas, and in non-teaching settings.

### Ambulatory versus inpatient surgeries, by body system

Figure 1 shows that nearly all hospital-based procedures related to the eye (99.3 percent), ear (96.3 percent), and nose/mouth/pharynx (93.8 percent) were outpatient. About two-thirds of all hospital-based procedures on the skin (70.4 percent), digestive system (66.8 percent), and urinary system (61.7 percent) were also outpatient. Roughly half of all hospital-based procedures involving the musculoskeletal (54.0 percent), nervous (47.9 percent), female genital (47.5 percent), and endocrine systems (46.0 percent), were outpatient.

Figure 1 Ambulatory versus inpatient surgeries by body system, 2007

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, State Inpatient Databases and State Ambulatory Surgery Databases, 2007, from the following 28 states: CA, CO, CT, FL, GA, HI, IA, IN, KS, KY, MD, ME, MI, MN, MO, NC, NE, NH, NJ, NY, OH, OK, SC, SD, TN, UT, VT, and WI

Bar chart in percentages; Ambulatory versus Inpatient per body system; Eye, Ambulatory, 99.3; Inpatient, 0.7; Ear, Ambulatory, 96.3; Inpatient, 3.7; Nose/mouth/pharynx, Ambulatory, 93.8; Inpatient, 6.2; Skin, Ambulatory, 70.4; Inpatient, 29.6; Digestive, Ambulatory, 66.8; Inpatient, 33.2; Urinary, Ambulatory, 61.7; Inpatient, 38.3; Musculoskeletal, Ambulatory, 54.0; Inpatient, 46.0; Nervous, Ambulatory, 47.9; Inpatient, 52.1; Female genital, Ambulatory, 47.5; Inpatient, 52.5; Endocrine, Ambulatory, 46.0; Inpatient, 54.0; Respiratory, Ambulatory, 31.2; Inpatient, 66.8; Cardiovascular, Ambulatory, 29.4; Inpatient, 70.6; Male genital, Ambulatory, 9.3; Inpatient, 90.7; Hnic/lymphatic, Ambulatory, 9.3; Inpatient, 90.7.

In contrast, respiratory, cardiovascular, male genital, and hemic/lymphatic procedures were primarily inpatient. About one in three surgical procedures on the respiratory (31.2 percent) and cardiovascular (29.4 percent) systems were performed in an outpatient setting, while less than 10 percent of all procedures on male genital organs and the hemic/lymphatic system were outpatient.

### The most common ambulatory surgeries performed in community hospitals

Table 2 lists the 25 most common AS procedures performed in community hospitals. Colonoscopy and biopsy was the most common AS procedure and comprised nearly 18.1 percent of all procedures performed in an outpatient setting. Upper GI endoscopy and biopsy accounted for 10.8 percent of all outpatient procedures. Other digestive system procedures commonly performed in the outpatient setting included: cholecystectomy, or gall bladder surgery (2.5 percent of all AS); hernia repair (inguinal and femoral─2.1 percent; other hernias─1.4 percent); and esophageal dilatation (1.3 percent). In fact, more ambulatory surgeries involved the digestive system (40.0 percent) than any other body system (data not shown).

Table 2 The 25 most common ambulatory surgeries performed in community hospitals in 28 states, 2007

All-listed procedures | Percentage of all ambulatory surgeries | Total number | | Total number of surgeries per 100,000 population^*^ | | Percentage performed in an ambulatory setting
All-listed procedures | Percentage of all ambulatory surgeries | Ambulatory surgeries (in thousands) | Inpatient surgeries (in thousands) | Ambulatory surgeries | Inpatient surgeries | Percentage performed in an ambulatory setting
Colonoscopy and biopsy | 18.1% | 2,247 | 363 | 1,160 | 187 | 86.1%
Upper gastrointestinal endoscopy, biopsy | 10.8% | 1,347 | 756 | 695 | 390 | 64.0%
Lens and cataract procedures | 5.5% | 689 | 1 | 356 | 1 | 99.8%
Diagnostic cardiac catheterization, coronary arteriography | 3.8% | 471 | 937 | 243 | 484 | 33.4%
Debridement of wound, infection or burn | 2.6% | 326 | 196 | 168 | 101 | 62.4%
Excision of semilunar cartilage of knee | 2.5% | 317 | 6 | 164 | 3 | 98.2%
Cholecystectomy and common duct exploration | 2.5% | 313 | 267 | 162 | 138 | 53.9%
Tonsillectomy and/or adenoidectomy | 2.5% | 306 | 17 | 158 | 9 | 94.8%
Inguinal and femoral hernia repair | 2.1% | 267 | 32 | 138 | 17 | 89.3%
Other excision of cervix and uterus | 2.1% | 266 | 34 | 137 | 18 | 88.6%
Breast biopsy and other diagnostic procedures on breast | 1.9% | 241 | 7 | 124 | 4 | 97.3%
Lumpectomy, quadrantectomy of breast | 1.9% | 235 | 11 | 121 | 6 | 95.5%
Myringotomy (ear tube surgery) | 1.9% | 232 | 7 | 120 | 4 | 97.0%
Endoscopy and endoscopic biopsy of the urinary tract | 1.6% | 199 | 124 | 103 | 64 | 61.5%
Partial excision bone | 1.5% | 191 | 130 | 99 | 67 | 59.6%
Diagnostic dilatation and curettage (D&C) | 1.5% | 190 | 15 | 98 | 8 | 92.6%
Transurethral excision, drainage, or removal urinary obstruction | 1.5% | 186 | 71 | 96 | 37 | 72.3%
Decompression peripheral nerve | 1.5% | 185 | 10 | 95 | 5 | 95.0%
Arthroplasty other than hip or knee | 1.4% | 180 | 43 | 93 | 22 | 80.8%
Other hernia repair | 1.4% | 175 | 134 | 90 | 69 | 56.5%
Incision and drainage, skin and subcutaneous tissue | 1.4% | 169 | 145 | 87 | 75 | 53.9%
Ureteral catheterization | 1.3% | 165 | 118 | 85 | 61 | 58.2%
Esophageal dilatation | 1.3% | 161 | 25 | 83 | 13 | 86.4%
Other fracture and dislocation procedure | 1.2% | 148 | 101 | 76 | 52 | 59.3%
Diagnostic bronchoscopy and biopsy of bronchus | 1.1% | 141 | 236 | 73 | 122 | 37.5%

* Based on state population estimates from the U.S. Census Bureau.

Source: Agency for Healthcare Research and Quality, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, State Inpatient Databases and State Ambulatory Surgery Databases, 2007, from the following 28 States: CA, CO, CT, FL, GA, HI, IA, IN, KS, KY, MD, ME, MI, MN, MO, NC, NE, NH, NJ, NY, OH, OK, SC, SD, TN, UT, VT, and WI.

Though procedures on the cardiovascular system accounted for a small number of AS overall, diagnostic cardiac catheterization alone comprised 3.8 percent of all outpatient procedures in the hospitals in these 28 states. Four of the 25 most common ambulatory procedures were related to the musculoskeletal system: excision of semilunar cartilage of knee (2.5 percent of all AS), partial bone excision (1.5 percent), arthroplasty other than hip or knee (1.4 percent), and other fracture and dislocation procedure (1.2 percent). Two commonly performed outpatient procedures on the skin were wound debridement (2.6 percent) and incision and drainage of the skin and subcutaneous tissue (1.4 percent).

Lens and cataract procedures, most often performed on elderly patients, accounted for 5.5 percent of all AS in the hospitals in these 28 states.^5^ Four of the 25 most common outpatient procedures were primarily or exclusively performed on women: other excision of cervix and uterus (2.1 percent of all AS), breast biopsy (1.9 percent), lumpectomy/quadrantectomy of the breast (1.9 percent), and diagnostic dilatation and curettage (D&C) (1.5 percent). Tonsillectomy and/or adenoidectomy and myringotomy (ear tube surgery)—two procedures primarily performed on children—were two of the most common surgical procedures performed in the ambulatory setting (2.5 percent and 1.9 percent of all procedures, respectively).

Three procedures involving the urinary tract were also among the top 25 AS procedures performed in hospitals—endoscopy/biopsy (1.6 percent of all AS), transurethral procedures for urinary obstruction (1.5 percent), and ureteral catheterization (1.3 percent). Finally, decompression of peripheral nerves (e.g., carpal tunnel release) comprised 1.5 percent of all AS, while bronchoscopy made up 1.1 percent of all AS.

Table 2 also provides information on the total number of procedures, rates, and the percentage of each procedure performed on an outpatient basis. For many procedures, it is clear that very few are done in an inpatient setting. For example, lens and cataract procedures, excision of semilunar cartilage of the knee, tonsillectomy, breast biopsy, lumpectomy, myringotomy, D&C, and decompression of peripheral nerve have rates lower than 10 inpatient procedures per 100,000 population, while rates for their outpatient counterparts are 12–50 times higher (over 300 times higher for lens procedures).

### An inventory of ambulatory surgical procedures performed in community hospitals

The appendix provides a comprehensive listing of all major procedures, by body system, performed in an outpatient setting in community hospitals.^6^ Overall, the highest numbers of ambulatory surgical procedures were performed on the digestive and musculoskeletal systems. The endocrine system accounted for the fewest outpatient procedures.

The appendix also provides details on procedures less commonly performed in AS settings that were not covered in table 2. For example, although laminectomy (Clinical Classifications Software (CCS) 3) is not a predominantly outpatient procedure, 22.1 percent were performed in an ambulatory setting (42.7 AS procedures per 100,000 population versus 150.8 inpatient (IP) procedures per 100,000 population). Other major procedures that are not predominantly AS but with significant numbers of ambulatory cases include:

– PTCA (CCS 45): 17.7 AS procedures vs. 242.4 IP procedures per 100,000 population
– Appendectomy (CCS 80): 26.8 AS procedures vs. 118.9 IP procedures per 100,000 population
– Open prostatectomy (CCS 114): 3.0 AS procedures vs. 28.1 IP procedures per 100,000 population
– Oophorectomy (CCS 119): 31.9 AS procedures vs. 121.4 IP procedures per 100,000 population
– Hysterectomy (CCS 124): 26.7 AS procedures vs. 166.6 IP procedures per 100,000 population
– Hip fracture/dislocation repair (CCS 146): 8.1 AS procedures vs. 98.0 IP procedures per 100,000 population
– Lower extremity amputation (CCS 157): 8.1 AS procedures vs. 38.2 IP procedures per 100,000 population
– Spinal fusion (CCS 158): 14.8 AS procedures vs. 124.0 IP procedures per 100,000 population

Mean charges for outpatient procedures were always lower than for inpatient. However, the difference in inpatient and outpatient charges for operations on the male genital organs was minimal when compared to other surgeries. The highest mean charges per visit were found among outpatient procedures performed on the cardiovascular system.

## Data Source

The estimates in this Statistical Brief are based upon data from the HCUP 2007 State Inpatient Database (SID) and 2007 State Ambulatory Surgery Database (SASD). This report evaluates inpatient and outpatient surgery data from 28 selected states that contributed data to both the 2007 SASD and SID: California, Colorado, Connecticut, Florida, Georgia, Hawaii, Indiana, Iowa, Kansas, Kentucky, Maine, Maryland, Michigan, Minnesota, Missouri, Nebraska, New Hampshire, New Jersey, New York, North Carolina, Ohio, Oklahoma, South Carolina, South Dakota, Tennessee, Utah, Vermont, and Wisconsin. Supplemental source included data on state population estimates from Table 1: Annual Estimates of the Population for the United States, Regions, States, and Puerto Rico: April 1, 2000 to July 1, 2007 (NST-EST2007-01), Population Division, U.S. Census Bureau, Release date: December 27, 2007 (http://www.census.gov/popest/states/tables/NST-EST2007-01.xls).

## Definitions

### Surgical procedures and Clinical Classifications Software (CCS)

Multiple surgical procedures can be listed on a record in the SID and SASD. Frequencies and rankings of procedures are based on all-listed—that is, all procedures listed on the record. Procedures are de-duplicated: if a particular procedure occurs multiple times during the same surgical visit or hospital stay, it is counted only once.

CCS groupings of procedures were used throughout the report. CCS categorizes procedure codes into clinically meaningful categories.^7^ This “clinical grouper” makes it easier to quickly understand patterns of procedure use.

Procedures on ambulatory surgery records can be coded using ICD-9-CM or the Common Procedural Terminology (CPT). When CPT was used, the CCS for Services and Procedures^8^ was used to classify procedures into groupings comparable to the CCS.

### Case definition

Records from the SASD meeting the following criteria were included:

– At least one surgical procedure as defined by an International Classification of Diseases, 9th Revision, Clinical Modification (ICD-9-CM) procedure code in the range of 00.50–86.99 or 88.40–88.59.
– At least one major therapeutic or diagnostic operating room procedure as defined by the HCUP Procedure Classes.^9^ Diagnostic procedures are included only if invasive, requiring anesthesia services or sedation.
– Length of stay of 0 or 1 day.
– Originate from a hospital-based ambulatory surgery center having at least 200 ambulatory surgical visits per year.
– The ambulatory surgery facility is designated as a short-term, community, non-rehabilitation hospital. Freestanding ambulatory surgery centers were not included.
– The procedure comprised at least 2,000 ambulatory surgery cases across the 28 states in 2007, because the focus of this analysis was on the most frequent procedures done in the ambulatory setting.
– Excludes procedures with the following characteristics: a procedure that is adjunct to another procedure (e.g., “extracorporeal circulation auxiliary to open heart procedures”), a heterogeneous “other” procedure category (e.g., “other OR heart procedures” which includes a wide range of heterogeneous, infrequent procedures), dental procedures, and procedures predominantly done in freestanding centers, radiology centers, or physician offices (e.g., “dialysis,” “proctoscopy,” “extracorporeal lithotripsy,” and “indwelling catheter”).
– Obstetrical procedures were excluded.

Records from the SID meeting similar criteria were included:

– At least one surgical procedure as defined by an ICD-9-CM procedure code in the range of 00.50–86.99 or 88.40–88.59.
– At least one major therapeutic or diagnostic operating room procedure as defined by the HCUP Procedure Classes. Diagnostic procedures are included only if invasive, requiring anesthesia services or sedation.
– Originate from a hospital with at least 200 inpatient surgical stays.
– The inpatient facility is designated as a short-term, community, non-rehabilitation hospital.
– The procedure met the criteria for including procedures from the SASD.
– Obstetrical procedures were excluded.

### Types of hospitals included in HCUP

HCUP is based on data from community hospitals, defined as short-term, non-Federal, general and other hospitals, excluding hospital units of other institutions (e.g., prisons). HCUP data include OB-GYN, ENT, orthopedic, cancer, pediatric, public, and academic medical hospitals. They exclude long-term care, rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals, but these types of encounters are included if they are from community hospitals.

### Unit of analysis

For this report, any reference to “visit” or “hospital stay” indicates that the unit of analysis is the record rather than the surgical procedure. Any reference to “surgeries” indicates that the unit of analysis is a major operating room procedure. A visit or stay can involve multiple procedures.

### Charges

Charges in HCUP data are the amount the hospital charged or billed for the entire surgical visit or hospital stay and do not reflect charges for individual surgical procedures. Charges do not necessarily reflect reimbursements or costs and do not include most professional (physician) fees. Cost-to-charge ratios are available to convert inpatient hospital charges to inpatient hospital costs, but an equivalent ratio for outpatient hospital data is currently not available.

## For More Information

For more information about HCUP, visit www.hcup-us.ahrq.gov.

For additional HCUP statistics, visit HCUPnet, our interactive query system, at www.hcup.ahrq.gov.

For information on other hospitalizations in the U.S., download HCUP Facts and Figures: Statistics on Hospital-Based Care in the United States in 2007, located at http://www.hcup-us.ahrq.gov/reports.jsp.

For a detailed description of HCUP, more information on the design of the SID, SASD, and methods to calculate estimates, please refer to the following publications:

Steiner, C., Elixhauser, A., Schnaier, J. The Healthcare Cost and Utilization Project: An Overview. Effective Clinical Practice 5(3):143–51, 2002.

Introduction to the HCUP State Inpatient Databases. Online. July 17, 2009. U.S. Agency for Healthcare Research and Quality. http://www.hcup-us.ahrq.gov/db/state/siddist/Introduction_to_SID.pdf.

Introduction to the HCUP State Ambulatory Surgery Databases. Online. July 17, 2009. U.S. Agency for Healthcare Research and Quality. http://www.hcup-us.ahrq.gov/db/state/sasddist/Introduction_to_SASD.pdf.

Russo, C.A., Owens, P., Steiner, C., Josephsen J. Ambulatory Surgery in U.S. Hospitals, 2003. HCUP Fact Book No. 9. Online. January 2007. U.S. Agency for Healthcare Research and Quality. http://www.ahrq.gov/data/hcup/factbk9/factbk9.pdf.

Appendix Major ambulatory surgeries performed in community hospitals in 28 states, 2007^*^ (pages 11 through 15)

All-Listed procedures (CCS number and category) | Total number | | Total number of surgeries per 100,000 population^**^ | | Percentage performed in an ambulatory setting | Mean charge per visit/stay
All-Listed procedures (CCS number and category) | Ambulatory surgeries (in thousands) | Inpatient surgeries (in thousands) | Ambulatory surgeries | Inpatient surgeries | Percentage performed in an ambulatory setting | Ambulatory surgeries | Inpatient surgeries
Operations on the nervous system
1 Incision and excision of CNS | 73.7 | 68.8 | 38.1 | 35.5 | 51.7 | $10,829 | $79,485
3 Laminectomy, excision intervertebral disc | 82.7 | 292.1 | 42.7 | 150.8 | 22.1 | $12,038 | $24,987
6 Decompression peripheral nerve | 184.7 | 9.7 | 95.4 | 5.0 | 95.0 | $4,672 | $25,956
Operations on the endocrine system
10 Thyroidectomy, partial or complete | 33.3 | 39.0 | 17.2 | 20.2 | 46.0 | $13,493 | $20,628
Operations on the eye
13 Corneal transplant | 11.7 | 0.3 | 6.0 | 0.1 | 97.6 | $13,119 | $27,705
14 Glaucoma procedures | 41.3 | 0.4 | 21.3 | 0.2 | 99.1 | $4,938 | $19,231
15 Lens and cataract procedures | 689.4 | 1.3 | 355.9 | 0.7 | 99.8 | $4,870 | $23,183
16 Repair of retinal tear, detachment | 57.0 | 1.7 | 29.4 | 0.9 | 97.1 | $10,516 | $31,161
17 Destruction of lesion of retina and choroid | 31.1 | 2.2 | 16.1 | 1.1 | 93.4 | $2,337 | $101,386
Operations on the ear
22 Tympanoplasty | 36.7 | 1.0 | 19.0 | 0.5 | 97.4 | $7,739 | $18,555
23 Myringotomy | 231.9 | 7.2 | 119.7 | 3.7 | 97.0 | $3,547 | $22,930
24 Mastoidectomy | 10.9 | 1.9 | 5.6 | 1.0 | 85.4 | $13,900 | $33,980
25 Diagnostic procedures on ear | 4.4 | 0.9 | 2.3 | 0.5 | 83.2 | $2,990 | $28,530
Operations on the nose, mouth, and pharynx
28 Plastic procedures on nose | 127.0 | 12.0 | 65.6 | 6.2 | 91.4 | $7,809 | $23,343
30 Tonsillectomy and/or adenoidectomy | 306.4 | 16.7 | 158.1 | 8.6 | 94.8 | $5,286 | $13,618
Operations on the respiratory system
35 Tracheoscopy and laryngoscopy with biopsy | 69.2 | 41.8 | 35.7 | 21.6 | 62.4 | $3,267 | $24,223
37 Diagnostic bronchoscopy and biopsy of bronchus | 141.5 | 235.6 | 73.0 | 121.6 | 37.5 | $4,608 | $43,630
39 Incision of pleura, thoracentesis, chest drainage | 38.4 | 270.7 | 19.8 | 139.8 | 12.4 | $3,076 | $33,347
Operations on the cardiovascular system
45 Percutaneous coronary angioplasty (PTCA) | 34.2 | 469.5 | 17.7 | 242.4 | 6.8 | $34,920 | $46,769
47 Diagnostic cardiac catheterization, coronary arteriography | 470.9 | 937.2 | 243.1 | 483.8 | 33.4 | $11,878 | $28,260
48 Insertion, revision, replacement, removal of cardiac pacemaker or cardioverter/defibrillator | 82.4 | 237.1 | 42.5 | 122.4 | 25.8 | $28,441 | $73,658
53 Varicose vein stripping, lower limb | 25.4 | 0.8 | 13.1 | 0.4 | 97.0 | $8,459 | $23,228
57 Creation, revision and removal of arteriovenous fistula or vessel-to-vessel cannula for dialysis | 78.9 | 35.2 | 40.7 | 18.2 | 69.1 | $10,277 | $55,828
60 Embolectomy and endarterectomy of lower limbs | 18.8 | 28.1 | 9.7 | 14.5 | 40.2 | $20,550 | $49,739
Operations on the hemic and lymphatic system
65 Bone marrow biopsy | 40.0 | 63.0 | 20.7 | 32.5 | 38.8 | $5,069 | $56,469
222 Blood transfusion | 134.5 | 1631.5 | 69.4 | 842.1 | 7.6 | $3,435 | $24,926
Operations on the digestive system
68 Injection or ligation of esophageal varices | 7.0 | 0.1 | 3.6 | 0.1 | 98.3 | $2,464 | $43,076
69 Esophageal dilatation | 160.7 | 25.2 | 83.0 | 13.0 | 86.4 | $3,116 | $22,833
70 Upper gastrointestinal endoscopy, biopsy | 1346.8 | 756.3 | 695.2 | 390.4 | 64.0 | $3,131 | $25,226
71 Gastrostomy, temporary and permanent | 32.1 | 144.7 | 16.6 | 74.7 | 18.1 | $3,846 | $51,514
76 Colonoscopy and biopsy | 2247.4 | 363.1 | 1160.0 | 187.4 | 86.1 | $2,369 | $24,356
80 Appendectomy | 51.9 | 230.3 | 26.8 | 118.9 | 18.4 | $14,156 | $21,746
81 Hemorrhoid procedures | 64.2 | 7.9 | 33.1 | 4.1 | 89.0 | $5,978 | $20,173
82 Endoscopic cannulation of pancreas (ERCP) | 42.1 | 26.9 | 21.7 | 13.9 | 61.0 | $6,115 | $32,782
83 Biopsy of liver | 73.4 | 50.3 | 37.9 | 25.9 | 59.4 | $3,599 | $41,657
84 Cholecystectomy and common duct exploration | 312.6 | 266.9 | 161.4 | 137.8 | 53.9 | $10,838 | $32,339
85 Inguinal and femoral hernia repair | 266.9 | 31.8 | 137.8 | 16.4 | 89.3 | $8,187 | $35,598
86 Other hernia repair | 174.6 | 134.4 | 90.1 | 69.4 | 56.5 | $8,711 | $30,397
87 Laparoscopy | 83.3 | 56.6 | 43.0 | 29.2 | 59.5 | $8,215 | $31,572
88 Abdominal paracentesis | 62.5 | 132.3 | 32.2 | 68.3 | 32.1 | $2,590 | $30,956
90 Excision, lysis peritoneal adhesions | 41.3 | 242.1 | 21.3 | 125.0 | 14.6 | $10,311 | $48,373
Operations on the urinary system
100 Endoscopy and endoscopic biopsy of the urinary tract | 198.9 | 124.5 | 102.7 | 64.3 | 61.5 | $4,300 | $29,406
101 Transurethral excision, drainage, or removal urinary obstruction | 185.6 | 71.1 | 95.8 | 36.7 | 72.3 | $8,044 | $24,309
102 Ureteral catheterization | 165.0 | 118.3 | 85.2 | 61.1 | 58.2 | $7,944 | $23,466
103 Nephrotomy and nephrostomy | 5.9 | 27.8 | 3.0 | 14.4 | 17.5 | $11,877 | $45,946
106 Genitourinary incontinence procedures | 71.9 | 63.5 | 37.1 | 32.8 | 53.1 | $9,929 | $16,633
109 Procedures on the urethra | 62.8 | 23.5 | 32.4 | 12.1 | 72.8 | $6,544 | $26,881
Operations on the male genital organs
113 Transurethral prostatectomy (TURP) | 30.2 | 47.6 | 15.6 | 24.6 | 38.8 | $10,900 | $18,612
114 Open prostatectomy | 5.8 | 54.4 | 3.0 | 28.1 | 9.6 | $22,771 | $26,890
115 Circumcision | 54.7 | 786.2 | 28.2 | 405.8 | 6.5 | $4,770 | $5,727
Operations on the female genital organs
119 Oophorectomy, unilateral and bilateral | 61.9 | 235.2 | 31.9 | 121.4 | 20.8 | $11,896 | $22,540
121 Ligation of fallopian tubes | 96.8 | 189.5 | 49.9 | 97.8 | 33.8 | $7,646 | $11,455
122 Removal ectopic pregnancy | 8.4 | 11.5 | 4.4 | 5.9 | 42.4 | $12,421 | $17,145
124 Hysterectomy, abdominal and vaginal | 51.8 | 322.7 | 26.7 | 166.6 | 13.8 | $14,839 | $19,476
125 Other excision of cervix and uterus | 266.3 | 34.1 | 137.4 | 17.6 | 88.6 | $7,362 | $19,339
127 Dilatation and curettage (D&C), aspiration after delivery or abortion | 121.3 | 26.3 | 62.6 | 13.6 | 82.2 | $5,472 | $13,189
128 Diagnostic dilatation and curettage (D&C) | 190.0 | 15.3 | 98.1 | 7.9 | 92.6 | $6,366 | $22,376
129 Repair of cystocele and rectocele, obliteration of vaginal vault | 26.0 | 75.2 | 13.4 | 38.8 | 25.7 | $11,504 | $16,398
Operations on the musculoskeletal system
142 Partial excision bone | 191.2 | 129.8 | 98.7 | 67.0 | 59.6 | $7,590 | $43,531
143 Bunionectomy or repair of toe deformities | 115.3 | 3.2 | 59.5 | 1.6 | 97.3 | $7,699 | $21,552
144 Treatment, facial fracture or dislocation | 57.5 | 20.9 | 29.7 | 10.8 | 73.4 | $7,872 | $37,249
145 Treatment, fracture or dislocation of radius and ulna | 114.5 | 51.0 | 59.1 | 26.3 | 69.2 | $7,807 | $27,774
146 Treatment, fracture or dislocation of hip and femur | 15.7 | 189.8 | 8.1 | 98.0 | 7.6 | $7,435 | $39,431
147 Treatment, fracture or dislocation of lower extremity (other than hip or femur) | 104.0 | 143.8 | 53.7 | 74.2 | 42.0 | $8,916 | $30,789
148 Other fracture and dislocation procedure | 147.6 | 101.4 | 76.2 | 52.3 | 59.3 | $6,986 | $33,983
149 Arthroscopy | 122.7 | 10.1 | 63.3 | 5.2 | 92.4 | $8,970 | $26,028
150 Division of joint capsule, ligament or cartilage | 44.8 | 9.7 | 23.1 | 5.0 | 82.3 | $8,436 | $21,661
151 Excision of semilunar cartilage of knee | 316.8 | 5.8 | 163.5 | 3.0 | 98.2 | $7,357 | $25,900
152 Arthroplasty knee | 140.4 | 375.0 | 72.4 | 193.6 | 27.2 | $12,535 | $38,674
154 Arthroplasty other than hip or knee | 180.2 | 42.7 | 93.0 | 22.1 | 80.8 | $11,387 | $35,824
155 Arthrocentesis | 100.3 | 44.5 | 51.8 | 23.0 | 69.3 | $1,149 | $21,822
157 Amputation of lower extremity | 15.7 | 74.1 | 8.1 | 38.2 | 17.5 | $5,843 | $58,073
158 Spinal fusion | 28.6 | 240.2 | 14.8 | 124.0 | 10.6 | $23,175 | $67,079
Operations on the integumentary system
165 Breast biopsy and other diagnostic procedures on breast | 240.5 | 6.7 | 124.1 | 3.4 | 97.3 | $3,863 | $33,749
166 Lumpectomy, quadrantectomy of breast | 235.0 | 11.1 | 121.3 | 5.7 | 95.5 | $7,458 | $21,836
167 Mastectomy | 22.9 | 46.0 | 11.8 | 23.7 | 33.3 | $15,003 | $23,339
168 Incision and drainage, skin and subcutaneous tissue | 169.4 | 145.0 | 87.4 | 74.9 | 53.9 | $1,674 | $18,201
169 Debridement of wound, infection or burn | 326.0 | 196.0 | 168.3 | 101.2 | 62.4 | $1,790 | $45,742
172 Skin graft | 111.5 | 59.8 | 57.5 | 30.9 | 65.1 | $6,080 | $66,369

* Statistics are based on major surgery-related procedures only. Diagnostic procedures are included only if invasive, requiring anesthesia services or sedation. Additionally, CCS procedure categories with fewer than 2,000 ambulatory surgery cases are excluded. Other excluded procedures include: a procedure that is adjunct to another procedure, a heterogeneous “other” procedure category, dental procedures, and procedures predominantly done in freestanding centers, radiology centers, or physician offices.

** Based on State population estimates from the U.S. Census Bureau.

Source: Agency for Healthcare Research and Quality, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, State Inpatient Databases and State Ambulatory Surgery Databases, 2007, from the following States: CA, CO, CT, FL, GA, HI, IA, IN, KS, KY, MD, ME, MI, MN, MO, NC, NE, NH, NJ, NY, OH, OK, SC, SD, TN, UT, VT, and WI.

1 LJ, McCarthy E, Pokras R. Changing patterns of surgical care in the United States, 1980-1995. Health Care Finance Rev. 1999 Fall; 21(1):31-49.

2 National Center for Health Statistics. Health, United States, 2007 with Chartbook on Trends in the Health of Americans. Hyattsville, MD: 2008.

3 These statistics include major and minor surgical procedures performed in inpatient operating suites, outpatient surgery suites, or procedure rooms within an outpatient care facility.

4 Full details about the types of procedures reported in this report are provided under “Definitions” on page 4.

5 The total number of lens and cataract procedures is much higher; many are performed in freestanding AS centers, which are not included in these data.

6 The appendix shows all procedures that were considered “surgical procedures” throughout this Brief. That is, these procedures comprise all the surgeries from which information was derived for tables 1-2 and figure 1.

7 HCUP CCS. Healthcare Cost and Utilization Project (HCUP). June 2009. U.S. Agency for Healthcare Research and Quality, Rockville, MD. www.hcup-us.ahrq.gov/toolssoftware/ccs/ccs.jsp

8 HCUP CCS-Services and Procedures. Healthcare Cost and Utilization Project (HCUP). June 2009. Agency for Healthcare Research and Quality, Rockville, MD. www.hcup-us.ahrq.gov/toolssoftware/ccs_svcsproc/ccssvcproc.jsp.

9 HCUP Procedure Classes. Healthcare Cost and Utilization Project (HCUP). November 2009. Agency for Healthcare Research and Quality, Rockville, MD. www.hcup-us.ahrq.gov/toolssoftware/procedure/procedure.jsp.