# Statistical Brief #75 Sports Injuries in Children Requiring Hospital Emergency Care, 2006

## Introduction

During 2006, unintentional injuries accounted for nearly a quarter of the estimated 119.2 million visits to hospital emergency departments (EDs) in the United States.^1^ Unintentional injuries sustained during sports are very common and frequently require emergency care; about 12,000 Americans are treated each day in the ED for sports-related injuries.^2^ Approximately two-thirds of all sports-related injury ED visits are for children.^3,4^

While the majority of children who visit the ED for sports-related injuries are treated and released, a small yet significant number of children are hospitalized for further care. A better understanding of the types of sports injuries for which children are being seen in the ED and differences in utilization patterns by patient demographics is critical to gain a complete picture of ED utilization for sports injuries in children.

This Statistical Brief presents data from the Healthcare Cost and Utilization Project (HCUP) on characteristics of ED care for sports injuries among children (patients ages 5 to 17 years) from the 25 states that provided ED and inpatient hospital data to HCUP in 2006. Common reasons for sports-related injury ED visits are examined with a specific focus on understanding which conditions resulted in the child being treated and released from the ED versus admitted to the hospital. Additionally, ED visits for sports-related injuries are examined by age, gender, urban-rural area of residence, and community-level income.

## Findings

Highlights

- Sports-related injuries accounted for one in five (22.0 percent) of the 1.4 million visits to the ED for injuries among children ages 5 to 17 in the 25 states included in this Brief.
- Children were treated and released from the ED in 98.7 percent of sports-related ED visits; whereas, in 1.3 percent of cases children were admitted to the hospital for further care.
- Oldest children (15–17 years) had the highest ED visit rates for sports injuries and the youngest children (5–9 years) had the lowest rates (154.0 visits versus 29.8 visits per 10,000 children in each age group, respectively).
- Boys had three times greater ED visit rates for sports injuries compared to girls (146.7 visits per 10,000 boys compared to 49.7 visits per 10,000 girls).
- Rates of sports injury visits were highest in remote rural settings (133.4 ED visits per 10,000 children) and lowest in metropolitan areas (105.0 and 87.7 visits per 10,000 children in small and large metropolitan areas, respectively).
- Superficial injury (contusion) was the single most common treat-and-release ED condition related to sports injury for boys and girls (51,700 and 20,000 visits, respectively).
- Leg and arm fractures were the most common reasons for sports-related ED visits in children to result in hospital admission, collectively accounting for 1,900 admissions from the ED.

Sports-related injuries accounted for one in five (22.0 percent) of 1.4 million visits to the ED for injuries among children aged 5 to 17 years in 2006 in the 25 states included in this brief (table 1). The overwhelming majority (98.7 percent) of sports-related injuries were “treat-and-release” cases (i.e., the child was released from the ED rather than being admitted to that hospital for further care); the remaining 1.3 percent of visits resulted in hospital admission.

Table 1 Overview of ED visits among children^†^ with sports injuries in 25 selected states, 2006

| All injury ED visits | Sports injury ED visits
| All injury ED visits | All sports injury ED visits | Treat-and-release ED visits for sports injuries | ED visits for sports injuries resulting in hospital admission
Number of visits (percentage of all ED visits) | 1,349,900 | 296,700 (100%) | 292,800 (98.7%) | 3,900 (1.3%)
Mean child age in years | 11.1 | 13.2 | 13.2 | 13.7
Rates per 10,000 children
All ED visits in children | 452.3 | 99.4 | 98.1 | 1.3
Age
5–9 years | 452.6 | 29.8 | 29.4 | 0.3
10–14 years | 451.9 | 130.9 | 129.5 | 1.5
15–17 years | 452.4 | 154.0 | 151.4 | 2.6
Gender
Girls | 373.5 | 49.7 | 49.4 | 0.3
Boys | 527.2 | 146.7 | 144.5 | 2.2
Patient residence^*^
Large metropolitan | 408.0 | 87.7 | 86.3 | 1.4
Small metropolitan | 464.5 | 105.0 | 103.8 | 1.2
Micropolitan (large town rural) | 577.5 | 128.5 | 127.3 | 1.2
Non-metropolitan, non-micropolitan (remote rural) | 577.6 | 133.4 | 132.1 | 1.3
Median community level income^*^
Bottom quartile (poorest) | 568.5 | 96.5 | 95.1 | 1.3
Second quartile (lower middle income) | 481.3 | 100.1 | 98.9 | 1.2
Third quartile (upper middle income) | 400.7 | 94.1 | 92.9 | 1.3
Fourth quartile (wealthiest) | 340.4 | 97.3 | 95.9 | 1.4

† Patients aged 5 to 17 years.

* A small percentage of ED records that were missing patient residence or median community-level income information were excluded from rate calculations.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), State Emergency Department Databases (SEDD) and State Inpatient Databases (SID) for the following 25 states: Arizona, California, Connecticut, Florida, Georgia, Hawaii, Indiana, Iowa, Kansas, Maine, Maryland, Minnesota, Missouri, Nebraska, New Hampshire, New Jersey, New York, Ohio, Rhode Island, South Carolina, South Dakota, Tennessee, Utah, Vermont, and Wisconsin; Denominator data for rates were based on 2006 Claritas data for the 25 study states.

### General characteristics of ED visits for sports injuries in children

ED visits for sports-related injuries among children aged 5 to 17 years varied by demographic characteristics, with rates being highest among older children and boys, as well as among children living in non-metropolitan areas (table 1 and figure 1).

Figure 1 Older children and boys were treated in the ED for sports-related injuries more commonly than younger children and girls, 2006

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), State Emergency Department Databases (SEDD) and State Inpatient Databases (SID) for the following 25 states: Arizona, California, Connecticut, Florida, Georgia, Hawaii, Indiana, Iowa, Kansas, Maine, Maryland, Minnesota, Missouri, Nebraska, New Hampshire, New Jersey, New York, Ohio, Rhode Island, South Carolina, South Dakota, Tennessee, Utah, Vermont, and Wisconsin; denominator data for rates were based on 2006 Claritas data for the 25 study states.

The mean age of children seen in the ED for sports-related injuries was older than the mean age of children seen for all injuries (13.2 years versus 11.1 years). Whereas rates of ED visits for all injuries were similar across age groups (approximately 452 visits per 10,000 children), ED visits for sports injuries varied by age group: oldest children had the highest visit rates and the youngest children had the lowest rates (154.0 visits versus 29.8 visits per 10,000 children in each age group, respectively). The association between increasing age and higher rate of ED visits for sports injuries in children held true, regardless of whether visits were treat-and-release or resulted in hospitalization. On average, children admitted to the hospital were slightly older (13.7 years) than those who were treated and released from the ED (13.2 years).

The rate of ED visits for sports injuries in children was about three times greater among boys than girls (146.7 visits per 10,000 boys compared to 49.7 visits per 10,000 girls), and this gender difference increased for those ED visits that resulted in hospitalization (2.2 admissions per 10,000 boys compared to 0.3 admissions per 10,000 girls). This gender difference may be attributable to a larger percentage of boys engaging in sports-related activities compared to girls.^5^

Similar to all injury ED visits in children, rates of sports injury visits were highest in non-metropolitan/non-micropolitan (remote rural) settings (133.4 ED visits per 10,000 children) and lowest in metropolitan areas (105.0 and 87.7 visits per 10,000 children in small and large metropolitan areas, respectively). However, these large differences in ED visit rates in children by patient residence were not seen among those sports injury ED visits that resulted in a hospital admission (which ranged from 1.2 to 1.4 visits per 10,000 children).

Lastly, rates of ED visits in children for all injuries were inversely associated with community-level income, such that the poorest communities experienced the highest rates of injury ED visits. However, rates of ED visits in children for sports-related injuries did not follow a similar trend nor did they vary as much by community-level income. Sports-related injury ED visits were highest among children from lower-middle income communities (100.1 visits per 10,000 children) and lowest among children from upper-middle income communities (94.1 visits per 10,000 children). The poorest and wealthiest communities had similar rates of ED visits in children for sports injuries (about 97 visits per 10,000 children). Rates of sports injury ED visits in children resulting in hospitalization were relatively constant regardless of community-level income (which ranged from 1.2 to 1.4 visits per 10,000 children).

### Most common reasons for treat-and-release ED visits for sports injuries in children, by gender

The majority of all ED visits in children for sports-related injuries result in the child being treated-and-released from the ED. Table 2 presents the top five reasons for treat-and-release ED visits for sports injuries among both boys and girls: superficial injury (contusion), sprains and strains, arm fracture, open wounds of the head, neck, and trunk, and other injuries due to external factors. These five conditions collectively accounted for about 81 percent of all ED visits for sports injuries in children and rarely resulted in admission to the hospital. The number of ED visits for boys for these conditions were two to five times greater than for girls.

Table 2 Top 5 most common reasons for [underlined: treat-and-release] ED visits for sports injuries in children^†^, in 25 study states, 2006^*^

Rank | First-listed/principal diagnosis | Number of visits | Number (percent) of visits that were treat- and-release | Number (percent) of visits that resulted in hospital admission
| Boys
1 | Superficial injury, contusion | 51,700 | 51,600 (99.8%) | 80 (0.2%)
2 | Sprains and strains | 43,700 | 43,700 (99.9%) | 40 (0.1%)
3 | Fracture of upper limb (arm) | 42,000 | 41,500 (98.8%) | 500 (1.2%)
4 | Open wounds of head, neck, or trunk | 22,300 | 22,300 (99.9%) | 20 (0.1%)
5 | Other injuries and conditions due to external causes± | 19,500 | 19,400 (99.5%) | 90 (0.5%)
| Girls
1 | Superficial injury, contusion | 20,000 | 20,000 (100.0%) | **
2 | Sprains and strains | 19,000 | 19,000 (100.0%) | **
3 | Fracture of upper limb (arm) | 10,900 | 10,800 (99.5%) | 50 (0.5%)
4 | Other injuries and conditions due to external causes± | 6,900 | 6,900 (99.6%) | 30 (0.4%)
5 | Open wounds of head, neck, or trunk | 4,300 | 4,300 (100.0%) | **

† Patients aged 5 to 17 years.

* Reasons for treat-and-release visits were based on the first-listed diagnosis on the ED record; hospital-admitted cases were based on principal diagnosis on the inpatient record.

** Counts suppressed due to small cell size (less than 11).

± Other injuries include a mix of conditions not classified elsewhere, such as head injury, low blood oxygen, and heat stroke.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), State Emergency Department Databases (SEDD) and State Inpatient Databases (SID) for the following 25 states: Arizona, California, Connecticut, Florida, Georgia, Hawaii, Indiana, Iowa, Kansas, Maine, Maryland, Minnesota, Missouri, Nebraska, New Hampshire, New Jersey, New York, Ohio, Rhode Island, South Carolina, South Dakota, Tennessee, Utah, Vermont, and Wisconsin.

Superficial injury (contusion) was the single most common treat-and-release ED condition related to sports injury for boys and girls (51,700 and 20,000 visits, respectively). Sprains and strains were second most frequent (43,700 and 19,000 visits among boys and girls, respectively), followed by arm fracture (42,000 and 10,900 visits among boys and girls, respectively). The fourth most common sports-injury visit for boys was open wounds of the head, neck, or trunk. The gender difference was most striking for this condition for which boys accounted for more than 5 times as many ED visits than girls (22,300 compared to 4,300 visits, respectively). The fifth most common reason for treat-and-release ED visits related to sports injuries in children was a mix of other conditions and injuries not classified elsewhere (such as head injury, low blood oxygen, and heat stroke) accounting for a total of 26,400 treat-and-release ED visits in children in 2006.

### Most common reasons for ED visits for sports injuries in children that resulted in a hospital stay, by gender

While the majority of ED visits in children for sports injuries were treat-and-release cases, about 1.3 percent (3,900 ED visits in the 25 study states) resulted in hospital admission. Table 3 presents the top five sports-related injury conditions for which children were admitted to the hospital after being seen in the ED: leg fracture, arm fracture (also a top listed condition for treat-and-release ED visits), intracranial injury, crushing injury, and skull and face fractures. These five conditions collectively accounted for 28.7 percent of all sports injury ED visits in children. On average, about 4 percent of these conditions seen in the ED resulted in hospitalization among children. Across all five conditions, boys were more frequently hospitalized than girls.

Table 3 Top 5 most common reasons for ED visits that [underlined: resulted in a hospital stay] for sports injuries in children^†^, in 25 study states, 2006^*^

Rank | First-listed/principal CCS diagnosis | Number of visits for this condition | Number (percent) of visits for this condition that were treat-and-release | Number (percent) of visits that resulted in hospital admission
| Boys
1 | Fracture of lower limb (leg) | 9,300 | 8,200 (88.0%) | 1,100 (12.0%)
2 | Fracture of upper limb (arm) | 42,000 | 41,500 (98.8%) | 500 (1.2%)
3 | Intracranial injury | 10,200 | 9,700 (95.2%) | 500 (4.8%)
4 | Crushing injury or internal injury | 900 | 400 (45.2%) | 500 (54.8%)
5 | Skull and face fractures | 5,200 | 5,000 (96.7%) | 200 (3.3%)
| Girls
1 | Fracture of lower limb (leg) | 2,300 | 2,100 (93.3%) | 200 (6.7%)
2 | Intracranial injury | 2,500 | 2,400 (95.7%) | 100 (4.3%)
3 | Fracture of upper limb (arm) | 10,900 | 10,800 (99.5%) | 50 (0.5%)
4 | Crushing injury or internal injury | 140 | 100 (68.3%) | 40 (31.7%)
5 | Skull and face fractures | 1,900 | 1,900 (98.5%) | 30 (1.5%)

† Patients aged 5 to 17 years.

* Reasons for treat-and-release visits were based on the first-listed diagnosis on the ED record; hospital-admitted cases were based on principal diagnosis on the inpatient record.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), State Emergency Department Databases (SEDD) and State Inpatient Databases (SID) for the following 25 states: Arizona, California, Connecticut, Florida, Georgia, Hawaii, Indiana, Iowa, Kansas, Maine, Maryland, Minnesota, Missouri, Nebraska, New Hampshire, New Jersey, New York, Ohio, Rhode Island, South Carolina, South Dakota, Tennessee, Utah, Vermont, and Wisconsin.

Leg and arm fractures were among the most common reasons for sports injury ED visits that resulted in hospital admission, collectively (across boys and girls) accounting for 1,900 admissions from the ED, respectively. ED visits for leg fracture resulted in hospital admission 10 times more frequently compared to visits for arm fracture (10.9 percent versus 1.1 percent, respectively). A significantly greater proportion of boys who initially presented to the ED with a sports-related leg or arm fracture were admitted to the hospital compared to girls with the same conditions.

While crushing or internal injury was seen less frequently in the ED than other injuries, it resulted in hospitalization in more than half the ED visits (51.8 percent). A substantially greater proportion of boys who initially presented to the ED with a sports-related crushing or internal injury were hospitalized for treatment compared to girls (54.8 versus 31.7 percent, respectively).

The two remaining top five conditions for sports injury ED visits in children that resulted in a hospital stay, intracranial injury and skull and face fractures, each resulted in hospital admission in less than 5 percent of cases. The rate of hospital admission for intracranial injury was similar between genders (about 4.5 percent), while the rate for skull and face fractures was more than twice as high in boys (3.3 percent versus 1.5 percent).

## Data Source

The estimates in this Statistical Brief are based upon data from the HCUP 2006 State Emergency Department Databases (SEDD) and 2006 State Inpatient Databases (SID) for the following 25 states: Arizona, California, Connecticut, Florida, Georgia, Hawaii, Indiana, Iowa, Kansas, Maine, Maryland, Minnesota, Missouri, Nebraska, New Hampshire, New Jersey, New York, Ohio, Rhode Island, South Carolina, South Dakota, Tennessee, Utah, Vermont, and Wisconsin. 2006 Claritas data are used for population denominators.

## Definitions

### Case Definition

For this report, the Clinical Classification Software (CCS) codes defining sports injuries included the following External Cause of Injury Codes (commonly referred to as E-codes):

E886.0 Tackles in sports that cause fall on same level from collision
E917.0 Striking against or struck accidentally by objects or persons in sports without subsequent fall
E917.5 Striking against or struck accidentally by objects or persons in sports with subsequent fall

#### ED visits

ED visits included information on all visits to hospital-affiliated emergency rooms for children aged 5 to 17 years of age in the 25 study states regardless of whether the child was treated-and-released from that ED or admitted to that hospital from the ED. This information was obtained by combining the State Emergency Department Databases (SEDD) with the State Inpatient Databases (SID) to get a complete enumeration of hospital-based ED visits within each participating state.

#### Treat-and-release ED visits

Treat-and-release ED visits were those ED visits in which children were treated and released from that ED— i.e., they were not admitted to that specific hospital. Information on treat-and-release cases is included in the State Emergency Department Databases (SEDD).

#### ED visits resulting in a hospital stay

ED visits resulting in a hospital stay included those children initially seen in the ED and then admitted to the same hospital. This information is included in the State Inpatient Databases (SID).

### Diagnoses, ICD-9-CM, and Clinical Classifications Software (CCS)

ICD-9-CM is the International Classification of Diseases, Ninth Revision, Clinical Modification, which assigns numeric codes to diagnoses. There are about 13,600 ICD-9-CM diagnosis codes. E-codes supplement the ICD-9-CM diagnosis codes. These codes designate the cause of injury. Multiple E-codes may be present on a single hospital record.

CCS categorizes ICD-9-CM diagnosis and procedure codes into clinically meaningful categories.^6^ This “clinical grouper” makes it easier to quickly understand patterns of procedure use.

For ED hospital records that were treat-and-release cases, this Brief reports the first-listed CCS diagnosis which is the diagnosis that appears first on the record and may not be the principal diagnosis. For ED visits that result in hospital admission, this Brief reports the principal CCS diagnosis that appears on the inpatient hospital record. The principal CCS diagnosis is that condition established after study to be chiefly responsible for admission to the hospital.

### Types of hospitals included in HCUP

HCUP is based on data from community hospitals, defined as short-term, non-Federal, general and other hospitals, excluding hospital units of other institutions (e.g., prisons). HCUP data include OB-GYN, ENT, orthopedic, cancer, pediatric, public, and academic medical hospitals. They exclude long-term care, rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals, but these types of discharges are included if they are from community hospitals.

### Unit of analysis

The unit of analysis is the ED visit or hospital discharge (i.e., the hospital stay), not a person or patient. This means that children visiting the ED multiple times in one year will be counted each time as a separate case. Multiple ED visits by children is not uncommon; thus, rates presented in this brief must be interpreted with caution. The numerator for the rates is “number of ED visits,” and one child may have several visits to the ED in a given year; thus, the rates should be interpreted as the rate of “visits” or “rate of hospitalizations” rather than the “rate of children” being seen in the ED or admitted to the hospital from the ED. Denominator data for rates were based on 2006 Claritas data for the 25 study states.

### Urban-rural patient residence

Urban-rural patient residence is a four category urban-rural designation for the patient’s county of residence. The categorization is a simplified adaptation of the 2003 version of the Urban Influence Codes (UIC). The 12 categories of the UIC are combined into four broader categories that differentiate between large and small metropolitan, micropolitan (large town rural), and a non-metropolitan/non-micropolitan (remote rural) residual.

### Median community-level income

Median community-level income is the median household income of the patient’s ZIP Code of residence. The cut-offs for the quartile designation are determined using ZIP Code demographic data obtained from Claritas. The income quartile value is missing for homeless and foreign patients.

## For More Information

For more information about HCUP, visit www.hcup-us.ahrq.gov.

For additional HCUP statistics, visit HCUPnet, our interactive query system, at www.hcup.ahrq.gov.

For information on other hospitalizations in the U.S., download HCUP Facts and Figures: Statistics on Hospital-based Care in the United States in 2006, located at http://www.hcup-us.ahrq.gov/reports.jsp.

For a detailed description of HCUP and more information on the SEDD please refer to the following publications:

Steiner, C., Elixhauser, A., Schnaier, J. The Healthcare Cost and Utilization Project: An Overview. Effective Clinical Practice 5(3):143–51, 2002.

Introduction to the HCUP State Emergency Department Databases (SEDD). Online. December 2007. U.S. Agency for Healthcare Research and Quality. http://www.hcup-us.ahrq.gov/db/state/sedddist/Introduction_to_SEDD.pdf.

1 Pitts SR, Niska RW, Xu J, Burt CW. National Hospital Ambulatory Medical Care Survey: 2006 Emergency Department Summary. Advance data from vital and health statistics; no. 386. Hyattsville, MD: National Center for Health Statistics. 2008.

2 Centers for Disease Control and Prevention Morbidity and Mortality Weekly Report: Non-fatal sports- and recreation-related injuries treated in emergency departments, United States, July 2000–June 2001. MMWR Weekly. 2002;51(33):736–739.

3 Burt CW, Overpck MD. Emergency visits for sports-related injuries. Annals of Emergency Medicine. 2001; 37(3):301–308.

4 Simon TD, Bublitz C, Hambidge SJ. Emergency department visits among pediatric patients for sports-related injury: basic epidemiology and impact of race/ethnicity and insurance status. Pediatric Emergency Medicine. 2006; 22(5):309–305.

5 Pate RR, Trost SG, Levin S, Dowda M. Sports participation and health-related behaviors among U.S. youth. Archives of Pediatric Adolescent Medicine. 2000;154:904–911.

6 HCUP CCS. Healthcare Cost and Utilization Project (HCUP), May 2008. U.S. Agency for Healthcare Research and Quality, Rockville, MD. www.hcup-us.ahrq.gov/toolssoftware/ccs/ccs.jsp.