# Statistical Brief #68 Hospitalizations for Brain Cancer, 2006

## Introduction

Each year, an estimated 51,400 Americans are diagnosed with a brain tumor in the United States. About 40 percent of these brain tumors are malignant.^1^ Cancerous brain tumors can grow rapidly and the effects can be debilitating, including memory loss, emotional disturbances, speech difficulties, seizures, paralysis, and death. 2 Even though this form of cancer is generally difficult to cure, the five- and ten-year survival rates for brain cancer have continually improved over the past ten years. 3,4

This Statistical Brief presents data from the Healthcare Cost and Utilization Project (HCUP) on stays related to brain cancer, or malignant brain tumors, in U.S. commu nity hospitals in 2006. Characteristics of stays for brain cancer are compared to all hospital stays, excluding newborns and maternal stays for childbirth. Differences by age, gender, payer, and region are also investigated for principal and secondary brain cancer diagnoses. In addition, common principal diagnoses for brain cancer-related stays are outlined. All differences between estimates noted in the text are statistically significant at the 0.05 level or better.

## Findings

Highlights

- There were nearly 73,500 hospitalizations related to brain cancer in 2006, or nearly 24.6 stays per 100,000 population.
- Between 1995 and 2006, the rate of hospitalizations principally for brain cancer remained stable, but the rate with brain cancer as a secondary diagnosis increased over 18 percent.
- Deaths in the hospital due to brain cancer have decreased by nearly one-third since 1995, from 6.2 percent to 4.4 percent.
- The rate of brain cancer-related hospitalization increased dramatically with age; men over 65 had the highest rates of hospitalization for brain cancer.
- The Northeast had the highest rates of hospitalization related to brain cancer.
- About 55 percent of all brain cancer-related hospitalizations had some form of cancer or cancer therapy as the principal reason for admission. Many of the remaining cases were admitted for treatment of conditions that are likely sequelae of cancer and its treatment.
- Compared with adults, children have lower hospitalization rates for frontal, temporal, parietal, and occipital lobe tumors and higher rates for cerebellar and brain stem tumors.

In 2006, there were nearly 73,500 hospitalizations involving brain cancer in the U.S., a rate of about 24.6 hospitalizations per 100,000 population. Slightly fewer than half of these stays (35,200 hospitalizations) were principally for brain cancer and totaled approximately $655.5 million in hospital costs. Nearly 38,300 hospitalizations cited brain cancer as a secondary diagnosis.

As shown in figure 1, the overall rate of brain cancer hospitalizations increased slightly between 1995 and 2006. As a principal diagnosis, the rate has remained stable. However, as a secondary condition, the rate has increased over 18 percent, from 10.8 stays per 100,000 population to 12.8 stays per 100,000 population. The greatest number of stays occurred in 2005, when there was a substantial increase in all hospitalizations involving a brain cancer diagnosis, particularly those as a secondary diagnosis.^5^

Figure 1 Between 1995 and 2006, the rate of stays principally for brain cancer remained relatively stable, yet increased as a secondary diagnosis by 18 percent

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, HCUPnet, Nationwide Inpatient Sample, 2006

### General characteristics

Table 1 presents general characteristics of brain cancer hospitalizations in 2006. Compared with all other hospitalizations (excluding newborns and maternal stays for childbirth), the mean length of stay for hospitalizations principally for brain cancer was nearly 2 days longer (6.9 days versus 5.1 days). For hospitalizations with a secondary diagnosis of brain cancer, the average length of stay was also longer than for all stays—6.4 days. Though brain cancer-related stays were longer, the average cost per day was dependent on the type of hospitalization. Stays principally for brain cancer were approximately $800 more costly than average ($2,700 versus $1,900), yet costs for secondary stays were no different from the average hospitalization ($1,800 versus $1,900).

Table 1 Characteristics of hospitalizations related to brain cancer compared to hospitalizations for all conditions, 2006

| Hospital stays principally for brain cancer | Hospital stays with a secondary diagnosis of a brain cancer | Hospital stays for all conditions^*^
Utilization characteristics
Total number of hospitalizations | 35,200 | 38,300 | 30,142,300
Mean length of stay, days | 6.9 | 6.4 | 5.1
Mean cost per hospitalization | $18,700 | $11,300 | $9,900
Mean cost per day | $2,700 | $1,800 | $1,900
Aggregate costs | $655.5 million | $433.5 million | $297.6 billion
Percentage admitted through the Emergency Department | 35.1% | 46.0% | 55.7%
Percentage died in hospital | 4.4% | 4.1% | 2.6%
Expected primary payer:
Private Insurance | 50.5% | 46.0% | 29.5%
Medicare | 31.5% | 34.2% | 48.7%
Medicaid | 10.9% | 15.3% | 12.3%
Uninsured | 3.5% | 2.1% | 5.8%
Patient characteristics
Percentage by age group:
Younger than 18 years | 10.0% | 19.2% | 6.5%
18 to 44 years | 20.5% | 18.9% | 18.5%
45 to 64 years | 39.0% | 34.5% | 30.2%
65 years and older | 30.2% | 26.7% | 44.7%
Percentage of male patients | 55.7% | 54.2% | 46.4%

* Hospital stays for newborns and maternal childbirth have been excluded.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2006

Patients principally admitted for brain cancer were substantially less likely to be admitted from the emergency department than the average hospitalization (35.1 percent versus 55.7 percent). Furthermore, brain cancer patients were more likely to die in the hospital than the average patient (4.4 percent versus 2.6 percent). Over time there has been a decline in deaths in the hospital for patients admitted for brain cancer—deaths decreased by nearly one-third from 1995 to 2006 for brain cancer hospitalizations, from 6.2 percent to 4.4 percent (not shown).

Private insurance was the primary payer for nearly half of all brain cancer-related stays (50.5 percent of principal stays, and 46.0 percent of secondary stays), followed by Medicare, which covered about a third of stays. This varied from the average hospitalization, in which Medicare was the payer for nearly half of all stays and private insurance covered one-third. Uninsured patients accounted for a smaller percentage of brain cancer-related stays than the average hospitalization (3.5 percent of principal stays and 2.1 percent of secondary stays compared with 5.8 percent uninsured among all stays).

### Brain cancer hospitalizations, by age and gender

The overall rate of brain cancer-related hospitalizations increased with patient age (table 1 and figure 2). Patients 45 years and older accounted for nearly two-thirds of all brain cancer-related hospitalizations, but the highest rates of hospitalization occurred among patients 65 and older (28.5 stays per 100,000 population for principal brain cancer and 27.5 stays per 100,000 population for those with the disease as a secondary diagnosis). Patients 45 and older were hospitalized slightly more often with brain cancer noted as the principal diagnosis. On the other hand, patients younger than 18 were hospitalized twice as often for secondary brain cancer—4.8 stays per 100,000 population for principal brain cancer versus 9.8 stays per 100,000 population for brain cancer as a secondary diagnosis—possibly indicating follow-up treatment for other conditions associated with brain cancer.

Figure 2 The rate of brain cancer-related hospitalizations increases with age, 2006

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, HCUPnet, Nationwide Inpatient Sample, 2006

Overall, brain cancer-related hospitalizations occurred more often among males than females. Males accounted for 55.7 percent of hospitalizations principally for brain cancer and 54.2 percent of stays with a secondary diagnosis of brain cancer (table 1). Figure 3 provides the rates of hospitalization for brain cancer by age and gender. While males had slightly higher rates of brain cancer-related hospitalizations than females among patients younger than 45 years old, the difference between males and females was much higher among patients 45 years and older. In fact, the rate of brain cancer hospitalizations was highest among men over the age of 65, with 36.6 stays per 100,000 population for principal brain cancer hospitalizations (62 percent higher than females) and 34.5 stays per 100,000 population for stays with a secondary brain cancer diagnosis (55 percent higher than females).

Figure 3 The rate of brain cancer-related hospitalizations was highest among men age 65 and older, 2006

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, HCUPnet, Nationwide Inpatient Sample, 2006

### Brain cancer hospitalizations, by region

As shown in Figure 4, hospitalizations with a brain cancer diagnosis occurred more frequently in the Northeast than any other region—30.1 stays per 100,000 population. As a principal diagnosis, there were 13.0 stays per 100,000 population in the Northeast, and 17.1 stays per 100,000 population with a secondary diagnosis of a brain cancer.

Figure 4 Overall, the Northeast had the highest rate of brain cancer stays, and the West and South had the lowest, 2006

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, HCUPnet, Nationwide Inpatient Sample, 2006

Overall, the South and West had the lowest rates of all brain cancer hospitalizations, each with nearly 23 stays per 100,000 population. When viewed by type of diagnosis, however, the rate of hospitalization varied: the Midwest had the lowest rate of stays for brain cancer as a principal diagnosis, and the West had the lowest rate for secondary diagnoses of brain cancer—each with 10.7 stays per 100,000 population.

### Specific locations of brain cancers

Table 2 shows the percentage of hospital stays for brain cancer by the specific location of the tumor for various age groups, based on a principal diagnosis of brain cancer. Compared with adults, children younger than 18 years have lower hospitalization rates for supratentorial tumors, or tumors in the upper brain (i.e., cerebrum, frontal, temporal, parietal, and occipital lobe tumors) and higher rates for infratentorial tumors, or tumors in the lower brain (cerebellar and brain stem). In general, frontal lobe tumor hospitalizations decrease with age while temporal and parietal lobe tumor hospital stays increase with age.

Table 2 Hospitalization rates for specific types of brain cancer by age group, 2006^*^

Brain cancer type^*^ | Stays per 100,000 population
Brain cancer type^*^ | <18 years | 18–44 years | 45–64 years | 65+ years
Supratentorial
Cerebrum | 7.6 | 3.6 | 2.9 | 2.9
Frontal lobe | 7.5 | 33.5 | 28.2 | 23.2
Temporal lobe | 5.0 | 14.6 | 17.9 | 20.7
Parietal lobe | 3.2 | 8.9 | 14.1 | 16.7
Occipital lobe | 1.4 | 2.2 | 3.5 | 4.0
Infratentorial
Cerebellum | 16.7 | 5.1 | 1.3 | 1.2
Brain stem | 11.4 | 2.7 | 1.2 | 1.2
Spinal cord | 3.5 | 3.0 | 1.9 | 0.8
Ventricles | 11.4 | 2.1 | 1.3 | 0.0
Unspecified | 16.9 | 9.5 | 11.7 | 12.1

* Brain cancer is the principal diagnosis.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2006 and Kids’ Inpatient Database, 2006

### Principal diagnoses for brain cancer-related hospitalizations

Less than half (47.9 percent) of all hospitalizations related to brain cancer had the diagnosis as the principal reason for the hospitalization. More often, another condition was listed as the principal reason for admission. Table 3 lists the top 20 principal diagnoses for all brain cancer-related hospitalizations. About 55 percent of all hospitalizations related to brain cancer had a form of cancer or cancer therapy as a principal diagnosis, including brain and nervous system cancer (47.9 percent), maintenance chemotherapy and radiotherapy (6.0 percent), secondary malignancies (1.0 percent), and other cancers (0.9 percent)—lung, leukemia, kidney, breast, and other forms.

Table 3 Top 20 principal diagnoses among all brain cancer-related hospitalizations, 2006

Rank | Principal diagnosis | Number of stays | Percentage of all brain cancer hospitalizations
1 | Brain and nervous system cancers | 35,200 | 47.9%
2 | Maintenance chemotherapy, radiotherapy | 4,400 | 6.0%
3 | Rehabilitation care, fitting of prostheses, and adjustment of devices | 3,100 | 4.3%
4 | Epilepsy, convulsions | 2,900 | 4.0%
5 | Pneumonia | 1,400 | 1.9%
6 | Complication of device, implant or graft | 1,300 | 1.8%
7 | Complications of surgical procedures or medical care | 1,300 | 1.8%
8 | Acute cerebrovascular disease (stroke) | 1,200 | 1.7%
9 | Septicemia (except in labor) | 1,200 | 1.7%
10 | Disease of white blood cells | 1,100 | 1.5%
11 | Phlebitis, thrombophlebitis, and thromboembolism | 1,000 | 1.4%
12 | Fluid and electrolyte disorders | 1,000 | 1.3%
13 | Other nervous system disorders | 900 | 1.3%
14 | Pulmonary heart disease | 900 | 1.2%
15 | Secondary malignancies | 800 | 1.0%
16 | Other cancers | 700 | 0.9%
17 | Urinary tract infections | 600 | 0.8%
18 | Other hereditary and degenerative nervous system conditions | 600 | 0.8%
19 | Aspiration pneumonitis, food/vomitus | 600 | 0.8%
20 | Respiratory failure, insufficiency, arrest (adult) | 600 | 0.8%

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2006

Other disorders affecting the nervous system were also common principal diagnoses among hospitalizations related to brain cancer. Epilepsy and convulsions accounted for 4.0 percent of stays, followed by other nervous system disorders (1.3 percent) and other hereditary and degenerative nervous system conditions (0.8 percent). Acute cerebrovascular disease, or stroke, was the principal diagnosis for 1.7 percent of brain cancer-related stays. Other conditions reflect the severity of illness for these patients—pneumonia, septicemia, pulmonary heart disease, aspiration pneumonitis, and respiratory failure. Over three percent of brain cancer patients experienced some complication of medical care.

## Data Source

The estimates in this Statistical Brief are based upon data from the HCUP 2006 Nationwide Inpatient Sample (NIS) and the 2006 Kids Inpatient Database (KID). Historical data were drawn from the 1994, 1995, 1996, 1997, 1998, 1999, 2000, 2001, 2002, 2003, 2004, and 2005 NIS. The statistics were generated from HCUPnet, a free, online query system that provides users with immediate access to largest set of publicly available, all-payer national, regional, and State-level hospital care databases from HCUP. Supplemental sources included data from the U.S. Census Bureau, Population Division, Annual Estimates of the Population for the United States, Regions, and Divisions and U.S. Census Bureau, Current Population Reports, P60–226, Coverage by Type of Health Insurance.

## Definitions

### Diagnoses, ICD-9-CM, and Clinical Classifications Software (CCS)

The principal diagnosis is that condition established after study to be chiefly responsible for the patient’s admission to the hospital. Secondary diagnoses are concomitant conditions that coexist at the time of admission or that develop during the stay.

ICD-9-CM is the International Classification of Diseases, Ninth Revision, Clinical Modification, which assigns numeric codes to diagnoses. There are about 13,600 ICD-9-CM diagnosis codes.

CCS categorizes ICD-9-CM diagnoses into a manageable number of clinically meaningful categories.^6^ This “clinical grouper” makes it easier to quickly understand patterns of diagnoses and procedures.

### Case Definition

For this report, Brain Cancer diagnoses were defined as CCS diagnosis:

– 35: Cancer of Brain and Nervous System

### Types of hospitals included in HCUP

HCUP is based on data from community hospitals, defined as short-term, non-Federal, general and other hospitals, excluding hospital units of other institutions (e.g., prisons). HCUP data include OB-GYN, ENT, orthopedic, cancer, pediatric, public, and academic medical hospitals. They exclude long-term care, rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals, but these types of discharges are included if they are from community hospitals.

### Unit of analysis

The unit of analysis is the hospital discharge (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the hospital multiple times in one year will be counted each time as a separate “discharge” from the hospital.

### Costs and charges

Total hospital charges were converted to costs using HCUP Cost-to-Charge Ratios based on hospital accounting reports from the Centers for Medicare and Medicaid Services (CMS).^7^ Costs will tend to reflect the actual costs of production, while charges represent what the hospital billed for the case. For each hospital, a hospital-wide cost-to-charge ratio is used because detailed charges are not available across all HCUP States. Hospital charges reflect the amount the hospital charged for the entire hospital stay and does not include professional (physician) fees. For the purposes of this Statistical Brief, costs are reported to the nearest hundred.

### Payer

Payer is the expected primary payer for the hospital stay. To make coding uniform across all HCUP data sources, payer combines detailed categories into more general groups:

– Medicare includes fee-for-service and managed care Medicare patients.
– Medicaid includes fee-for-service and managed care Medicaid patients. Patients covered by the State Children’s Health Insurance Program (SCHIP) may be included here. Because most state data do not identify SCHIP patients specifically, it is not possible to present this information separately.
– Private insurance includes Blue Cross, commercial carriers, and private HMOs and PPOs.
– Other includes Worker’s Compensation, TRICARE/CHAMPUS, CHAMPVA, Title V, and other government programs.
– Uninsured includes an insurance status of “self-pay” and “no charge.”

When more than one payer is listed for a hospital discharge, the first-listed payer is used.

### Region

Region is one of the four regions defined by the U.S. Census Bureau:

– Northeast: Maine, New Hampshire, Vermont, Massachusetts, Rhode Island, Connecticut, New York, New Jersey, and Pennsylvania
– Midwest: Ohio, Indiana, Illinois, Michigan, Wisconsin, Minnesota, Iowa, Missouri, North Dakota, South Dakota, Nebraska, and Kansas
– South: Delaware, Maryland, District of Columbia, Virginia, West Virginia, North Carolina, South Carolina, Georgia, Florida, Kentucky, Tennessee, Alabama, Mississippi, Arkansas, Louisiana, Oklahoma, and Texas
– West: Montana, Idaho, Wyoming, Colorado, New Mexico, Arizona, Utah, Nevada, Washington, Oregon, California, Alaska, and Hawaii

### Admission source

Admission source indicates where the patient was located prior to admission to the hospital. Emergency admission indicates the patient was admitted to the hospital through the emergency department. Admission from another hospital indicates the patient was admitted to this hospital from another short-term, acute-care hospital. This usually signifies that the patient required the transfer in order to obtain more specialized services that the originating hospital could not provide. Admission from long-term care facility indicates the patient was admitted from a long-term facility such as a nursing home.

### Discharge status

Discharge status indicates the disposition of the patient at discharge from the hospital, and includes the following six categories: routine (to home), transfer to another short-term hospital, other transfers (including skilled nursing facility, intermediate care, and another type of facility such as a nursing home), home health care, against medical advice (AMA), or died in the hospital.

## For More Information

For a detailed description of HCUP, please refer to the following publication:

Steiner, C., Elixhauser, A., Schnaier, J. The Healthcare Cost and Utilization Project: An Overview. Effective Clinical Practice 5(3):143–51, 2002.

1 Statistical Report: Primary Brain Tumors in the United States, 2000–2004. Central Brain Tumor Registry of the United States. Hinsdale, IL. 2008. http://www.cbtrus.org/reports/reports.html (Accessed 2/6/2009).

2 What You Need to Know About Brain Tumors. National Cancer Institute. Bethesda, MD. 2003. http://www.cancer.gov/cancertopics/wyntk/brain/ (Accessed 2/6/2009).

3 Brain Tumor—Adults. Medline Plus. National Library of Medicine, National Institutes of Medicine, 2009. http://www.nlm.nih.gov/medlineplus (Accessed 2/19/2009).

4 Ries LAG, Melbert D, Krapcho M, Stinchcomb DG, Howlader N, Horner MJ, Mariotto A, Miller BA, Feuer EJ, Altekruse SF, Lewis DR, Clegg L, Eisner MP, Reichman M, Edwards BK (eds). SEER Cancer Statistics Review, 1975–2005, National Cancer Institute. Bethesda, MD. http://seer.cancer.gov/ (Accessed 2/6/2009).

5 While it is not known what caused this increase, the spike in hospital admissions in 2005 is corroborated by the National Hospital Discharge Survey (NHDS), a survey of hospital stays based on a different sampling strategy from the data used in this report.

6 HCUP CCS. Healthcare Cost and Utilization Project (HCUP). May 2008. U.S. Agency for Healthcare Research and Quality, Rockville, MD. www.hcup-us.ahrq.gov/toolssoftware/ccs/ccs.jsp

7 HCUP Cost-to-Charge Ratio Files (CCR). Healthcare Cost and Utilization Project (HCUP). 2001–2006. U.S. Agency for Healthcare Research and Quality, Rockville, MD. www.hcup-us.ahrq.gov/db/state/costtocharge.jsp