# Statistical Brief #33 Reasons for Being Admitted to the Hospital through the Emergency Department for Children and Adolescents, 2004

## Introduction

In 2004, over 1 million children and adolescents entered the hospital through the emergency department (ED), accounting for roughly half of all pediatric hospital stays (excluding births and adolescent pregnancy cases).^1^ Understanding the reasons why children and adolescents are admitted to the hospital from the ED can help identify conditions for which emergency utilization potentially could be avoided if adequate primary care were available. Examining admissions through the ED is critical to addressing problems of potential overcrowding in the ED, increased costs associated with emergency care, and problems in quality of and access to primary care.

This Statistical Brief presents data from the Healthcare Cost and Utilization Project (HCUP) on the most common reasons for hospitalizations that began in the ED for patients under 18 years of age and compares these pediatric stays with similar stays for adults. All differences between estimates noted in the text are statistically significant at the 0.05 level or better.

This brief is the second report of a two-part series on pediatric stays that began in the ED. General information on utilization and cost characteristics of pediatric hospital admissions that began in ED is presented in Statistical Brief #32.^2^

## Findings

Highlights

- Among children and adolescents, respiratory disorders were the most frequent reason for admission to the hospital through the ED, accounting for 27.8 percent of all such admissions.
- Asthma was the single most common reason for hospital stays that began in the ED with over 95,000 hospital admissions (accounting for 8.5 percent of all pediatric admissions through the ED).
- For the youngest children (age 0 to 4), respiratory conditions —mainly acute bronchitis, pneumonia, and asthma—comprised about 40 percent of stays that began in the ED.
- Injuries first treated in the ED that resulted in admission to the hospital increased with age among children and adolescents. About 4 percent of children under 1 were admitted through the ED compared with about 30 percent of 15 to 17 year olds.

In 2004, children and adolescents under 18 years of age accounted for 17.3 percent (6.7 million) of the 38.7 million total hospital stays. Two-thirds of pediatric hospitalizations were related to either births or maternal care. Excluding these cases, nearly half of the remaining pediatric stays (1.1 million hospitalizations) were admitted through the ED. Children and adolescents were often seen in the ED and subsequently admitted to the hospital for acute or preventable conditions, such as asthma or injury.

### Reasons for admission to the hospital through the ED for children and adolescents

Figure 1 shows the reasons for child and adolescent hospital admissions from the ED compared with adults, organized by body system. Respiratory disorders accounted for 27.8 percent of all pediatric admissions through the ED. Injuries and digestive disorders were the next most common category of conditions, comprising 16.6 percent and 14.2 percent, respectively, of all pediatric admissions through the ED. Endocrine and nervous system conditions each constituted about 7 percent of admissions. Mental health and substance abuse (MHSA) disorders comprised 5.1 percent of pediatric stays that began in the ED.

Figure 1 Reasons for hospitalizations admitted through the emergency department, by body system and age group, 2004*

*Based on principal diagnosis; excludes births and maternal cases.

Note: All other disorders include: infections, perinatal conditions, skin disorders, blood disorders, congenital disorders, musculoskeletal disorders, and neoplasms.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2004.

Table 1 presents the 20 most frequent specific conditions for which children and adolescents were admitted to the hospital through the ED. These 20 conditions accounted for about two-thirds of all pediatric admissions through the ED. Asthma was the single most common condition with over 95,000 admissions (accounting for 8.5 percent of all pediatric admissions through the ED). This was followed by two conditions also related to the respiratory system—pneumonia and acute bronchitis. These top three conditions accounted for nearly one-quarter of all pediatric admissions through the ED. Appendicitis and fluid/electrolyte disorders ranked 4th and 5th with 64,200 and 53,300, respectively, hospital admissions originating from the ED. Other top 20 conditions included mood disorders (ranked 8th), fractures of the leg and arm (ranked 11th and 12th), and brain injury (ranked 13th).

Table 1 Top 20 most common reasons for admission to the ED for children and adolescents, 2004^*^

Rank | Condition (CCS code) | Number of admissions through the ED | Percentage of all admissions through the ED
1 | Asthma | 95,400 | 8.5
2 | Pneumonia | 83,200 | 7.4
3 | Acute bronchitis | 75,900 | 6.8
4 | Appendicitis | 64,200 | 5.7
5 | Fluid and electrolyte disorders | 53,300 | 4.8
6 | Epilepsy, convulsions | 35,100 | 3.1
7 | Urinary tract infections | 31,500 | 2.8
8 | Mood disorders (depression and bipolar disorder) | 29,000 | 2.6
9 | Intestinal infection | 27,200 | 2.4
10 | Skin and subcutaneous tissue infections | 27,100 | 2.4
11 | Fracture of leg | 24,600 | 2.2
12 | Fracture of arm | 24,400 | 2.2
13 | Brain injury | 23,600 | 2.1
14 | Other infections of upper respiratory tract (nose, throat, trachea) | 23,500 | 2.1
15 | Other conditions occurring around the time of birth | 22,600 | 2.0
16 | Viral infections | 22,100 | 2.0
17 | Meningitis | 20,800 | 1.8
18 | Inflammation of stomach and intestines (noninfectious gastroenteritis) | 20,300 | 1.8
19 | Fever of unknown origin | 18,400 | 1.6
20 | Diabetes mellitus with complications | 15,800 | 1.4
Top 20 most frequent conditions admitted through the ED | | 738,000 | 65.9%
All other conditions admitted through the ED | | 381,200 | 34.1%
Total admissions through the ED for children and adolescents | | 1,119,200 | 100%

* Includes individuals under 18 years of age and excludes births and maternal cases.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2004.

### Reasons for admission to the hospital through the ED, by pediatric age groupings

The reasons why children and adolescents were admitted through the ED varied by age group (figure 2 and table 2). For the youngest children (0 to 4 years), respiratory conditions—mainly acute bronchitis, pneumonia, and asthma—comprised about 40 percent of stays that began in the ED. This percentage dropped to 25.6 percent for 5 to 9 year olds and declined even further for 10 to 14 year olds (12.0 percent) and 15 to 17 year olds (7.9 percent).

Figure 2 Reasons for hospitalizations admitted through the emergency department, by body system and pediatric age group, 2004*

*Based on principal diagnosis; excludes births and maternal cases.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2004.

Table 2 Top five specific conditions that resulted in admission to the hospital from the ED for children and adolescents, by age group, 2004^*^

Age Groups
Under 1 year | | 1–4 years | | 5–9 years | | 10–14 years | | 15–17 years
Condition (CCS Code) | Number of admissions through the ED (percent) | Condition (CCS Code) | Number of admissions through the ED (percent) | Condition (CCS Code) | Number of admissions through the ED (percent) | Condition (CCS Code) | Number of admissions through the ED (percent) | Condition (CCS Code) | Number of admissions through the ED (percent)
Acute bronchitis | 57,900 (21.4) | Asthma | 44,000 (15.1%) | Asthma | 24,800 (13.7%) | Appendicitis | 27,000 (14.0%) | Appendicitis | 17,300 (9.4%)
Other conditions occurring around the time of birth | 22,500 (8.3) | Pneumonia | 39,600 (13.6%) | Appendicitis | 16,800 (9.3%) | Asthma | 13,100 (6.8%) | Mood disorders (depression and bipolar disorder) | 15,100 (8.2%)
Pneumonia | 21,600 (8.0) | Fluid and electrolyte disorders | 29,000 (10.0%) | Pneumonia | 13,800 (7.6%) | Mood disorders (depression and bipolar disorder) | 11,700 (6.1%) | Brain injury | 7,900 (4.3%)
Urinary tract infections | 14,200 (5.2) | Acute bronchitis | 16,700 (5.7%) | Fracture of arm | 9,500 (5.2%) | Fracture of leg | 8,300 (4.3%) | Fracture of leg | 7,300 (4.0%)
Fluid and electrolyte disorders | 12,600 (4.7) | Epilepsy, convulsions | 15,400 (5.3%) | Fluid and electrolyte disorders | 7,100 (3.9%) | Diabetes mellitus with complications | 6,700 (3.5%) | Poisoning by other medications and drugs | 7,000 (3.8%)

* Includes individuals under 18 years of age and excludes births and maternal cases.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2004.

For children under one year of age, acute bronchitis was the single most common reason for admission accounting for over 1 in 5 admissions from the ED. For 1 to 4 and 5 to 9 year olds, asthma was the most common reason for admission with about 1 in 7 cases admitted through the ED. Asthma admissions from the ED decreased with age. For 10 to 14 year olds asthma accounted for 1 in 15 admissions and represented only 1 in 35 stays for 15 to 17 year olds (data not shown).

In contrast, admissions for injuries cases through the ED increased with age among children and adolescents—from 4.4 percent in children under 1 (data not shown) to 30.1 percent for 15 to 17 year olds. Stays for MHSA conditions that began in the ED also increased with age accounting for less than 1 percent of stays for children 1 to 4 years of age (data not shown) to over 15 percent for 15 to 17 year olds.

### Reasons for admission to the hospital through the ED, pediatric stays versus adult stays

Adults were admitted to the hospital from the ED for different reasons than children and adolescents (table 3). While respiratory conditions were largely responsible for such admissions in the pediatric population, adults were most frequently admitted for circulatory system disorders. Heart-related conditions, such as congestive heart failure, chest pain, hardening of the arteries, heart attack, stroke, and irregular heart beat, accounted for over a quarter (27.2 percent) of all adult stays that began in the ED among adults. This is most likely due to the chronic nature of many circulatory diseases that render them less common in the pediatric population. However, similar to younger patients, conditions of the digestive and respiratory systems, and injuries, accounted for a large portion of stays that originated in the ED among adults. One specific condition that was common in both adult and pediatric stays that began in the ED was pneumonia, which accounted for 5.2 percent of adults stays and 7.4 percent of pediatric stays.

Table 3 Top 20 most common reasons for admission to the ED for adults, 2004^*^

Rank | Condition (CCS code) | Number of admissions through the ED | Percentage of all cases admitted through the ED
1 | Congestive heart failure | 787,100 | 5.2
2 | Pneumonia | 785,700 | 5.2
3 | Chest pain | 685,900 | 4.5
4 | Hardening of the heart arteries and other heart disease | 482,900 | 3.2
5 | Heart attack (acute myocardial infarction) | 446,000 | 2.9
6 | Stroke (acute cerebrovascular disease) | 423,400 | 2.8
7 | Irregular heart beat (cardiac dysrhythmias) | 421,700 | 2.8
8 | Chronic obstructive lung disease | 391,900 | 2.6
9 | Urinary tract infection | 343,700 | 2.3
10 | Septicemia | 330,600 | 2.2
11 | Mood disorders (depression and bipolar disorder) | 316,600 | 2.1
12 | Diabetes mellitus with complications | 315,400 | 2.1
13 | Fluid and electrolyte disorders | 310,600 | 2.1
14 | Skin and subcutaneous tissue infections | 290,400 | 1.9
15 | Gall bladder disease | 268,300 | 1.8
16 | Gastrointestinal hemorrhage | 252,100 | 1.7
17 | Hip fracture | 240,700 | 1.6
18 | Pancreatic disorders | 221,400 | 1.5
19 | Intestinal obstruction without hernia | 220,000 | 1.5
20 | Fainting | 217,800 | 1.4
Top 20 most frequent conditions admitted through the ED | | 7,752,200 | 51.1%
All other conditions admitted through the ED | | 7,424,100 | 48.9%
Total admissions through the ED for adults | | 15,176,300 | 100%

* Includes individuals over 17 years of age and excludes maternal cases.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2004.

## Data Source

The estimates in this Statistical Brief are based on data from the HCUP 2004 Nationwide Inpatient Sample (NIS).

## Definitions

### Types of hospitals included in HCUP

HCUP is based on data from community hospitals, defined as short-term, non-Federal, general and other hospitals, excluding hospital units of other institutions (e.g., prisons). HCUP data include OB-GYN, ENT, orthopedic, cancer, pediatric, public, and academic medical hospitals. They exclude long-term care, rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals, but these types of discharges are included if they are from community hospitals.

### Unit of analysis

The unit of analysis is the hospital discharge (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the hospital multiple times in one year will be counted each time as a separate “discharge” from the hospital.

### Pediatric, neonatal, and maternal cases

Definitions of pediatric, birth, and maternal cases are as follows:

– Pediatric cases: hospital stays for individuals under 18 years of age
– Birth cases: hospital stays during which a child is born (identified via diagnosis codes of V3000 to V3901 with the last 2 digits being “00” or “01” in any diagnosis field)
– Maternal cases: hospital stays for females who are pregnant or gave birth (identified via NEOMAT code of “1” or “3”)

### Diagnoses, ICD-9-CM, and Clinical Classifications Software (CCS)

The principal diagnosis is that condition established after study to be chiefly responsible for the patient’s admission to the hospital. Secondary diagnoses are concomitant conditions that coexist at the time of admission or that develop during the stay.

ICD-9-CM is the International Classification of Diseases, Ninth Revision, Clinical Modification, which assigns numeric codes to diagnoses. There are about 12,000 ICD-9-CM diagnosis codes.

CCS categorizes ICD-9-CM diagnoses into 260 clinically meaningful categories.^3^ This “clinical grouper” makes it easier to quickly understand patterns of diagnoses and procedures.

### Emergency admission

Admission source indicates where the patient was located prior to admission to the hospital. Emergency admission indicates the patient was admitted to the hospital through the emergency department.

## For More Information

For a detailed description of HCUP and more information on the design of the NIS and methods to calculate estimates, please refer to the following publications:

Steiner, C., Elixhauser, A., Schnaier, J. The Healthcare Cost and Utilization Project: An Overview. Effective Clinical Practice 5(3):143–51, 2002.

Design of the HCUP Nationwide Inpatient Sample, 2004. Online. August 8, 2006. U.S. Agency for Healthcare Research and Quality. http://www.hcup-us.ahrq.gov/db/nation/nis/reports/NIS_2004_Design_Report.pdf

Houchens, R., Elixhauser, A. Final Report on Calculating Nationwide Inpatient Sample (NIS) Variances, 2001. HCUP Methods Series Report #2003-2. Online. June 2005 (revised June 6, 2005). U.S. Agency for Healthcare Research and Quality. http://www.hcup-us.ahrq.gov/reports/CalculatingNISVariances200106092005.pdf

1 Births include hospital stays for a newborn child. Adolescent pregnancy stays include hospitalizations during which the patient was pregnant or gave birth.

2 Merrill, C. T. (Thomson Healthcare) and Owens, P. L. (AHRQ). Hospital Admissions That Began in the Emergency Department for Children and Adolescents, 2004. HCUP Statistical Brief #32. June 2007. Agency for Healthcare Research and Quality, Rockville, MD. http://www.hcup-us.ahrq.gov/reports/statbriefs/sb32.pdf

3 HCUP Clinical Classifications Software (CCS). Healthcare Cost and Utilization Project (HCUP). August 2006. U.S. Agency for Healthcare Research and Quality, Rockville, MD. www.hcup-us.ahrq.gov/toolssoftware/ccs/ccs.jsp