# Statistical Brief #302 Mental Health Disorders Among Delivery Inpatient Stays by Patient Race and Ethnicity, 2020

## Introduction

Mental health disorders are common during and following pregnancy and may contribute to poorer maternal and neonatal outcomes.^1^ For example, maternal depression is associated with a higher rate of premature delivery and low birth weight infants.^2^ The proportion of delivery hospital stays involving a mental health disorder diagnosis has increased from 0.6 percent of delivery stays in 2000 to 7.3 percent of delivery stays in 2018.^3^ Moreover, this increasing trend was exacerbated in 2020 when pregnant women experienced COVID-19 pandemic-related stress associated with factors such as job loss, feeling unprepared for birth, and fear of COVID-19 infection.^4–6^

The prevalence of mental health disorders is generally similar across racial and ethnic groups in the United States.^7^ However, little is known about racial and ethnic differences in the rates of mental health disorders among women during pregnancy and delivery. Given the high prevalence of mental health disorders among delivery stays, especially during the COVID-19 pandemic, it is important to understand how mental health disorder diagnoses differ by patient race and ethnicity in order to address existing disparities and prevent widening disparities among maternal and neonatal outcomes.

This Healthcare Cost and Utilization Project (HCUP) Statistical Brief presents statistics on mental health disorders during delivery inpatient stays by patient race and ethnicity using weighted estimates from the 2020 National Inpatient Sample (NIS). First, changes in the rate of delivery stays with any mental health disorder diagnosis are presented by patient race and ethnicity from 2017 to 2020. Second, the distribution of delivery stays with and without a mental health disorder diagnosis is presented by patient race and ethnicity. Third, the rate of delivery stays with any mental health disorder diagnosis is presented by patient race and ethnicity for select patient and hospital characteristics and for specific and prevalent mental health disorders. Finally, the rate is provided by patient race and ethnicity for delivery stays involving common obstetric risk factors and either a concurrent mental health disorder diagnosis or no concurrent mental health disorder diagnosis. Because of the large sample size of the NIS data, small differences can be statistically significant but not clinically important. Thus, only differences greater than or equal to 10 percent are discussed in the text.

## Findings

Highlights

■ In 2020, White non-Hispanic women had the highest rate of delivery stays involving mental health disorders (14.0 per 100 delivery stays), and Asian/Pacific Islander non-Hispanic women had the lowest (3.6 per 100 delivery stays).
■ Between 2017 and 2020, the rate of delivery stays involving mental health disorders increased 52 percent, with the lowest rate of increase among Black non-Hispanic women (47 percent) and the highest rate of increase among other non-Hispanic race/ethnicity women (71 percent).
■ Anxiety and obsessive-compulsive disorders were the most common type of mental health disorder among delivery stays in 2020, with the highest rate among White non-Hispanic women and the lowest rate among Asian/Pacific Islander non-Hispanic women (9.6 and 2.2 per 100 delivery stays, respectively).
■ The rate of delivery stays involving anxiety and obsessive-compulsive disorders increased 74 percent between 2017 and 2020.
■ Select obstetric risk factors were more common among delivery stays involving at least one mental health disorder than among delivery stays with no mental health disorders (79.1 vs. 62.5 per 100 delivery stays, respectively).

### Prevalence of mental health disorder diagnoses among delivery stays, by patient race and ethnicity, 2020

Figure 1 displays the rate of delivery stays involving at least one mental health disorder diagnosis per 100 delivery stays from 2017 to 2020.

Figure 1 Rate of delivery stays involving a mental health disorder diagnosis, by patient race and ethnicity, 2017–2020

Abbreviations: API, Asian/Pacific Islander; NH, non-Hispanic

Note: Patient race and ethnicity information was missing for less than 5.5% of delivery stays involving a mental health disorder in any year (i.e., 5.3% missing in 2017, 3.2% missing in 2018, 3.0% missing in 2019, and 3.0% missing in 2020).

Source: Agency for Healthcare Research and Quality (AHRQ), Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS), 2017–2020

■ The rate of delivery stays with at least one mental health disorder diagnosis increased 52 percent between 2017 and 2020.
  From 2017 through 2020, the rate of delivery stays with a mental health diagnosis increased from 6.9 to 10.5 per 100 delivery stays, a 52 percent increase. The rate increased for all racial and ethnic groups over the 4-year period. The rate increase was highest for other non-Hispanic (NH) race/ethnicity women at 71 percent (from 4.5 to 7.7 per 100 delivery stays) and lowest for Black NH women at 47 percent (from 5.8 to 8.5 per 100 delivery stays).
■ White non-Hispanic women had the highest rate and Asian/Pacific Islander non-Hispanic women had the lowest rate of delivery stays with a mental health disorder diagnosis.
  Across years, White NH women had the highest rate of delivery inpatient stays with a mental health disorder (14.0 per 100 delivery stays in 2020), which was nearly four times higher than the rate among Asian/Pacific Islander NH women (3.6 per 100 delivery stays in 2020).

Figure 2 presents the distribution of delivery stays with and without a mental health disorder diagnosis in 2020 by patient race and ethnicity.

Figure 2 Distribution of delivery stays with and without a mental health disorder diagnosis, by patient race and ethnicity, 2020

Abbreviations: API, Asian/Pacific Islander; MHD, mental health disorder; NH, non-Hispanic

Source: Agency for Healthcare Research and Quality (AHRQ), Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS), 2020

■ White non-Hispanic women accounted for a larger proportion of delivery stays with a mental health disorder diagnosis than delivery stays with no mental health disorder diagnosis.
  In 2020, more than 10 percent of the 3.5 million total delivery stays involved a mental health disorder diagnosis. The distribution of patient race and ethnicity differed for delivery stays that included a mental health disorder diagnosis versus those that did not. More than two-thirds of delivery stays involving a mental health disorder diagnosis were for White non-Hispanic women, compared with less than half of delivery stays that did not involve a mental health disorder diagnosis (67.8 vs. 48.6 percent).

Table 1 presents the rate of delivery stays with a mental health disorder diagnosis per 100 delivery stays by patient race and ethnicity across select patient and hospital characteristics in 2020.

Table 1 Number and rate of delivery stays with a mental health disorder diagnosis per 100 delivery stays, by patient and hospital characteristics and patient race and ethnicity, 2020

Characteristic | All | | API NH | | Black NH | | Hispanic | | White NH | | Other NH
Characteristic | N | Rate | N | Rate | N | Rate | N | Rate | N | Rate | N | Rate
All MHD-related delivery stays | 361,700 | 10.5 | 7,300 | 3.6 | 43,000 | 8.5 | 42,100 | 5.9 | 245,300 | 14.0 | 13,300 | 7.7
Age group, years
12–19 | 16,500 | 10.6 | 100 | 4.8 | 3,100 | 8.8 | 2,900 | 6.0 | 9,100 | 15.7 | 800 | 10.0
20–24 | 68,000 | 10.7 | 600 | 4.6 | 10,400 | 8.4 | 9,200 | 5.7 | 43,100 | 15.0 | 2,600 | 8.3
25–34 | 206,800 | 10.4 | 4,100 | 3.3 | 23,000 | 8.5 | 22,300 | 5.9 | 144,000 | 13.6 | 7,200 | 7.4
35–55 | 70,400 | 10.6 | 2,500 | 4.0 | 6,600 | 8.1 | 7,600 | 6.2 | 49,100 | 14.4 | 2,700 | 7.7
Primary expected payer
Medicaid | 153,400 | 10.7 | 1,800 | 3.6 | 29,100 | 9.3 | 24,600 | 5.6 | 87,100 | 16.9 | 6,300 | 7.6
Private | 187,000 | 10.3 | 5,100 | 3.7 | 10,700 | 6.3 | 15,000 | 6.5 | 144,500 | 12.7 | 6,200 | 8.0
Self-pay/No charge^*^ | 4,300 | 5.2 | 100 | 1.5 | 600 | 7.3 | 800 | 2.9 | 2,500 | 7.8 | 200 | 3.9
Other payers^‡^ | 16,500 | 14.2 | 300 | 5.2 | 2,600 | 13.8 | 1,600 | 10.4 | 11,000 | 16.7 | 500 | 9.6
Community-level income
Quartile 1 (lowest) | 90,700 | 9.6 | 700 | 3.2 | 20,800 | 8.6 | 12,700 | 5.2 | 50,500 | 13.6 | 3,300 | 7.7
Quartiles 2 and 3 | 188,700 | 10.9 | 3,100 | 3.8 | 17,700 | 8.3 | 21,400 | 5.9 | 134,600 | 14.5 | 6,300 | 7.7
Quartile 4 (highest) | 79,400 | 10.5 | 3,500 | 3.6 | 4,100 | 7.7 | 7,600 | 7.5 | 58,700 | 13.4 | 3,500 | 7.6
Patient location
Large metropolitan | 185,900 | 9.5 | 5,500 | 3.5 | 27,600 | 8.4 | 27,400 | 5.9 | 113,900 | 13.6 | 7,900 | 7.0
Small metropolitan | 122,900 | 11.9 | 1,500 | 4.1 | 12,600 | 9.2 | 12,400 | 6.2 | 87,900 | 15.2 | 3,600 | 9.1
Nonmetropolitan | 52,300 | 11.3 | 200 | 4.2 | 2,700 | 6.0 | 2,100 | 4.8 | 43,200 | 13.2 | 1,900 | 9.6
Hospital region
Northeast | 67,600 | 12.3 | 1,300 | 3.5 | 7,500 | 10.5 | 8,300 | 8.7 | 46,200 | 15.6 | 3,100 | 8.0
Midwest | 94,400 | 13.1 | 1,000 | 3.8 | 10,000 | 10.1 | 4,500 | 7.5 | 71,700 | 15.5 | 2,000 | 9.2
South | 122,500 | 8.9 | 1,300 | 2.7 | 21,200 | 7.1 | 11,200 | 4.0 | 82,500 | 12.5 | 4,300 | 6.1
West | 77,100 | 9.6 | 3,700 | 4.1 | 4,400 | 10.1 | 18,100 | 6.4 | 44,900 | 13.7 | 3,900 | 9.6

Abbreviations: API, Asian/Pacific Islander; MHD, mental health disorder; NH, non-Hispanic

Notes: Total number of delivery stays is rounded to the nearest 100. Patient race and ethnicity information was missing for 3.0% of delivery stays involving a mental health disorder in 2020.

* Self-pay/No charge: includes self-pay, no charge, charity, and no expected payment.

‡ Other payers include Medicare, which provides health insurance for a limited number of individuals with disabilities or with end-stage renal disease under the age of 65 years and was the primary payer for 1.6% of all delivery stays involving a mental health disorder in 2020.

Source: Agency for Healthcare Research and Quality (AHRQ), Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS), 2020

■ Delivery stays for women residing in small metropolitan and nonmetropolitan areas and those living in the Midwest and Northeast had the highest rates of stays involving a mental health disorder.
  The rate of delivery stays involving a mental health disorder diagnosis was higher for women residing in small metropolitan and nonmetropolitan areas compared with those residing in large metropolitan areas (11.9 and 11.3, respectively, vs. 9.5 per 100 delivery stays).
  Among delivery stays for Black non-Hispanic (NH) and Hispanic women, the rate was approximately 30 and 20 percent lower, respectively, for those residing in nonmetropolitan areas compared with those residing in large metropolitan areas. In contrast, the rate was similar for White NH women residing in nonmetropolitan and large metropolitan areas.
  The rate of delivery stays involving a mental health disorder was higher for women living in the Midwest and Northeast (13.1 and 12.3 per 100 delivery stays, respectively) than those living in the South and West (8.9 and 9.6, respectively). This pattern was observed for Hispanic and White NH women but did not hold for other racial and ethnic groups, for which the rate was lower only in the South.
■ Among Black non-Hispanic and White non-Hispanic women, those with Medicaid as the primary expected payer had higher rates of delivery stays involving a mental health disorder than those with private insurance as the expected payer; the reverse was true for Hispanic women.
  Among Black NH women, the rate of delivery stays involving a mental health disorder was higher for stays expected to be paid by Medicaid (9.3 per 100 delivery stays) versus private insurance (6.3) or stays expected to be self-pay/no charge (7.3). Among White NH individuals, the rate also was higher for Medicaid (16.9) versus private insurance (12.7) or self-pay/no charge (7.8). In contrast, for Hispanic individuals, the rate of delivery stays involving a mental health disorder was higher for stays expected to be paid by private insurance (6.5) versus Medicaid (5.6) or self-pay/no charge (2.9). The highest rate of delivery stays involving a mental health disorder diagnosis was observed among delivery stays for women with other expected payers, which comprise a variety of Federal payers, including Medicare.

Figure 3 displays the rate of delivery stays involving the two most common mental health disorders of the 13 examined in 2020.

Figure 3 Rate of delivery stays involving a mental health disorder diagnosis, by type of mental health disorder and patient race and ethnicity, 2020

Abbreviations: API, Asian/Pacific Islander; NH, non-Hispanic

Notes: Patient race and ethnicity information was missing for less than 5.5% of delivery stays involving a mental health disorder (5.3% missing in 2017 and 3.0% missing in 2020). Diagnoses are selected from mental health-related Clinical Classifications Software Refined (CCSR) for ICD-10-CM Diagnoses categories (www.hcup-us.ahrq.gov/toolssoftware/ccsr/dxccsr.jsp). Diagnosis categories are not mutually exclusive.

Source: Agency for Healthcare Research and Quality (AHRQ), Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS), 2017 and 2020

■ Anxiety and obsessive-compulsive disorders were the most common type of mental health disorder diagnosis among delivery stays in 2020.
  Overall, 6.7 per 100 delivery stays in 2020 involved anxiety and obsessive-compulsive disorders, followed by depressive disorders at a rate of 5.0 per 100 delivery stays. Anxiety and obsessive-compulsive disorders were the most common type of mental health disorder among delivery stays for all racial and ethnic groups except for Black non-Hispanic (NH) women, for whom anxiety and obsessive-compulsive disorders and depressive disorders were equally common.
■ The rate of delivery stays involving anxiety and obsessive-compulsive disorders and depressive disorders increased 60–70 percent between 2017 and 2020.
  Comparing 2017 and 2020, the rate of delivery stays involving anxiety and obsessive-compulsive disorders increased 74.3 percent. The percentage increase was high for all racial and ethnic groups, ranging from 73.6 percent for White NH women to 100.4 percent for Asian/Pacific Islander NH women. Similarly, the rate of delivery stays involving depressive disorders increased 61.3 percent between 2017 and 2020, ranging from 55.2 percent for Black NH women to 93.4 percent for other NH race/ethnicity women.

### Maternal risk factors among delivery stays involving a mental health disorder diagnosis, by patient race and ethnicity, 2020

Table 2 presents the rate of delivery stays involving 12 common obstetric risk factors among delivery stays with and without a co-occurring mental health disorder diagnosis by patient race and ethnicity in 2020.^8^ Risk factors are listed from highest to lowest rate of delivery stays with a co-occurring mental health disorder for all races and ethnicities in 2020. Only risk factors with at least 5 percent prevalence across all racial and ethnic groups are included.

Table 2 Rate of delivery stays with obstetric risk factors per 100 delivery stays, by presence of a co-occurring mental health disorder diagnosis and patient race and ethnicity, 2020

Type of obstetric risk factor | Overall | | API NH | | Black NH | | Hispanic | | White NH | | Other NH
Type of obstetric risk factor | MHD | No MHD | MHD | No MHD | MHD | No MHD | MHD | No MHD | MHD | No MHD | MHD | No MHD
Number of deliveries (thousands) | 361.7 | 3,092.3 | 7.3 | 192.7 | 43.0 | 464.8 | 42.1 | 671.7 | 245.3 | 1,502.6 | 13.3 | 159.2
Rate per 100 delivery stays
Anemia, preexisting | 20.5 | 14.9 | 20.4 | 14.4 | 37.1 | 27.1 | 24.4 | 15.9 | 16.9 | 10.8 | 22.2 | 16.3
Maternal age >35 years | 19.5 | 19.1 | 34.0 | 30.6 | 15.3 | 16.0 | 18.2 | 17.4 | 20.0 | 19.3 | 20.7 | 20.4
Previous cesarean birth | 18.1 | 17.8 | 16.9 | 16.6 | 22.2 | 20.5 | 19.3 | 19.4 | 17.3 | 16.4 | 18.4 | 18.3
Substance use disorder | 16.9 | 5.2 | 5.5 | 0.9 | 22.6 | 7.1 | 10.8 | 1.9 | 17.4 | 6.8 | 16.7 | 4.4
Asthma, acute or moderate/severe | 15.6 | 5.6 | 14.7 | 3.7 | 22.3 | 8.9 | 17.3 | 4.9 | 14.4 | 5.3 | 15.5 | 5.2
Preterm birth | 14.3 | 9.5 | 12.6 | 8.1 | 19.7 | 13.7 | 13.5 | 9.6 | 13.4 | 8.3 | 14.8 | 9.7
Preeclampsia without severe features or gestational hypertension | 13.2 | 9.7 | 11.3 | 6.6 | 13.0 | 11.7 | 11.7 | 8.4 | 13.6 | 10.3 | 13.1 | 8.6
Gastrointestinal disease | 13.0 | 5.5 | 11.0 | 4.9 | 12.1 | 5.3 | 13.4 | 5.8 | 13.3 | 5.5 | 12.3 | 5.8
Gestational diabetes mellitus | 9.7 | 9.1 | 17.6 | 17.5 | 7.1 | 7.3 | 11.0 | 10.4 | 9.7 | 7.8 | 10.9 | 11.0
Neuromuscular disease | 7.3 | 1.8 | 8.7 | 1.5 | 8.1 | 2.1 | 8.1 | 1.5 | 7.1 | 1.9 | 7.1 | 1.7
Preeclampsia with severe features | 7.1 | 3.9 | 7.2 | 3.0 | 11.4 | 6.8 | 6.8 | 3.9 | 6.4 | 3.2 | 7.3 | 3.8
Chronic hypertension | 6.7 | 3.4 | 5.8 | 2.3 | 12.4 | 6.8 | 5.8 | 2.5 | 5.9 | 3.0 | 6.4 | 2.9
At least one of the 12 common risk factors | 79.1 | 62.5 | 79.5 | 65.5 | 86.6 | 71.4 | 78.4 | 60.8 | 78.1 | 60.2 | 79.0 | 63.2

Abbreviations: API, Asian/Pacific Islander; MHD, mental health disorder; NH, non-Hispanic

Notes: Obstetric risk factors are presented from highest to lowest rate of delivery stays with a co-occurring mental health disorder diagnosis for all races and ethnicities in 2020. Obstetric risk factors are not mutually exclusive. Only obstetric risk factors with at least 5% prevalence across all racial and ethnic groups are included. Patient race and ethnicity information was missing for 3.0% of delivery stays involving a mental health disorder and 3.3% of delivery stays with no mental health disorders in 2020.

Source: Agency for Healthcare Research and Quality (AHRQ), Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS), 2020

■ Obstetric risk factors were more common among delivery stays with a mental health disorder diagnosis than among delivery stays with no mental health disorders.
  Overall, 79.1 per 100 delivery stays with a mental health disorder diagnosis also included at least one of 12 common obstetric risk factors, compared with 62.5 per 100 delivery stays without a mental health disorder diagnosis. This differential held across all racial and ethnic groups.
  The rate of delivery stays involving most of the specific obstetric risk factors, including anemia, asthma, and preterm birth, was higher overall and for each racial and ethnic group when the delivery stay also involved at least one mental health disorder. For example, the rate of delivery stays involving asthma was two to three times higher when the stay included a mental health disorder versus when the stay did not (e.g., 15.6 vs. 5.6 per 100 delivery stays overall). The rate of delivery stays involving maternal age older than 35 years, previous cesarean birth, and gestational diabetes mellitus was similar among delivery stays that involved a mental health disorder diagnosis and stays without mental health disorders.

## References

1 U.S. Department of Health and Human Services, Office of the Surgeon General. The Surgeon General’s Call to Action to Improve Maternal Health. 2020. www.hhs.gov/sites/default/files/call-to-action-maternal-health.pdf. Accessed September 6, 2022.
2 Gold J, Marcus SM. Effect of maternal mental illness on pregnancy outcomes. Expert Review of Obstetrics & Gynecology. 2008;3(3):391–401.
3 Logue TC, Wen T, Monk C, Guglielminotti J, Huang Y, Wright JD, . Trends in and complications associated with mental health condition diagnoses during delivery hospitalizations. American Journal of Obstetrics & Gynecology. 2022;226(3):405.e1–16.
4 Moyer CA, Compton SD, Kaselitz E, Muzik M. Pregnancy-related anxiety during COVID-19: a nationwide survey of 2740 pregnant women. Archives of Women’s Mental Health. 2020;23(6):757–65.
5 Preis H, Mahaffey B, Heiselman C, Lobel M. Vulnerability and resilience to pandemic-related stress among U.S. women pregnant at the start of the COVID-19 pandemic. Social Science & Medicine. 2020:266:113348.32927382
6 King LS, Feddoes DE, Kirshenbaum JS, Humphreys KL, Gotlib IH. Pregnancy during the pandemic: the impact of COVID-19-related stress on risk for prenatal depression. Psychological Medicine. 2021;1–11.
7 American Psychiatric Association. Mental Health Disparities: Diverse Populations. 2017. www.psychiatry.org/File%20Library/Psychiatrists/Cultural-Competency/Mental-Health-Disparities/Mental-Health-Facts-for-Diverse-Populations.pdf. Accessed September 19, 2022.
8 Leonard SA, Kennedy CJ, Carmichael SL, Lyell DJ, Main EK. An expanded obstetric comorbidity scoring system for predicting severe maternal morbidity. Obstetrics & Gynecology. 2020;136(3):440–9.32769656

## About Statistical Briefs

Healthcare Cost and Utilization Project (HCUP) Statistical Briefs provide basic descriptive statistics on a variety of topics using HCUP administrative healthcare data. Topics include hospital inpatient, ambulatory surgery, and emergency department use and costs, quality of care, access to care, medical conditions, procedures, and patient populations, among other topics. The reports are intended to generate hypotheses that can be further explored in other research; the reports are not designed to answer in-depth research questions using multivariate methods.

## Data Source

The estimates in this Statistical Brief are based upon data from the HCUP 2020 National Inpatient Sample (NIS). Historical data were drawn from the 2017–2019 NIS.

## Definitions

### Diagnoses, ICD-10-CM, Clinical Classifications Software Refined (CCSR) for ICD-10-CM/PCS, and diagnosis-related groups (DRGs)

The principal diagnosis is that condition established after study to be chiefly responsible for the patient’s admission to the hospital. Secondary diagnoses are conditions that coexist at the time of admission that require or affect patient care treatment received or management, or that develop during the inpatient stay. All-listed diagnoses include the principal diagnosis plus the secondary conditions.

ICD-10-CM/PCS is the International Classification of Diseases, Tenth Revision, Clinical Modification/Procedure Coding System. There are over 70,000 ICD-10-CM diagnosis codes and 75,000 ICD-10-PCS procedure codes.

The CCSR aggregates ICD-10-CM diagnosis codes into a manageable number of clinically meaningful categories.^a^ The CCSR is intended to be used analytically to examine patterns of healthcare in terms of cost, utilization, and outcomes; rank utilization by diagnoses; and risk-adjust by clinical condition. The CCSR capitalizes on the specificity of the ICD-10-CM coding scheme and allows ICD-10-CM codes to be classified in more than one category. Approximately 10 percent of diagnosis codes are associated with more than one CCSR category because the diagnosis code documents either multiple conditions or a condition along with a common symptom or manifestation. All CCSR categories were considered in identifying mental health disorder diagnoses for this Statistical Brief. ICD-10-CM coding definitions for each CCSR category presented in this Statistical Brief can be found in the CCSR reference file, available at www.hcup-us.ahrq.gov/toolssoftware/ccsr/ccs_refined.jsp#download (http://www.hcup-us.ahrq.gov/toolssoftware/ccsr/ccs_refined.jsp#user). For this Statistical Brief, a custom version of v2022.1 of the CCSR was used; see below for further details on the differences.

DRGs comprise a patient classification system that categorizes patients into groups that are clinically coherent and homogeneous with respect to resource use. DRGs group patients according to diagnosis, type of treatment (procedure), age, and other relevant criteria. Each hospital stay has one assigned DRG.

### Case definition

Inpatient delivery stays were identified using the ICD-10-CM/PCS and DRG codes in Table 3. Delivery stays were defined as records that included a delivery code and did not include an abortion code.

Table 3 Clinical codes used to identify delivery stays

Code type | Code | Description
Delivery codes
ICD-10-CM | Z370 | Single live birth
ICD-10-CM | Z371 | Single stillbirth
ICD-10-CM | Z372 | Twins, both liveborn
ICD-10-CM | Z373 | Twins, one liveborn and one stillborn
ICD-10-CM | Z374 | Twins, both stillborn
ICD-10-CM | Z3750 | Multiple births, unspecified, all liveborn
ICD-10-CM | Z3751 | Triplets, all liveborn
ICD-10-CM | Z3752 | Quadruplets, all liveborn
ICD-10-CM | Z3753 | Quintuplets, all liveborn
ICD-10-CM | Z3754 | Sextuplets, all liveborn
ICD-10-CM | Z3759 | Other multiple births, all liveborn
ICD-10-CM | Z3760 | Multiple births, unspecified, some liveborn
ICD-10-CM | Z3761 | Triplets, some liveborn
ICD-10-CM | Z3762 | Quadruplets, some liveborn
ICD-10-CM | Z3763 | Quintuplets, some liveborn
ICD-10-CM | Z3764 | Sextuplets, some liveborn
ICD-10-CM | Z3769 | Other multiple births, some liveborn
ICD-10-CM | Z377 | Other multiple births, all stillborn
ICD-10-CM | Z379 | Outcome of delivery, unspecified
ICD-10-CM | O80 | Vaginal delivery
ICD-10-CM | O82 | C-section
ICD-10-CM | O7582 | C-section
MS-DRG v.33-35 | 765 | Vaginal Delivery with CC/MCC
MS-DRG v.33-35 | 766 | Vaginal Delivery without CC/MCC
MS-DRG v.33-35 | 767 | Vaginal Delivery with Sterilization and/or D&C
MS-DRG v.33-35 | 768 | Vaginal Delivery with O.R. Procedures except Sterilization and/or D&C
MS-DRG v.33-35 | 774 | Vaginal Delivery with Complicating Diagnosis
MS-DRG v.36 | 768 | Vaginal Delivery with O.R. Procedures except Sterilization &/or D&C
MS-DRG v.36 | 783 | Cesarean Section with Sterilization with MCC
MS-DRG v.36 | 784 | Cesarean Section with Sterilization with CC
MS-DRG v.36 | 785 | Cesarean Section with Sterilization without CC/MCC
MS-DRG v.36 | 786 | Cesarean Section without Sterilization with MCC
MS-DRG v.36 | 787 | Cesarean Section without Sterilization with CC
MS-DRG v.36 | 788 | Cesarean Section without Sterilization without CC/MCC
MS-DRG v.36 | 796 | Vaginal Delivery with Sterilization/D&C with MCC
MS-DRG v.36 | 797 | Vaginal Delivery with Sterilization/D&C with CC
MS-DRG v.36 | 798 | Vaginal Delivery with Sterilization/D&C without CC/MCC
MS-DRG v.36 | 805 | Vaginal Delivery without Sterilization/D&C with MCC
MS-DRG v.36 | 806 | Vaginal Delivery without Sterilization/D&C with CC
MS-DRG v.36 | 807 | Vaginal Delivery without Sterilization/D&C without CC/MCC
ICD-10-PCS | 10D00Z0 | Extraction of Products of Conception, High, Open Approach
ICD-10-PCS | 10D00Z1 | Extraction of Products of Conception, Low, Open Approach
ICD-10-PCS | 10D00Z2 | Extraction of Products of Conception, Extraperitoneal, Open Approach
ICD-10-PCS | 10D07Z3 | Extraction of Products of Conception, Low Forceps, Via Natural or Artificial Opening
ICD-10-PCS | 10D07Z4 | Extraction of Products of Conception, Mid Forceps, Via Natural or Artificial Opening
ICD-10-PCS | 10D07Z5 | Extraction of Products of Conception, High Forceps, Via Natural or Artificial Opening
ICD-10-PCS | 10D07Z6 | Extraction of Products of Conception, Vacuum, Via Natural or Artificial Opening
ICD-10-PCS | 10D07Z7 | Extraction of Products of Conception, Internal Version, Via Natural or Artificial Opening
ICD-10-PCS | 10D07Z8 | Extraction of Products of Conception, Other, Via Natural or Artificial Opening
ICD-10-PCS | 10E0XZZ | Delivery of Products of Conception, External Approach
Abortion codes (for exclusion)
ICD-10-CM | O00 | Ectopic pregnancy
ICD-10-CM | O01 | Hydatidiform mole
ICD-10-CM | O02 | Other abnormal products of conception
ICD-10-CM | O03 | Spontaneous abortion
ICD-10-CM | O04 | Complications following (induced) termination of pregnancy
ICD-10-CM | O07 | Failed attempted termination of pregnancy
ICD-10-CM | O08 | Complications following ectopic and molar pregnancy
ICD-10-PCS | 10A00ZZ | Abortion of Products of Conception, Open Approach
ICD-10-PCS | 10A03ZZ | Abortion of Products of Conception, Percutaneous Approach
ICD-10-PCS | 10A04ZZ | Abortion of Products of Conception, Percutaneous Endoscopic Approach
ICD-10-PCS | 10A07Z6 | Abortion of Products of Conception, Vacuum, Via Natural or Artificial Opening
ICD-10-PCS | 10A07ZW | Abortion of Products of Conception, Laminaria, Via Natural or Artificial Opening
ICD-10-PCS | 10A07ZX | Abortion of Products of Conception, Abortifacient, Via Natural or Artificial Opening
ICD-10-PCS | 10A07ZZ | Abortion of Products of Conception, Via Natural or Artificial Opening
ICD-10-PCS | 10A08ZZ | Abortion of Products of Conception, Via Natural or Artificial Opening Endoscopic

Abbreviations: CC, complications or comorbidities; D&C, dilation and curettage; ICD-10-CM/PCS, International Classification of Diseases, Tenth Revision, Clinical Modification/Procedure Coding System; MCC, major complications or comorbidities; MS-DRG, Medicare Severity Diagnosis Related Group; O.R., operating room

Delivery stays involving a mental health disorder diagnosis were identified based on the presence of any CCSR category listed in Table 4 for any-listed diagnosis on the hospital discharge record. The two specific mental health disorder categories presented in Figure 3 were defined by the following CCSR categories: anxiety and obsessive-compulsive disorders (MBD005 and MBD006) and depressive disorders (MBD002). Among the other CCSR categories involving less common mental health disorders that were not presented in Figure 3, all showed an increase in the rate per 100 deliveries between 2017 and 2020 except for schizophrenia spectrum and other psychotic disorders (MBD001) and somatic disorders (MBD011); however, these two CCSR categories involved very small sample sizes.

Table 4 Clinical codes used to identify mental health disorder diagnoses

CCSR category | CCSR category description
MBD001 | Schizophrenia spectrum and other psychotic disorders
The following two ICD-10-CM diagnosis codes were also considered as schizophrenia spectrum and other psychotic disorders for this Statistical Brief:; - F53, Mental and behavioral disorders associated with the puerperium, not elsewhere classified (from CCSR MBD013, Miscellaneous mental and behavioral disorders/conditions); - F531, Puerperal psychosis (from CCSR MBD013, Miscellaneous mental and behavioral disorders/conditions)
MBD002 | Depressive disorders
The following two ICD-10-CM diagnosis codes were also considered as depressive disorders for this Statistical Brief:; - F530, Postpartum depression (from CCSR MBD013, Miscellaneous mental and behavioral disorders/conditions); - O906, Postpartum mood disturbance (from CCSR PRG027, Complications specified during the puerperium)
MBD003 | Bipolar and related disorders
MBD004 | Other specified and unspecified mood disorders
MBD005 | Anxiety and fear-related disorders
MBD006 | Obsessive-compulsive and related disorders
MBD007 | Trauma- and stressor-related disorders
MBD008 | Disruptive, impulse-control and conduct disorders
MBD009 | Personality disorders
MBD010 | Feeding and eating disorders
MBD011 | Somatic disorders
MBD012 | Suicidal ideation/attempt/intentional self-harm
MBD013 | Miscellaneous mental and behavioral disorders/conditions

Abbreviations: CCSR, Clinical Classifications Software for ICD-10-CM Diagnoses; ICD-10-CM, International Classification of Diseases, Tenth Revision, Clinical Modification

Obstetric risk factors were defined with ICD-10-CM codes based on a validated obstetrics comorbidity scoring system developed by Leonard et al.^b^ that used birth data from California during 2016 and 2017 to select 27 patient-level risk factors associated with severe maternal morbidity.

### Percentage change

Percentage change between years was calculated using the following formula:

Percentage change = ( (2020 value − 2017 value)/(2017 value) ) × 100

### Types of hospitals included in the HCUP National Inpatient Sample

The National Inpatient Sample (NIS) is based on data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). The NIS includes obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical center hospitals. Excluded are long-term care facilities such as rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. Beginning in 2012, long-term acute care hospitals are also excluded. However, if a patient received long-term care, rehabilitation, or treatment for a psychiatric or chemical dependency condition in a community hospital, the discharge record for that stay will be included in the NIS.

### Unit of analysis

The unit of analysis is the hospital discharge (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the hospital multiple times in 1 year will be counted each time as a separate discharge from the hospital.

### Expected payer

To make coding uniform across all HCUP data sources, the primary expected payer for the hospital stay combines detailed categories into general groups:

- Medicare: includes fee-for-service and managed care Medicare
- Medicaid: includes fee-for-service and managed care Medicaid
- Private insurance: includes commercial nongovernmental payers, regardless of the type of plan (e.g., private health maintenance organizations [HMOs], preferred provider organizations [PPOs])
- Self-pay/No charge: includes self-pay, no charge, charity, and no expected payment
- Other payers: includes other Federal and local government programs (e.g., TRICARE, CHAMPVA, Indian Health Service, Black Lung, Title V) and Workers’ Compensation

Hospital stays that were expected to be billed to the State Children’s Health Insurance Program (SCHIP) are included under Medicaid.

For this Statistical Brief, when more than one payer is listed for a hospital discharge, the first-listed payer is used.

### Community-level income

Community-level income is based on the median household income of the patient’s ZIP Code of residence. Quartiles are defined so that the total U.S. population is evenly distributed.

### Location of patients’ residence

Place of residence is based on a simplified adaptation of the Urban Influence Codes (UIC) developed by the United States Department of Agriculture (USDA) Economic Research Service (ERS). Starting with 2014 data, the county-level designation is based on the 2013 version of the UIC. Prior to 2014, the categorization was based on the 2003 version of the UIC. The 12 categories of the UIC are combined into 3 broader categories that differentiate between large metropolitan counties (include one or more urbanized areas with at least 1 million residents), small metropolitan counties (include one or more urbanized areas with 50,000–999,999 residents), and nonmetropolitan counties (i.e., micropolitan counties (include at least one urbanized area with 10,000–49,999 residents) or nonurban residual counties (rural)).

### Region

Region is one of the four regions defined by the U.S. Census Bureau:

- Northeast: Maine, New Hampshire, Vermont, Massachusetts, Rhode Island, Connecticut, New York, New Jersey, and Pennsylvania
- Midwest: Ohio, Indiana, Illinois, Michigan, Wisconsin, Minnesota, Iowa, Missouri, North Dakota, South Dakota, Nebraska, and Kansas
- South: Delaware, Maryland, District of Columbia, Virginia, West Virginia, North Carolina, South Carolina, Georgia, Florida, Kentucky, Tennessee, Alabama, Mississippi, Arkansas, Louisiana, Oklahoma, and Texas
- West: Montana, Idaho, Wyoming, Colorado, New Mexico, Arizona, Utah, Nevada, Washington, Oregon, California, Alaska, and Hawaii

### Reporting of race and ethnicity

Data on Hispanic ethnicity are collected differently among the States and also can differ from the census methodology of collecting information on race (White, Black, Asian/Pacific Islander, American Indian/Alaska Native, Other [including mixed race]) separately from ethnicity (Hispanic, non-Hispanic). State data organizations often collect Hispanic ethnicity as one of several categories that include race. Therefore, for multistate analyses, HCUP creates the combined categorization of race and ethnicity for data from States that report ethnicity separately. When a State data organization collects Hispanic ethnicity separately from race, HCUP uses Hispanic ethnicity to override any other race category to create a Hispanic category for the uniformly coded race/ethnicity data element, while also retaining the original race and ethnicity data. This Statistical Brief reports race and ethnicity for the following categories: Asian/Pacific Islander non-Hispanic (NH), Black NH, Hispanic, White NH, and other NH race and ethnicity (including American Indian/Alaska Native and Other).

## About HCUP

The Healthcare Cost and Utilization Project (HCUP, pronounced “H-Cup”) is a family of healthcare databases and related software tools and products developed through a Federal-State-Industry partnership and sponsored by the Agency for Healthcare Research and Quality (AHRQ). HCUP databases bring together the data collection efforts of State data organizations, hospital associations, and private data organizations (HCUP Partners) and the Federal government to create a national information resource of encounter-level healthcare data. HCUP includes the largest collection of longitudinal hospital care data in the United States, with all-payer, encounter-level information beginning in 1988. These databases enable research on a broad range of health policy issues, including cost and quality of health services, medical practice patterns, access to healthcare programs, and outcomes of treatments at the national, State, and local market levels.

HCUP would not be possible without the contributions of the following data collection Partners from across the United States:

- Alaska Department of Health
- Alaska Hospital and Healthcare Association
- Arizona Department of Health Services
- Arkansas Department of Health
- California Department of Health Care Access and Information
- Colorado Hospital Association
- Connecticut Hospital Association
- Delaware Division of Public Health
- District of Columbia Hospital Association
- Florida Agency for Health Care Administration
- Georgia Hospital Association
- Hawaii Laulima Data Alliance
- Hawaii University of Hawai’i at Hilo
- Illinois Department of Public Health
- Indiana Hospital Association
- Iowa Hospital Association
- Kansas Hospital Association
- Kentucky Cabinet for Health and Family Services
- Louisiana Department of Health
- Maine Health Data Organization
- Maryland Health Services Cost Review Commission
- Massachusetts Center for Health Information and Analysis
- Michigan Health & Hospital Association
- Minnesota Hospital Association
- Mississippi State Department of Health
- Missouri Hospital Industry Data Institute
- Montana Hospital Association
- Nebraska Hospital Association
- Nevada Department of Health and Human Services
- New Hampshire Department of Health & Human Services
- New Jersey Department of Health
- New Mexico Department of Health
- New York State Department of Health
- North Carolina Department of Health and Human Services
- North Dakota (data provided by the Minnesota Hospital Association)
- Ohio Hospital Association
- Oklahoma State Department of Health
- Oregon Association of Hospitals and Health Systems
- Oregon Health Authority
- Pennsylvania Health Care Cost Containment Council
- Rhode Island Department of Health
- South Carolina Revenue and Fiscal Affairs Office
- South Dakota Association of Healthcare Organizations
- Tennessee Hospital Association
- Texas Department of State Health Services
- Utah Department of Health
- Vermont Association of Hospitals and Health Systems
- Virginia Health Information
- Washington State Department of Health
- West Virginia Department of Health and Human Resources
- Wisconsin Department of Health Services
- Wyoming Hospital Association

## About the NIS

The HCUP National (Nationwide) Inpatient Sample (NIS) is a nationwide database of hospital inpatient stays. The NIS is nationally representative of all community hospitals (i.e., short-term, non-Federal, non-rehabilitation hospitals). The NIS includes all payers. It is drawn from a sampling frame that contains hospitals comprising more than 96 percent of all discharges in the United States. The vast size of the NIS allows the study of topics at the national and regional levels for specific subgroups of patients. In addition, NIS data are standardized across years to facilitate ease of use. Over time, the sampling frame for the NIS has changed; thus, the number of States contributing to the NIS varies from year to year. The NIS is intended for national estimates only; no State-level estimates can be produced. The unweighted sample size for the 2020 NIS is 6,471,165 (weighted, this represents 32,355,827 inpatient stays).

## For More Information

For other information on hospitalizations related to mental health disorders and maternal health, refer to the Mental and Substance Use Disorders, Race and Ethnicity, Pregnancy and Childbirth, and Women’s Health HCUP Statistical Briefs topic areas located at www.hcup-us.ahrq.gov/reports/statbriefs/sbtopic.jsp.

For additional HCUP statistics, visit:

- HCUP Fast Stats at https://datatools.ahrq.gov/hcup-fast-stats for easy access to the latest HCUP-based statistics for healthcare information topics
- HCUPnet, HCUP’s interactive query system, at https://datatools.ahrq.gov/hcupnet
- HCUP Summary Trend Tables at www.hcup-us.ahrq.gov/reports/trendtables/summarytrendtables.jsp for monthly information on hospital utilization

For more information about HCUP, visit www.hcup-us.ahrq.gov/.

For a detailed description of HCUP and more information on the design of the National Inpatient Sample (NIS), please refer to the following database documentation:

Agency for Healthcare Research and Quality. Overview of the National (Nationwide) Inpatient Sample (NIS). Healthcare Cost and Utilization Project (HCUP). Rockville, MD: Agency for Healthcare Research and Quality. Updated September 2021. www.hcup-us.ahrq.gov/nisoverview.jsp. Accessed March 9, 2022.

## Acknowledgments

The authors would like to acknowledge the contributions of Marguerite Barrett of M.L. Barrett, Inc., and Minya Sheng of IBM.

a Agency for Healthcare Research and Quality. Clinical Classifications Software Refined (CCSR) for ICD-10-CM Diagnoses. Healthcare Cost and Utilization Project (HCUP). Agency for Healthcare Research and Quality. Updated February 2022. www.hcup-us.ahrq.gov/toolssoftware/ccsr/dxccsr.jsp. Accessed March 9, 2022.

b Leonard SA, Kennedy CJ, Carmichael SL, Lyell DJ, Main EK. An expanded obstetric comorbidity scoring system for predicting severe maternal morbidity. Obstetrics & Gynecology. 2020;136(3):440–9.32769656