# Statistical Brief #30 Hospital Stays for Prostate Cancer, 2004

## Introduction

In the United States, prostate cancer is a leading cause of cancer-related deaths in men, second only to lung cancer.^1^ After basal cell carcinoma,^2^ prostate cancer is the most common cancer diagnosis for men. Nearly one in six men will be diagnosed with prostate cancer during his lifetime. Currently, about two million men are living with prostate cancer in the U.S.^3^ Although most treatment of prostate cancer occurs in the outpatient setting,^4^ a significant portion of care is provided in the hospital, especially for surgical treatment.

This Statistical Brief presents data from the Healthcare Cost and Utilization Project (HCUP) on the treatment of prostate cancer in U.S. hospitals in 2004. The utilization and cost of hospital stays for prostate cancer are compared with all hospital stays for males. Age and payer differences among these hospital stays are also presented. Finally, commonly performed procedures used to treat prostate cancer and inpatient use of these procedures are examined. All differences between estimates noted in the text are statistically significant at the 0.05 level or better.

## Findings

Highlights

- In 2004, prostate cancer was principally responsible for more than 81,000 hospital stays, but overall nearly half a million hospital stays involved prostate cancer.
- From 1997 to 2004, the number of hospital stays principally for prostate cancer decreased nearly 30 percent while the number with prostate cancer listed as a secondary diagnosis increased about 8 percent, suggesting that more men are living with prostate cancer and are being hospitalized for other conditions.
- Hospital costs for treatment of prostate cancer totaled $657 million in 2004. Compared with the average hospital stay among males, those for prostate cancer were shorter, though more costly per day, and more likely to occur among older men.
- About half of the men hospitalized principally for prostate cancer were age 45–64, while men age 65–84 accounted for 44 percent of such stays. Men over age 65 accounted for almost 90 percent of stays where prostate cancer was a secondary diagnosis.
- Private insurance and Medicare were the most common sources of payment for hospital stays for prostate cancer—nearly half principally for prostate cancer were billed to private insurance; Medicare was most often billed for stays where prostate cancer was a secondary diagnosis.
- The most common procedures performed during hospital stays principally for prostate cancer were open prostatectomy and transurethral prostatectomy (TURP). The rate of open prostatectomy remained relatively stable from 1997 to 2004, while the rate of TURP decreased.

In 2004, nearly half a million hospital stays in the U.S. involved a diagnosis of prostate cancer. Prostate cancer was principally responsible for about 81,300 hospital stays among males, and it was listed as a secondary diagnosis in about 416,700 hospitalizations. As shown in figure 1, there were 56.2 hospitalizations per 100,000 males in the U.S. principally for prostate cancer in 2004—a nearly 30 percent decrease from 1997, when there were 78.9 hospital stays per 100,000 males. However, hospital stays where prostate cancer was listed as a secondary diagnosis increased about 8 percent over this time period, from 267.8 to 288.3 stays per 100,000 males. This suggests that more men are living with prostate cancer and are being hospitalized for other conditions. In 2004, hospital costs for the treatment of prostate cancer totaled about $657 million.

Figure 1 Hospitalization rate for prostate cancer, 1997–2004

*The denominator is the U.S. male population. U.S. Census Bureau, Population Division, Census 2004.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 1997–2004.

### General characteristics of hospital stays for prostate cancer

Table 1 presents utilization and cost information for the treatment of prostate cancer in U.S. community hospitals compared with all hospital stays among males. On average, hospital stays principally for prostate cancer were about 1.6 days shorter than the average hospitalization for males (3.4 days versus 5.0 days). The average cost for a prostate cancer hospitalization was $8,100—about $700 less than the mean cost for all hospitalizations among males. However, because the average hospital stay for prostate cancer was significantly shorter, these stays resulted in a mean hospital cost per day that was about 33 percent higher than the mean cost per day for all male stays ($2,400 versus $1,800), indicating more intensive treatment.

Table 1 Hospital stays for prostate cancer^*^ compared to hospital stays for all conditions among men, 2004

| Hospital stays for prostate cancer | All male hospital stays
Total number of discharges | 81,300 | 15,773,400
Mean length of stay, days | 3.4 | 5.0
Mean cost per hospitalization | $8,100 | $8,800
Mean cost per day | $2,400 | $1,800
Aggregate costs | $656,992,300 | $137,995,269,600
Mean age | 65.0 | 47.5
Percentage admitted through emergency department | 7.6% | 48.4%
In-hospital deaths | 2.1% | 2.6%

* Based on principal diagnosis.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2004.

With an average age of 65 years, males hospitalized principally for prostate cancer were nearly 18 years older than men hospitalized for all conditions (47.5 years). Although hospital stays for prostate cancer had significantly lower emergency admission rates (7.6 percent versus 48.4 percent), these stays were just as likely to result in an in-hospital death.

### Differences in hospital stays for prostate cancer, by age and payer

Figure 2 illustrates that approximately half (50.4 percent) of the hospital stays principally for prostate cancer occurred among men age 45 to 64, followed closely by men age 65 to 84 (43.5 percent). Together, the 45 to 84 age groups accounted for nearly all hospital admissions for prostate cancer. On the other hand, when examining hospitalizations during which prostate cancer was listed as a secondary diagnosis, the age distribution was older. Men older than 65 years comprised almost 90 percent of hospitalizations where prostate cancer was a secondary diagnosis.

Figure 2 Distribution of hospitalizations for prostate cancer, by age, 2004

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2004.

Figure 3 shows that private insurance and Medicare were the most common sources of payment for charges related to prostate cancer hospitalizations. Private insurance was billed for nearly half (49.0 percent) of charges for admissions principally for prostate cancer, and Medicare was billed for 43.5 percent of these hospital charges. This finding coincides with the age distribution, reflecting the most common sources of payment for men age 45 to 64 and those age 65 to 84. Also reflecting the age distribution noted above, hospital stays with a secondary diagnosis of prostate cancer were predominantly covered by Medicare.

Figure 3 Distribution of hospitalizations for prostate cancer, by payer, 2004

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2004.

### Procedures performed during hospital stays for prostate cancer

Table 2 lists the procedures commonly associated with hospital stays that were principally for prostate cancer. The two most frequent procedures were open prostatectomy and transurethral prostatectomy (TURP). An open prostatectomy is the surgical removal of all or part of the prostate, and is the most common surgical treatment for prostate cancer. TURP—a procedure involving no incision—is most commonly used to treat benign tumors of the prostate, but is also performed on men with prostate cancer when a prostatectomy cannot be performed due to other health factors. Open prostatectomies were performed during 72.2 percent of all hospital stays for prostate cancer, while TURPs were performed during 12.9 percent of these stays. Other common procedures associated with hospitalizations for prostate cancer included blood transfusions (12.9 percent), endoscopy of the urinary tract (6.8 percent), and laproscopy of the gastrointestinal system (4.1 percent).

Table 2 Procedures commonly associated with hospital stays for prostate cancer,^*^ 2004

All-listed procedure | Number of hospital stays with this procedure | Percentage of prostate cancer stays with this procedure
Open prostatectomy | 58,700 | 72.2%
Transurethral prostatectomy (TURP) | 10,500 | 12.9%
Blood transfusion | 10,500 | 12.9%
Endoscopy and endoscopic biopsy of the urinary tract | 5,500 | 6.8%
Laparoscopy (gastrointestinal only) | 3,300 | 4.1%
Therapeutic radiology for cancer treatment | 2,000 | 2.5%
Transurethral excision; drainage; or removal urinary obstruction | 2,000 | 2.5%
Diagnostic procedures; male genital | 1,700 | 2.1%
Insertion of catheter or spinal stimulator and injection into spinal canal | 1,600 | 2.0%
Inguinal and femoral hernia repair | 1,400 | 1.7%

* Based on principal diagnoses.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2004.

Although the hospitalization rate for prostate cancer decreased by nearly 30 percent between 1997 and 2004, the use of an open prostatectomy during inpatient hospitalization remained relatively stable (figure 4). However, the rate of inpatient TURPs performed during this period declined by about 44 percent, decreasing from 117.1 inpatient procedures per 100,000 males in 1997 to 65.8 inpatient procedures per 100,000 males in 2004. This decrease was especially marked between 2001 and 2004, during which time a decrease of about 30 percent was noted. The reduction in the number of TURPs performed in the inpatient hospital setting can be attributed in part to advances in new surgical technologies and favorable payment policies, which allow the use of outpatient facilities for TURPs. Previously published reports indicate that in 2003, approximately 20 percent of TURPs were performed in the outpatient hospital setting, while only about 4 percent of open prostatectomies were outpatient procedures.^5^

Figure 4 Inpatient open prostatectomy and transurethral prostatectomy (TURP) rates, 1997–2004*

*Based on all-listed procedures.

**The denominator is the male population. U.S. Census Bureau, Population Division, Census 2004.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 1997–2004.

### Most common principal reasons for the hospitalization of men with prostate cancer

In 2004, nearly 498,000 hospitalizations occurred among men with prostate cancer; however, the vast majority of these stays were for the principal treatment of other conditions. Table 3 illustrates that about one in six hospital admissions among men with prostate cancer was for the principal treatment of prostate cancer. Approximately 15 percent of all stays among men with prostate cancer were principally for the treatment of five circulatory disorders: coronary atherosclerosis (narrowing of the arteries of the heart)), congestive heart failure, cardiac dysrhythmias, acute myocardial infarction (heart attack), and acute cerebrovascular disease (stroke). Pneumonia and osteoarthritis were also common reasons for hospitalization among men with prostate cancer. Just over 3 percent of patients with prostate cancer were hospitalized with a principal diagnosis of secondary malignancies, or metastatic cancer.

Table 3 Top 10 most common principal reasons for hospitalization among patients with prostate cancer,^*^ 2004

Rank | Principal diagnosis | Number of hospital stays among patients with prostate cancer | Percentage of all hospital stays among patients with prostate cancer
1 | Prostate cancer | 81,300 | 16.3%
2 | Coronary atherosclerosis (narrowing of the arteries of the heart) | 21,500 | 4.3%
3 | Pneumonia | 21,400 | 4.3%
4 | Congestive heart failure; nonhypertensive | 18,300 | 3.7%
5 | Secondary malignancies | 15,300 | 3.1%
6 | Cardiac dysrhythmias | 14,700 | 3.0%
7 | Osteoarthritis | 12,700 | 2.5%
8 | Acute myocardial infarction (heart attack) | 11,800 | 2.4%
9 | Urinary tract infections | 11,000 | 2.2%
10 | Acute cerebrovascular disease (stroke) | 10,600 | 2.1%

* Based on all-listed diagnoses.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2004.

## Data Source

The estimates in this Statistical Brief are based on data from the Healthcare Cost and Utilization Project (HCUP) 2004 Nationwide Inpatient Sample (NIS). Historical data were drawn from the 1997–2004 NIS. Supplemental sources included data on age group population estimates from Table 2: Annual Estimates of the Population by Selected Age Groups and Sex for the United States: April 1, 2000 to July 1, 2005 (NST-EST2005-02) and the archives from the Population Division, U.S. Census Bureau (http://www.census.gov/popest/estimates.php).

## Definitions

### Types of hospitals included in HCUP

HCUP is based on data from community hospitals, defined as short-term, non-Federal, general and other hospitals, excluding hospital units of other institutions (e.g., prisons). HCUP data include OB-GYN, ENT, orthopedic, cancer, pediatric, public, and academic medical hospitals. They exclude long-term care, rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals, but these types of discharges are included if they are from community hospitals.

### Unit of analysis

The unit of analysis is the hospital discharge (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the hospital multiple times in one year will be counted each time as a separate “discharge” from the hospital.

### Costs and charges

Total hospital charges were converted to costs using HCUP cost-to-charge ratios based on hospital accounting reports from the Centers for Medicare and Medicaid Services (CMS).^6^ Costs will tend to reflect the actual costs of production, while charges represent what the hospital billed for the case. For each hospital, a hospital-wide cost-to-charge ratio is used because detailed charges are not available across all HCUP States. Hospital charges reflect the amount the hospital charged for the entire hospital stay and does not include professional (physician) fees. For the purposes of this Statistical Brief, costs are reported to the nearest hundreds.

### Payer

Up to two payers can be coded for a hospital stay in HCUP data. When this occurs, the following hierarchy is used:

– If either payer is listed as Medicaid, the payer is “Medicaid.”
– For non-Medicaid stays, if either payer is listed as Medicare, the payer is “Medicare.”
– For stays that are neither Medicaid nor Medicare, if either payer is listed as private insurance, the payer is “private insurance.”
– For stays that are not Medicaid, Medicare or private insurance, if either payer is some other third-party payer, the payer is “other,” which consists of Worker’s Compensation, TRICARE/CHAMPUS, CHAMPVA, Title V, and other government programs.
– For stays that have no third-party payer and the payer is listed as “self-pay” or “no charge,” the payer is “uninsured.”

### Diagnoses, ICD-9-CM, and Clinical Classifications Software (CCS), and Diagnosis-Related Groups (DRGs)

The principal diagnosis is that condition established after study to be chiefly responsible for the patient’s admission to the hospital. Secondary diagnoses are concomitant conditions that coexist at the time of admission or that develop during the stay. All-listed diagnoses include the principal diagnosis plus these additional secondary conditions.

ICD-9-CM is the International Classification of Diseases, Ninth Revision, Clinical Modification, which assigns numeric codes to diagnoses. There are about 12,000 ICD-9-CM diagnosis codes.

CCS categorizes ICD-9-CM diagnoses into 260 clinically meaningful categories.^7^ This “clinical grouper” makes it easier to quickly understand patterns of diagnoses and procedures.

The following ICD-9-CM diagnosis codes are included in CCS category 29, Prostate Cancer:

– 185 Malignant neoplasm of prostate
– 233.4 Carcinoma in situ of prostate
– V10.46 Personal history of malignant neoplasm—prostate

### Procedures and Clinical Classifications Software (CCS)

The principal procedure is the procedure that was performed for definitive treatment rather than one performed for diagnostic or exploratory purposes (i.e., the procedure that was necessary to take care of a complication). If two procedures appear to meet this definition, the procedure most related to the principal diagnosis was selected as the principal procedure. All-listed procedures include the principal procedure plus any additional secondary procedures.

CCS categorizes procedure codes into clinically meaningful categories. This “clinical grouper” makes it easier to quickly understand patterns of procedure use.

The following ICD-9-CM procedure codes are included in the CCS procedure category 113, Transurethral prostatectomy (TURP):

– 60.2 Transurethral prostatectomy
– 60.21 Transurethral (ultrasound) laser guided induced prostatectomy (TULIP)
– 60.29 Other transurethral prostatectomy
– 60.96 Transurethral destruction of prostate tissue by microwave thermotherapy
– 60.97 Other transurethral destruction of prostate tissue by other thermotherapy

The following ICD-9-CM procedure codes are included in the CCS procedure category 114, Open prostatectomy:

– 60.3 Suprapubic prostatectomy
– 60.4 Retropubic prostatectomy
– 60.5 Radical prostatectomy
– 60.61 Local excision of lesion of prostate
– 60.62 Perineal prostatectomy
– 60.69 Other

## For More Information

For a detailed description of HCUP and more information on the design of the NIS and methods to calculate estimates, please refer to the following publications:

Steiner, C., Elixhauser, A., Schnaier, J. The Healthcare Cost and Utilization Project: An Overview. Effective Clinical Practice 5(3):143–51, 2002.

Design of the HCUP Nationwide Inpatient Sample, 2004. Online. August 8, 2006. U.S. Agency for Healthcare Research and Quality. http://www.hcup-us.ahrq.gov/db/nation/nis/reports/NIS_2004_Design_Report.pdf

Houchens, R., Elixhauser, A. Final Report on Calculating Nationwide Inpatient Sample (NIS) Variances, 2001. HCUP Methods Series Report #2003-2. Online. June 2005 (revised June 6, 2005). U.S. Agency for Healthcare Research and Quality. http://www.hcup-us.ahrq.gov/reports/CalculatingNISVariances200106092005.pdf

Houchens R. L., Elixhauser, A. Using the HCUP Nationwide Inpatient Sample to Estimate Trends. (Updated for 1988–2004). HCUP Methods Series Report #2006-05 Online. August 18, 2006. U.S. Agency for Healthcare Research and Quality. http://www.hcup-us.ahrq.gov/reports/2006_05_NISTrendsReport_1988-2004.pdf

1 National Cancer Institute. A Snapshot of Prostate Cancer. September 2006. http://planning.cancer.gov/disease/Prostate-Snapshot.pdf (Accessed March 19, 2007)

2 Basal cell carcinoma is the most common cancer in men and women. It is a slow-growing skin cancer that is generally noninvasive and easy to treat.

3 Ries LAG, Harkins D, Krapcho M, Mariotto A, Miller BA, Feuer EJ, Clegg L, Eisner MP, Horner MJ, Howlader N, Hayat M, Hankey BF, Edwards BK (eds). SEER Cancer Statistics Review, 1975–2003, National Cancer Institute. Bethesda, MD. http://seer.cancer.gov/csr/1975_2003/ (Accessed March 19, 2007)

4 Wilson LS, Tesoro R, Elkin EP, et al. Cumulative cost pattern comparison of prostate cancer treatments. Cancer 2007; 109:518–527.

5 Russo CA, Owens P, Steiner C, Josephsen J. Ambulatory Surgery in U.S. Hospitals, 2003. Agency for Healthcare Research and Quality, 2007. HCUP Fact Book No. 9. AHRQ Publication No. 07-0007. ISBN 1-58763-228-4.

6 HCUP Cost-to-Charge Ratio Files (CCR). Healthcare Cost and Utilization Project (HCUP). 2001–2003. U.S. Agency for Healthcare Research and Quality, Rockville, MD. www.hcup-us.ahrq.gov/db/state/costtocharge.jsp

7 HCUP CCS. Healthcare Cost and Utilization Project (HCUP). August 2006. U.S. Agency for Healthcare Research and Quality, Rockville, MD. www.hcup-us.ahrq.gov/toolssoftware/ccs/ccs.jsp