# Statistical Brief #281 Overview of Operating Room Procedures During Inpatient Stays in U.S. Hospitals, 2018

## Introduction

More than one-quarter of inpatient stays in the United States involve at least one operating room (OR) procedure.^1^ On average, these stays are more than twice as costly as stays without OR procedures.^1^ With surgical care accounting for nearly one-third of healthcare spending in the United States,^2^ identifying the volume, costs, and characteristics of OR procedures can help guide cost reduction efforts and provide baseline data for assessing the potential impact of changes in reimbursement policy and advances in medical technology.

This Healthcare Cost and Utilization Project (HCUP) Statistical Brief presents statistics on OR procedures performed during inpatient stays using the 2018 National Inpatient Sample (NIS).^a^ Inpatient stays with and without OR procedures are compared in terms of patient characteristics, utilization characteristics, and outcomes. Additionally, the most common all-listed and most costly principal OR procedures are presented overall and by patient sex-age group. Because of the large sample size of the NIS data, small differences can be statistically significant. Thus, only differences greater than or equal to 10 percent are discussed in the text.

## Findings

Highlights

■ In 2018, 9.6 million inpatient stays involved OR procedures, with a total of 14.4 million OR procedures. Stays involving OR procedures totaled $210.3 billion in aggregate costs.
■ Cesarean sections constituted 8.1 percent of all OR procedures, with a rate of 2,001.3 per 100,000 females aged 18–44 years.
■ Appendectomy was the most common and one of the five most costly OR procedures for children, accounting for 4–5 percent of aggregate costs for stays with a principal OR procedure among males and females aged 0–17 years.
■ Spine fusion was the most costly principal OR procedure in 2018, with stays for this procedure totaling $14.1 billion in aggregate costs.
■ Knee arthroplasty and hip arthroplasty were the second and third most costly principal OR procedures by aggregate cost in 2018. Each of these procedures accounted for 4–5 percent of all OR procedures by volume.
■ Ranked by mean cost per stay, heart, lung, and liver transplants were among the five most expensive principal OR procedures in 2018.

### Inpatient stays with and without OR procedures, 2018

Figure 1 shows the percentage of all inpatient stays with OR procedures and the percentage of aggregate costs attributed to stays involving OR procedures in 2018.

Figure 1 Percentage of inpatient stays and aggregate costs for stays with and without OR procedures, 2018

Abbreviation: OR, operating room

Bar chart that shows the percentage of inpatient stays with and without operating room (OR) procedures and aggregate costs attributed to stays with and without OR procedures in 2018. Inpatient stays (N = 35,527,500): 27.0% of inpatient stays with OR procedures and 73.0% of stays without OR procedures. Aggregate costs ($448,811 million): 47.3 percent of costs attributed to stays with OR procedures and 52.7% attributed to stays without OR procedures.

Source: Agency for Healthcare Research and Quality (AHRQ), Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS), 2018

■ Inpatient stays involving OR procedures constituted only about one-fourth of all stays but nearly half of all aggregate hospital costs.
  In 2018, 27.0 percent of inpatient stays involved at least one OR procedure. The costs associated with these stays accounted for 47.3 percent of aggregate costs for all inpatient stays.

Table 1 presents select utilization characteristics and outcomes for 2018 inpatient stays involving OR procedures compared with stays that did not involve OR procedures. Stays with OR procedures may include either those with a principal OR procedure (i.e., where the OR procedure is performed for definitive treatment, for example, appendectomy) or stays with a non-OR principal procedure where an OR procedure is secondary (e.g., principal non-OR procedure of mechanical ventilation with secondary OR procedure of tracheostomy). Table 1 separately presents stays with any OR procedure (principal or secondary) and the subset of stays with a principal OR procedure.

Table 1 Utilization and outcomes for inpatient stays with and without OR procedures, 2018

Characteristic or outcome | Stays with OR procedures | | Stays without OR procedures
Characteristic or outcome | Any OR procedure | Principal OR procedure | Stays without OR procedures
Number of stays, N | 9,605,500 | 8,425,900 | 25,922,000
All hospital stays, % | 27.0 | 23.7 | 73.0
Rate of stays per 100,000 population | 2,941.7 | 2,580.4 | 7,938.6
Aggregate costs, $ millions | 210,312 | 188,512 | 234,498
Aggregate costs, % | 47.3 | 42.4 | 52.7
Mean cost per stay, $ | 21,900 | 22,400 | 9,000
Mean length of stay, days | 5.1 | 5.1 | 4.5
Admitted from emergency department, % | 33.1 | 33.5 | 63.3
Discharge status, %
Routine (to home) or to home healthcare | 82.8 | 81.9 | 79.7
Transfer to another short-term hospital | 0.7 | 0.7 | 2.4
Transfer to other type of facility | 14.8 | 15.8 | 13.8
Died in the hospital | 1.3 | 1.2 | 2.2
Other^*^ | 0.3 | 0.3 | 1.8

Abbreviation: OR, operating room

Notes: Number of stays and mean cost per stay are rounded to the nearest hundred. Discharge status was missing for less than 1 percent of stays.

* Other discharges include alive/destination unknown and against medical advice.

Source: Agency for Healthcare Research and Quality (AHRQ), Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS), 2018

■ In 2018, 9.6 million inpatient stays involved OR procedures, totaling $210.3 billion in aggregate costs.
  Of the 9,605,500 stays with at least one OR procedure, the vast majority (8,425,900) had an OR procedure as the principal procedure. This subset of stays accounted for $188.5 billion in aggregate costs.
■ On average, inpatient stays with OR procedures were longer and more than twice as expensive as stays without OR procedures.
  In 2018, stays involving OR procedures averaged 5.1 days, with an average cost of $21,900. In contrast, stays without OR procedures averaged 4.5 days, with an average cost of $9,000.
  Compared with inpatient stays without OR procedures, a lower percentage of stays involving OR procedures were admitted from the emergency department (33.1 vs. 63.3 percent). Additionally, the percentage of stays that resulted in in-hospital death was lower among stays that involved OR procedures than among stays that did not (1.3 vs. 2.2 percent). Similarly, the percentage of stays transferred to another short-term hospital was lower among stays with OR procedures than among those without OR procedures (0.7 vs. 2.4 percent).

Figure 2 displays the distribution of inpatient stays with and without OR procedures by patient sex, age group, primary expected payer, community-level income quartile, and location of patients’ residence in 2018.

Figure 2 Inpatient stays with and without OR procedures, by patient characteristic, 2018

Abbreviations: Med, medium; metro, metropolitan; OR, operating room; procs, procedures

Note: Community-level income quartile was missing for less than 2 percent of stays and patient location was missing for less than 1 percent of stays.

*Self-pay/No charge: includes self-pay, no charge, charity, and no expected payment.

Bar chart that shows the distribution of inpatient stays with and without operating room (OR) procedures in 2018 by patient sex, age group, primary expected payer, community-level income, and patient location. Data are provided in Supplemental Table 1.

Supplemental Table 1 Inpatient stays with and without OR procedures, by patient characteristic, 2018, for data presented in Figure 2

Characteristic | Stays with OR procs | Stays without OR procs
Sex
Male | 39.0 | 45.7
Female | 61.0 | 54.3
Age, years
0–17 | 3.3 | 19.1
18–44 | 32.2 | 20.6
45–64 | 28.0 | 22.7
65–74 | 19.7 | 14.8
75+ | 16.8 | 22.7
Expected payer
Medicare | 38.3 | 41.9
Medicaid | 17.8 | 24.5
Private insurance | 37.1 | 26.0
Self-pay/No charge^*^ | 3.4 | 4.8
Other | 3.3 | 2.6
Community-level income
Quartile 1 (lowest) | 25.8 | 30.2
Quartile 2 | 26.2 | 26.5
Quartile 3 | 24.7 | 23.0
Quartile 4 (highest) | 21.8 | 18.6
Patient location
Large central metro | 28.8 | 30.4
Large fringe metro | 24.5 | 23.6
Med & small metro | 30.4 | 29.8
Micropolitan & noncore | 15.9 | 15.7

* Self-pay/No charge: includes self-pay, no charge, charity, and no expected payment.

Source: Agency for Healthcare Research and Quality (AHRQ), Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS), 2018

■ Female patients, patients aged 18–74 years, patients with stays billed to private insurance, and patients living in the wealthiest communities represented a higher percentage of stays involving OR procedures than of stays without OR procedures.
  In 2018, the distribution of inpatient stays with and without OR procedures varied by patient sex, patient age, primary expected payer for the stay, and patients’ community-level income but not by patient location. Females accounted for a larger percentage of stays with OR procedures than of stays without OR procedures (61.0 vs. 54.3 percent). The percentage was also higher for stays with versus without OR procedures for patients aged 18–44 years (32.2 vs. 20.6 percent), 45–64 years (28.0 vs. 22.7 percent), and 65–74 years (19.7 vs. 14.8 percent). Stays with a primary expected payer of private insurance represented 37.1 percent of stays with OR procedures but only 26.0 percent of stays without OR procedures. Patients living in the wealthiest communities (quartile 4) constituted 21.8 percent of stays involving OR procedures but only 18.6 percent of stays without OR procedures.

### Most frequent all-listed OR procedures, 2018

Table 2 presents the 20 most common all-listed OR procedures during inpatient stays in 2018. Specifically, the total number of procedures and the population rate are provided, as well as the percentage of all OR procedures and the percentage of stays with an OR procedure that the procedures represent. Because more than one OR procedure can be performed during an inpatient stay, the denominators for these two percentage calculations are distinct.

Table 2 Most frequent all-listed OR procedures, 2018

Rank | All-listed OR procedure | Number of procedures | Rate per 100,000 population | Percent of all OR procedures | Percent of stays with an OR procedure
1 | Cesarean section | 1,167,700 | 357.6 | 8.1 | 12.2
2 | Knee arthroplasty | 715,200 | 219.0 | 5.0 | 7.4
3 | Perineal muscle laceration repair (second-degree or greater obstetrical and other) | 688,400 | 210.8 | 4.8 | 7.2
4 | Hip arthroplasty | 599,500 | 183.6 | 4.2 | 6.2
5 | Percutaneous coronary intervention | 481,800 | 147.5 | 3.4 | 5.0
6 | Spine fusion | 455,500 | 139.5 | 3.2 | 4.7
7 | Cholecystectomy | 335,200 | 102.7 | 2.3 | 3.5
8 | Femur fixation | 307,300 | 94.1 | 2.1 | 3.2
9 | Colectomy | 298,600 | 91.5 | 2.1 | 3.1
10 | Vertebral discectomy | 285,600 | 87.5 | 2.0 | 3.0
11 | Subcutaneous tissue and fascia excision | 241,100 | 73.8 | 1.7 | 2.5
12 | Gastrointestinal system lysis of adhesions | 238,000 | 72.9 | 1.7 | 2.5
13 | Bone excision | 227,700 | 69.7 | 1.6 | 2.4
14 | Saphenous vein harvest and other therapeutic vessel removal | 223,900 | 68.6 | 1.6 | 2.3
15 | Fallopian tube ligation and excision | 223,000 | 68.3 | 1.6 | 2.3
16 | Angioplasty and related vessel procedures (endovascular; excluding carotid) | 201,800 | 61.8 | 1.4 | 2.1
17 | Coronary artery bypass graft | 201,600 | 61.7 | 1.4 | 2.1
18 | Salpingectomy | 191,200 | 58.6 | 1.3 | 2.0
19 | Appendectomy | 190,000 | 58.2 | 1.3 | 2.0
20 | Musculoskeletal procedures, not elsewhere classified | 184,800 | 56.6 | 1.3 | 1.9
Top 20 OR procedures (6,501,000 stays) | | 7,457,900 | 2,284.0 | 51.9 | 67.7
All OR procedures (9,605,500 stays) | | 14,365,200 | 4,399.3 | 100.0 | 100.0

Abbreviations: ICD-10-PCS, International Classification of Diseases, Tenth Revision, Procedure Coding System; OR, operating room

Notes: Number of procedures is rounded to the nearest hundred. Percentage is based on unrounded data values. Procedures were identified using the Clinical Classifications Software Refined (CCSR) for ICD-10-PCS Procedures. Procedure totals include only one occurrence of a CCSR category per inpatient stay because multiple codes may be used for related procedures performed during a single operation. The overall number of procedures represents the sum of all CCSR category totals. Although some procedures are specific to the female population (e.g., cesarean section and perineal muscle laceration repair), the population denominator used to calculate the rate includes both sexes.

Source: Agency for Healthcare Research and Quality (AHRQ), Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS), 2018

■ The 20 most frequent OR procedures accounted for more than half of OR procedures in 2018.
  In 2018, there were 14,365,200 total OR procedures (4,399.3 per 100,000 population) performed during 9,605,500 total inpatient stays. The 20 most frequent OR procedures represented 7,457,900 of these procedures (51.9 percent)—a rate of 2,284.0 per 100,000 population. Inpatient stays involving 1 or more of the 20 most frequent OR procedures accounted for 6,501,000 stays, or 67.7 percent of the 9,605,500 stays with at least one OR procedure.
■ Cesarean sections constituted 8.1 percent of all OR procedures. Knee arthroplasty, perineal muscle laceration repair, and hip arthroplasty each accounted for 4–5 percent.
  Along with cesarean section, which represented 8.1 percent of all procedures, three other obstetric/gynecological procedures were among the top 20 procedures in 2018: perineal muscle laceration repair (second-degree or greater obstetrical tear/laceration or other), fallopian tube ligation (i.e., closing off) and excision (i.e., partial removal), and salpingectomy (i.e., removal or resection of fallopian tubes). Combined, these four procedures accounted for 15.8 percent of all OR procedures.
  Eight musculoskeletal procedures constituted 21.0 percent of all OR procedures: knee arthroplasty (i.e., reconstruction or replacement), hip arthroplasty, spine fusion, femur fixation (i.e., stabilization of broken bone), vertebral discectomy (i.e., removal of all or part of the damaged disc), excision of subcutaneous tissue and fascia (i.e., connective tissue covering muscle, bone, and other organs), bone excision, and musculoskeletal procedures not elsewhere classified.
  Four cardiovascular procedures constituted 7.7 percent of all OR procedures: percutaneous coronary intervention (PCI), saphenous vein (i.e., large leg vein) harvest and other therapeutic vessel removal, angioplasty and related vessel procedures, and coronary artery bypass graft (CABG).
  Four procedures related to diseases of the gastrointestinal (GI) system accounted for 7.4 percent of all OR procedures: cholecystectomy (i.e., removal of the gallbladder), colectomy (i.e., removal of all or part of the colon), GI system lysis of adhesions (i.e., cutting of fibrous bands of scar tissue), and appendectomy.

Table 3 presents the five most common all-listed OR procedures during inpatient stays by sex-age group in 2018.

Table 3 Most frequent all-listed OR procedures by sex-age group, 2018

Males | | | | Females
Rank | All-listed OR procedure | Number of OR procedures | Rate per 100,000 population | Rank | All-listed OR procedure | Number of OR procedures | Rate per 100,000 population
Ages 0–17 years | | 270,100 | 717.3 | Ages 0–17 years | | 228,500 | 633.3
1 | Appendectomy | 26,000 | 69.1 | 1 | Appendectomy | 17,400 | 48.1
2 | Bone fixation excluding extremities | 8,800 | 23.4 | 2 | Perineal muscle laceration repair^*^ | 9,700 | 26.8
3 | Musculoskeletal procedures, not elsewhere classified | 8,500 | 22.6 | 3 | Spine fusion | 8,800 | 24.4
4 | Upper GI therapeutic procedures, not elsewhere classified | 8,500 | 22.6 | 4 | Bone fixation, excluding extremities | 8,100 | 22.3
5 | Femur fixation | 8,300 | 22.0 | 5 | Cesarean section | 7,700 | 21.4
Ages 18–44 years | | 818,500 | 1,386.4 | Ages 18–44 years | | 3,328,700 | 5,769.3
1 | Fixation of leg and foot bones | 34,100 | 57.7 | 1 | Cesarean section | 1,154,700 | 2,001.3
2 | Appendectomy | 33,300 | 56.4 | 2 | Perineal muscle laceration repair^*^ | 676,500 | 1,172.5
3 | Subcutaneous tissue and fascia excision | 29,500 | 50.0 | 3 | Fallopian tube ligation, excision | 216,600 | 375.4
4 | Bone excision | 28,900 | 48.9 | 4 | Salpingectomy | 84,100 | 145.8
5 | Spine fusion | 27,900 | 47.2 | 5 | Cholecystectomy | 77,300 | 134.0
Ages 45–64 years | | 2,233,000 | 5,432.3 | Ages 45–64 years | | 2,202,400 | 5,102.5
1 | PCI | 146,400 | 356.2 | 1 | Knee arthroplasty | 164,200 | 380.5
2 | Knee arthroplasty | 110,500 | 268.8 | 2 | Spine fusion | 103,100 | 238.9
3 | Hip arthroplasty | 99,400 | 241.9 | 3 | Hip arthroplasty | 99,200 | 229.7
4 | Spine fusion | 96,000 | 233.6 | 4 | Hysterectomy | 77,200 | 178.8
5 | Vertebral discectomy | 65,000 | 158.1 | 5 | Salpingectomy | 76,000 | 176.1
Ages 65–74 years | | 1,512,800 | 10,568.3 | Ages 65–74 years | | 1,454,300 | 8,930.9
1 | Knee arthroplasty | 107,100 | 748.3 | 1 | Knee arthroplasty | 170,200 | 1,045.0
2 | PCI | 90,800 | 634.2 | 2 | Hip arthroplasty | 112,100 | 688.3
3 | Hip arthroplasty | 77,800 | 543.8 | 3 | Spine fusion | 66,800 | 410.4
4 | Spine fusion | 61,400 | 428.6 | 4 | PCI | 46,600 | 286.0
5 | Saphenous vein harvest^†^ | 60,000 | 418.9 | 5 | Colectomy | 42,600 | 261.5
Age 75+ years | | 1,065,500 | 12,330.6 | Age 75+ years | | 1,248,400 | 9,958.1
1 | PCI | 69,500 | 804.2 | 1 | Hip arthroplasty | 127,000 | 1,012.8
2 | Hip arthroplasty | 65,000 | 752.7 | 2 | Femur fixation | 122,100 | 974.0
3 | Knee arthroplasty | 57,000 | 659.2 | 3 | Knee arthroplasty | 96,300 | 768.0
4 | Femur fixation | 42,900 | 496.8 | 4 | PCI | 51,400 | 410.0
5 | Saphenous vein harvest^†^ | 32,900 | 380.8 | 5 | Colectomy | 38,700 | 308.5

Abbreviations: GI, gastrointestinal; ICD-10-PCS, International Classification of Diseases, Tenth Revision, Procedure Coding System; OR, operating room; PCI, percutaneous coronary intervention

Notes: Number of procedures is rounded to the nearest hundred. Procedures were identified using the Clinical Classifications Software Refined (CCSR) for ICD-10-PCS Procedures. Procedure totals include only one occurrence of a CCSR category per inpatient stay because multiple codes may be used for related procedures performed during a single operation. The overall number of procedures represents the sum of all CCSR category totals. The population denominators used to calculate rates are sex and age-group specific.

* Includes second-degree obstetrical and other repair.

† Includes other therapeutic vessel removal, such as destruction of superior vena cava and excision of coronary vein.

Source: Agency for Healthcare Research and Quality (AHRQ), Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS), 2018

■ Procedures related to diseases of the GI system were among the most common OR procedures for males and females in the two youngest age groups (0–17 and 18–44 years).
  Appendectomy ranked in the top five procedures for both males and females aged 17 years and younger (69.1 per 100,000 males and 48.1 per 100,000 females), as well as for males aged 18–44 years (56.4 per 100,000). Another procedure group related to GI diseases—upper GI therapeutic procedures, not elsewhere classified—was among the five most common procedures for males aged 0–17 years (22.6 per 100,000). Cholecystectomy was among the top five procedures for females aged 18–44 years (134.0 per 100,000).
■ Obstetric/gynecological procedures were among the most frequent procedures for females in the groups aged 0–17, 18–44, and 45–64 years.
  Cesarean section was the top OR procedure for females aged 18–44 years, with the highest rate observed for any OR procedure across sex-age groups—2,001.3 per 100,000 females. Cesarean section was also among the five most common OR procedures for females aged 17 years or younger, but the rate among this group was relatively low (21.4 per 100,000).
  Four other obstetric/gynecological procedures ranked in the top five OR procedures for specific female age groups: perineal muscle laceration repair for ages 0–17 years (26.8 per 100,000) and 18–44 years (1,172.5 per 100,000), fallopian tube ligation and excision for ages 18–44 years (375.4 per 100,000), hysterectomy for ages 45–64 years (178.8 per 100,000), and salpingectomy for ages 18–44 years (145.8 per 100,000) and 45–64 years (176.1 per 100,000).
■ For adults in the three older age groups (45–64, 65–74, and 75+ years), cardiovascular and musculoskeletal procedures were among the most common OR procedures.
  PCI was common among adults aged 45+ years and occurred in the top five OR procedures for both males and females in each of the three older age groups (except for females aged 45–64 years). PCI rates increased with age for both sexes, and population rates for males were roughly double the corresponding rates for females (634.2 vs. 286.0 per 100,000 population for ages 65–74 years and 804.2 vs. 410.0 per 100,000 for ages 75+ years).
  Hip arthroplasty and knee arthroplasty also ranked among the top OR procedures for both females and males in the three older age groups. The population rate of both procedures was always higher for females than for males (except that hip arthroplasty for ages 45–64 years was similar for males and females). For knee arthroplasty, the difference between the sexes was greater among those aged 45–64 and 65–74 years (40–42 percent higher for females than for males) than among those aged 75+ years (16.5 percent higher for females).

### Most costly principal OR procedures during inpatient stays, 2018

Because hospital costs represent an overall inpatient stay and are not specific to a single procedure, the following tables focus on OR procedures that are the principal procedure for the stay. Because a stay has only one principal procedure, the total number of stays with a principal procedure is equivalent to the total number of principal procedures.

Table 4 presents the 20 most costly principal OR procedures in 2018. For stays with each principal OR procedure, the aggregate cost, mean cost per stay, and total number of stays are presented. OR procedures are ranked by aggregate cost on the left side of the table and by mean cost per stay on the right side. Stays with a non-OR principal procedure, including those involving an OR procedure (e.g., principal procedure of spontaneous vaginal delivery with secondary procedure of perineal muscle laceration repair), are excluded.

Table 4 Most costly stays with a principal OR procedure, 2018

Ranked by aggregate cost | | | | | Ranked by mean cost per stay
Rank | Principal OR procedure | Aggregate cost, $ millions | Mean cost per stay, $ | Number of stays | Rank | Principal OR procedure | Aggregate cost, $ millions | Mean cost per stay, $ | Number of stays
1 | Spine fusion | 14,145 | 33,800 | 418,700 | 1 | Heart transplant | 1,012 | 304,300 | 3,300
2 | Knee arthroplasty | 11,877 | 16,800 | 705,100 | 2 | Lung transplant | 476 | 220,700 | 2,200
3 | Hip arthroplasty | 10,468 | 17,700 | 591,700 | 3 | Heart and great vessel bypass | 738 | 159,100 | 4,600
4 | PCI | 9,391 | 23,500 | 399,000 | 4 | Liver transplant | 1,119 | 149,400 | 7,500
5 | Cesarean section | 8,598 | 7,500 | 1,150,200 | 5 | Heart assist device procs | 1,924 | 128,400 | 15,000
6 | CABG | 7,322 | 46,800 | 156,600 | 6 | Tracheostomy | 3,583 | 107,600 | 33,300
7 | Colectomy | 6,080 | 25,900 | 234,600 | 7 | Ventriculostomy (percutaneous) | 861 | 67,200 | 12,800
8 | Heart valve replacement (non-endovascular)^*^ | 5,627 | 60,400 | 93,200 | 8 | Kidney transplant | 1,326 | 65,600 | 20,200
9 | Femur fixation | 5,455 | 20,000 | 272,500 | 9 | Heart valve replacement (non-endovascular)^*^ | 5,627 | 60,400 | 93,200
10 | Cholecystectomy | 4,332 | 15,100 | 286,500 | 10 | Septal repair^†^ | 971 | 60,300 | 16,100
11 | Angioplasty^‡^ | 4,010 | 31,600 | 126,900 | 11 | Vessel repair, replacement | 1,523 | 58,900 | 25,800
12 | Tracheostomy | 3,583 | 107,600 | 33,300 | 12 | Select CNS drainage procs^§^ | 758 | 54,800 | 13,800
13 | Heart valve replacement (endovascular)^*^ | 3,440 | 48,100 | 71,600 | 13 | Other coronary artery procs (not PCI or CABG) | 165 | 50,600 | 3,300
14 | Aneurysm repair | 2,839 | 44,100 | 64,300 | 14 | Esophagectomy | 197 | 50,000 | 4,000
15 | Subcutaneous tissue and fascia excision | 2,789 | 19,700 | 141,800 | 15 | Heart valve replacement (endovascular)^*^ | 3,440 | 48,100 | 71,600
16 | Arthroplasty of joint other than knee or hip | 2,768 | 19,300 | 143,100 | 16 | CABG | 7,322 | 46,800 | 156,600
17 | Pacemaker, defibrillator procs | 2,703 | 40,900 | 66,100 | 17 | Decompressive craniectomy | 437 | 46,700 | 9,400
18 | Fixation of leg and foot bones | 2,673 | 20,000 | 133,600 | 18 | Ligation and embolization of vessels | 2,133 | 46,500 | 45,900
19 | CNS excision procs | 2,587 | 36,600 | 70,700 | 19 | Gastrostomy | 193 | 44,300 | 4,400
20 | Small bowel resection | 2,322 | 29,600 | 78,400 | 20 | Aneurysm repair | 2,839 | 44,100 | 64,300
Top 20 | | 113,009 | 21,600 | 5,237,900 | Top 20 | | 36,646 | 60,400 | 607,200
All principal OR procs | | 188,512 | 22,400 | 8,425,900 | All principal OR procs | | 188,512 | 22,400 | 8,425,900

Abbreviations: CABG, coronary artery bypass graft; CNS, central nervous system; ICD-10-PCS, International Classification of Diseases, Tenth Revision, Procedure Coding System; OR, operating room; PCI, percutaneous coronary intervention; procs, procedures

Notes: A minimum volume threshold of 1,000 stays was applied for top procedures by mean cost. Mean cost per stay and number of stays are rounded to the nearest hundred. Procedures were identified using the Clinical Classifications Software Refined (CCSR) for ICD-10-PCS Procedures.

* Includes heart valve replacement and other valve procedures.

† Includes septal repair and other therapeutic heart procedures.

‡ Includes angioplasty and related vessel procedures (endovascular, excluding carotid).

§ Includes CNS drainage procedures other than minimally invasive CNS biopsy, lumbar puncture, spinal canal and spinal cord drainage, intracranial epidural and subdural space drainage, and percutaneous ventriculostomy.

Source: Agency for Healthcare Research and Quality (AHRQ), Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS), 2018

■ Ranked by aggregate cost, the three most costly principal OR procedures in 2018 were spine fusion, knee arthroplasty, and hip arthroplasty.
  Three musculoskeletal procedures—spine fusion, knee arthroplasty, and hip arthroplasty—were the three most costly OR procedures in 2018, with stays for these procedures totaling $14.1 billion, $11.9 billion, and $10.5 billion in aggregate costs, respectively. Four other musculoskeletal procedures also ranked in the top 20 OR procedures by highest aggregate cost: femur fixation ($5.5 billion), subcutaneous tissue and fascia excision ($2.8 billion), arthroplasty of joint other than knee and hip ($2.8 billion), and fixation of leg and foot bones ($2.7 billion). Together, stays for these seven musculoskeletal procedures accounted for more than one-fourth (26.6 percent) of aggregate costs for all stays with a principal OR procedure.
  Seven cardiovascular procedures ranked among the 20 most costly principal OR procedures in 2018: PCI ($9.4 billion), CABG ($7.3 billion), non-endovascular heart valve replacement and other valve procedures ($5.6 billion), angioplasty ($4.0 billion), endovascular (i.e., performed through or inside of blood vessels) heart valve replacement and other valve procedures ($3.4 billion), aneurysm repair ($2.8 billion), and pacemaker and defibrillator procedures ($2.7 billion). Combined, stays for these seven cardiovascular procedures represented 18.7 percent of aggregate costs for all stays with a principal OR procedure.
■ Ranked by mean cost per stay, heart, lung, and liver transplants were among the five most expensive principal OR procedures in 2018.
  With a mean cost per stay of $304,300, heart transplant was the most expensive of all principal OR procedures associated with at least 1,000 inpatient stays in 2018. Lung, liver, and kidney transplants were also among the 20 most expensive principal OR procedures, with mean costs of $220,700, $149,400, and $65,600 per stay, respectively.
  In addition to heart transplants, 10 other cardiovascular procedures were among the 20 most expensive principal OR procedures in 2018. The mean cost per stay exceeded $100,000 for two of these procedures: heart and great vessel bypass ($159,100 per stay) and heart assist device procedures ($128,400 per stay).

Table 5 presents by sex-age group the five most costly principal OR procedures during inpatient stays in 2018, based on aggregate cost. Aggregate cost, percentage of aggregate costs for all principal OR procedure stays, and number of stays are provided. Stays with a non-OR principal procedure are excluded.

Table 5 Most costly stays with a principal OR procedure by sex-age group, 2018

Males | | | | | Females
Rank | Principal OR procedure | Aggregate cost, $ millions | Percent of all aggregate costs | Number of stays | Rank | Principal OR procedure | Aggregate cost, $ millions | Percent of all aggregate costs | Number of stays
Ages 0–17 years | | 6,201 | 100.0 | 153,400 | Ages 0–17 years | | 5,014 | 100.0 | 127,200
1 | Heart and great vessel bypass | 406 | 6.6 | 2,500 | 1 | Spine fusion | 472 | 9.4 | 8,300
2 | Tracheostomy | 338 | 5.5 | 1,000 | 2 | Heart and great vessel bypass | 302 | 6.0 | 1,700
3 | Appendectomy | 298 | 4.8 | 23,800 | 3 | Septal repair^*^ | 295 | 5.9 | 3,700
4 | Septal repair^*^ | 285 | 4.6 | 3,500 | 4 | Tracheostomy | 220 | 4.4 | 700
5 | Spine fusion | 252 | 4.1 | 4,100 | 5 | Appendectomy | 194 | 3.9 | 15,500
Ages 18–44 years | | 12,082 | 100.0 | 463,300 | Ages 18–44 years | | 20,104 | 100.0 | 1,798,500
1 | Spine fusion | 851 | 7.0 | 24,400 | 1 | Cesarean section | 8,491 | 42.2 | 1,137,500
2 | Fixation of leg and foot bones | 567 | 4.7 | 25,500 | 2 | Cholecystectomy | 858 | 4.3 | 70,300
3 | Bone fixation^†^ | 446 | 3.7 | 16,700 | 3 | Spine fusion | 742 | 3.7 | 23,900
4 | Femur fixation | 443 | 3.7 | 14,300 | 4 | Gastrectomy | 678 | 3.4 | 59,800
5 | Colectomy | 429 | 3.5 | 15,800 | 5 | Hysterectomy | 521 | 2.6 | 46,700
Ages 45–64 years | | 34,925 | 100.0 | 1,309,400 | Ages 45–64 years | | 27,770 | 100.0 | 1,244,200
1 | Spine fusion | 2,852 | 8.2 | 87,600 | 1 | Spine fusion | 2,940 | 10.6 | 95,200
2 | PCI | 2,766 | 7.9 | 123,200 | 2 | Knee arthroplasty | 2,718 | 9.8 | 162,100
3 | CABG | 2,204 | 6.3 | 49,100 | 3 | Hip arthroplasty | 1,702 | 6.1 | 98,200
4 | Knee arthroplasty | 1,856 | 5.3 | 108,700 | 4 | Colectomy | 1,066 | 3.8 | 45,700
5 | Hip arthroplasty | 1,716 | 4.9 | 98,400 | 5 | PCI | 1,038 | 3.7 | 46,000
Ages 65–74 years | | 24,147 | 100.0 | 905,700 | Ages 65–74 years | | 20,857 | 100.0 | 895,700
1 | CABG | 2,060 | 8.5 | 44,800 | 1 | Knee arthroplasty | 2,782 | 13.3 | 168,500
2 | Spine fusion | 1,990 | 8.2 | 56,800 | 2 | Spine fusion | 2,117 | 10.2 | 62,300
3 | PCI | 1,790 | 7.4 | 74,800 | 3 | Hip arthroplasty | 1,905 | 9.1 | 110,900
4 | Knee arthroplasty | 1,768 | 7.3 | 105,600 | 4 | PCI | 939 | 4.5 | 38,600
5 | Hip arthroplasty | 1,333 | 5.5 | 77,000 | 5 | Colectomy | 826 | 4.0 | 33,900
Age 75+ years | | 18,084 | 100.0 | 684,400 | Age 75+ years | | 19,308 | 100.0 | 843,300
1 | PCI | 1,393 | 7.7 | 55,400 | 1 | Hip arthroplasty | 2,267 | 11.7 | 124,800
2 | Heart valve replacement (endovascular)^‡^ | 1,274 | 7.0 | 26,800 | 2 | Femur fixation | 2,023 | 10.5 | 113,500
3 | Hip arthroplasty | 1,201 | 6.6 | 63,900 | 3 | Knee arthroplasty | 1,612 | 8.4 | 95,100
4 | CABG | 1,118 | 6.2 | 22,400 | 4 | Heart valve replacement (endovascular)^‡^ | 1,147 | 5.9 | 24,500
5 | Knee arthroplasty | 949 | 5.2 | 56,100 | 5 | PCI | 1,041 | 5.4 | 41,400

Abbreviations: CABG, coronary artery bypass graft; ICD-10-PCS, International Classification of Diseases, Tenth Revision, Procedure Coding System; OR, operating room; PCI, percutaneous coronary intervention

Notes: Number of stays is rounded to the nearest hundred. Percentage is based on unrounded data values. Procedures were identified using the Clinical Classifications Software Refined (CCSR) for ICD-10-PCS Procedures.

* Includes septal repair and other therapeutic heart procedures.

† Excludes extremities.

‡ Includes heart valve replacement and other valve procedures (endovascular).

Source: Agency for Healthcare Research and Quality (AHRQ), Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS), 2018

■ In 2018, spine fusion was one of the five most costly principal OR procedures for both males and females in all age groups younger than 75 years.
  Spine fusion was among the top five most costly principal OR procedures for all but the oldest age group (75+ years). Across sex-age groups, the aggregate cost of stays for spine fusion ranged from $252 million among males aged 0–17 years to $2.9 billion among females aged 45–64 years.
  For males aged 18–44 years, three other musculoskeletal procedures ranked in the top five most costly principal OR procedures: fixation of leg and foot bones ($567 million); bone fixation, excluding extremities ($446 million); and femur fixation ($443 million). Together with stays for spine fusion, stays for these musculoskeletal procedures accounted for 19.1 percent of costs for all stays with a principal OR procedure among this sex-age group.
  Hip arthroplasty and knee arthroplasty were among the most costly principal OR procedures for both males and females in the three older age groups. For males aged 45–64, 65–74, and 75+ years, stays for hip and knee arthroplasty combined accounted for 10–13 percent of aggregate costs for all stays with a principal OR procedure. Hip and knee arthroplasty combined constituted an even higher percentage of aggregate costs for females in the three older age groups (16–22 percent).
■ For individuals in the two younger age groups (0–17 and 18–44 years), procedures related to GI diseases were among the most costly principal OR procedures.
  Among children (ages 0–17 years), appendectomy was one of the principal OR procedures with the highest aggregate costs. Stays for this procedure totaled $298 million for males and $194 million for females in the youngest age group (4–5 percent of aggregate costs for stays with a principal OR procedure among the sex-age groups).
  Other procedures related to GI diseases ranked in the top five most costly OR procedures for individuals aged 18–44 years. These included colectomy for males ($429 million) and cholecystectomy and gastrectomy (i.e., removal of part or all of the stomach) for females ($858 and $678 million, respectively).
■ Cardiovascular procedures were among the most costly principal OR procedures for adults in the older age groups (45–64, 65–74, and 75+ years).
  CABG and PCI ranked in the five most costly principal OR procedures for males aged 45–64, 65–74, and 75+ years. Stays for these two procedures combined constituted 14–16 percent of costs for all stays with OR procedures among these male age groups. PCI was also one of the five most costly procedures for females in the three older age groups, accounting for 4–5 percent of aggregate costs for stays with a principal OR procedure.
  Heart valve replacement and other valve procedures (endovascular) also ranked in the five most costly principal OR procedures for males and females aged 75+ years, accounting for 6–7 percent of aggregate costs for stays with a principal OR procedure among these groups.

## References

1 McDermott KW, Freeman WJ, Elixhauser A. Overview of Operating Room Procedures During Inpatient Stays in U.S. Hospitals, 2014. HCUP Statistical Brief #233. December 2017. Agency for Healthcare Research and Quality, Rockville, MD. www.hcup-us.ahrq.gov/reports/statbriefs/sb233-Operating-Room-Procedures-United-States-2014.pdf. Accessed March 5, 2021.
2 Muñoz E, Muñoz W III, Wise L. National and surgical health care expenditures, 2005–2025. Annals of Surgery. 2010;251(2):195–200.20054269

## About Statistical Briefs

Healthcare Cost and Utilization Project (HCUP) Statistical Briefs provide basic descriptive statistics on a variety of topics using HCUP administrative healthcare data. Topics include hospital inpatient, ambulatory surgery, and emergency department use and costs, quality of care, access to care, medical conditions, procedures, and patient populations, among other topics. The reports are intended to generate hypotheses that can be further explored in other research; the reports are not designed to answer in-depth research questions using multivariate methods.

## Data Source

The estimates in this Statistical Brief are based upon data from the HCUP 2018 National Inpatient Sample (NIS). Supplemental sources included population denominator data for use with HCUP databases, derived from information available from Claritas, a vendor that produces population estimates and projections based on data from the U.S. Census Bureau.^b^

## Definitions

### Procedures, ICD-10-PCS, Clinical Classifications Software Refined (CCSR) for ICD-10-PCS Procedures, diagnosis-related groups (DRGs), Procedure Classes

All-listed procedures include all procedures performed during the hospital stay, whether for definitive treatment or for diagnostic or exploratory purposes. The first-listed procedure is the procedure that is listed first on the discharge record. Inpatient data define this as the principal procedure—the procedure that is performed for definitive treatment rather than for diagnostic or exploratory purposes (i.e., the procedure that was necessary to take care of a complication).

ICD-10-PCS is the International Classification of Diseases, Tenth Revision, Procedure Coding System, which went into effect on October 1, 2015. There are over 75,000 ICD-10-PCS procedure codes.

The CCSR aggregates ICD-10-PCS procedure codes into a manageable number of clinically meaningful categories.^c^ The CCSR is intended to be used analytically to examine patterns of healthcare in terms of cost, utilization, and outcomes, as well as to perform rank utilization by procedures. ICD-10-PCS coding definitions for each CCSR category presented in this Statistical Brief can be found in the CCSR reference file, available at www.hcup-us.ahrq.gov/toolssoftware/ccsr/prccsr.jsp. For this Statistical Brief, v2021.1 of the CCSR was used.

DRGs comprise a patient classification system that categorizes patients into groups that are clinically coherent and homogeneous with respect to resource use. DRGs group patients according to diagnosis, type of treatment (procedure), age, and other relevant criteria. Each hospital stay has one assigned DRG.

Major operating room (OR) procedures were defined using the Procedure Classes Refined for ICD-10-PCS software, which categorizes each ICD-10-PCS procedure code as either major therapeutic, major diagnostic, minor therapeutic, or minor diagnostic.^d^ If at least one major diagnostic or major therapeutic procedure was on a hospital record, the hospital stay was classified as involving a major OR procedure.

### Unit of analysis

The unit of analysis is the hospital discharge (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the hospital multiple times in 1 year will be counted each time as a separate discharge from the hospital.

### Population rates

Rates of stays per 100,000 population were calculated using 2018 hospital discharge totals in the numerator and Claritas^e^ estimates of the corresponding 2018 U.S. population (e.g., the population for a specific sex-age group) in the denominator. Individuals hospitalized multiple times are counted more than once in the numerator.

Population rate of stays = ( (number of stays among patients in group)/(number of U.S. residents in group) ) × 100,000

### Costs and charges

Total hospital charges were converted to costs using HCUP Cost-to-Charge Ratios based on hospital accounting reports from the Centers for Medicare & Medicaid Services (CMS).^f^ Costs reflect the actual expenses incurred in the production of hospital services, such as wages, supplies, and utility costs; charges represent the amount a hospital billed for the case. For each hospital, a hospital-wide cost-to-charge ratio is used. Hospital charges reflect the amount the hospital billed for the entire hospital stay and do not include professional (physician) fees. For the purposes of this Statistical Brief, missing charges were imputed using the mean charge for the DRG before converting charges to costs. Costs are reported to the nearest hundred dollars.

### How HCUP estimates of costs differ from National Health Expenditure Accounts

There are a number of differences between the costs cited in this Statistical Brief and spending as measured in the National Health Expenditure Accounts (NHEA), which are produced annually by CMS.^g^ The largest source of difference comes from the HCUP coverage of inpatient treatment only in contrast to the NHEA inclusion of outpatient costs associated with emergency departments and other hospital-based outpatient clinics and departments as well. The outpatient portion of hospitals’ activities has been growing steadily and may exceed half of all hospital revenue in recent years. On the basis of the American Hospital Association Annual Survey, 2018 outpatient gross revenues (or charges) were about 49 percent of total hospital gross revenues.^h^

Smaller sources of differences come from the inclusion in the NHEA of hospitals that are excluded from HCUP. These include Federal hospitals (Department of Defense, Veterans Administration, Indian Health Services, and Department of Justice [prison] hospitals) as well as psychiatric, substance abuse, and long-term care hospitals. A third source of difference lies in the HCUP reliance on billed charges from hospitals to payers, adjusted to provide estimates of costs using hospital-wide cost-to-charge ratios, in contrast to the NHEA measurement of spending or revenue. HCUP costs estimate the amount of money required to produce hospital services, including expenses for wages, salaries, and benefits paid to staff as well as utilities, maintenance, and other similar expenses required to run a hospital. NHEA spending or revenue measures the amount of income received by the hospital for treatment and other services provided, including payments by insurers, patients, or government programs. The difference between revenues and costs includes profit for for-profit hospitals or surpluses for nonprofit hospitals.

### Location of patients’ residence

Place of residence is based on the urban-rural classification scheme for U.S. counties developed by the National Center for Health Statistics (NCHS) and based on the Office of Management and Budget (OMB) definition of a metropolitan service area as including a city and a population of at least 50,000 residents:

- Large Central Metropolitan: Counties in a metropolitan area with 1 million or more residents that satisfy at least one of the following criteria: (1) containing the entire population of the largest principal city of the metropolitan statistical area (MSA), (2) having their entire population contained within the largest principal city of the MSA, or (3) containing at least 250,000 residents of any principal city in the MSA
- Large Fringe Metropolitan: Counties in a metropolitan area with 1 million or more residents that do not qualify as large central metropolitan counties
- Medium Metropolitan: Counties in a metropolitan area of 250,000–999,999 residents
- Small Metropolitan: Counties in a metropolitan area of 50,000–249,999 residents
- Micropolitan: Counties in a nonmetropolitan area of 10,000–49,999 residents
- Noncore: Counties in a nonmetropolitan and nonmicropolitan area

For this Statistical Brief, we combined the medium and small metropolitan categories and the micropolitan and noncore categories.

### Community-level income

Community-level income is based on the median household income of the patient’s ZIP Code of residence. Quartiles are defined so that the total U.S. population is evenly distributed. Cut-offs for the quartiles are determined annually using ZIP Code demographic data obtained from Claritas, a vendor that produces population estimates and projections based on data from the U.S. Census Bureau.^i^ The value ranges for the income quartiles vary by year. The income quartile is missing for patients who are homeless or foreign.

### Expected payer

To make coding uniform across all HCUP data sources, the primary expected payer for the hospital stay combines detailed categories into general groups:

- Medicare: includes fee-for-service and managed care Medicare
- Medicaid: includes fee-for-service and managed care Medicaid
- Private insurance: includes commercial nongovernmental payers, regardless of the type of plan (e.g., private health maintenance organizations [HMOs], preferred provider organizations [PPOs])
- Self-pay/No charge: includes self-pay, no charge, charity, and no expected payment
- Other payers: includes other Federal and local government programs (e.g., TRICARE, CHAMPVA, Indian Health Service, Black Lung, Title V) and Workers’ Compensation

Hospital stays that were expected to be billed to the State Children’s Health Insurance Program (SCHIP) are included under Medicaid.

For this Statistical Brief, when more than one payer is listed for a hospital discharge, the first-listed payer is used.

### Admission source or point of origin

Admission source (now known as the patient’s point of origin) indicates where the patient was located prior to admission to the hospital. Emergency admission indicates that the patient was admitted to the hospital through the emergency department.

### Discharge status

Discharge status reflects the disposition of the patient at discharge from the hospital and includes the following five categories: routine (to home) or to home healthcare; transfer to another short-term hospital; other transfers (including skilled nursing facility, intermediate care, and another type of facility such as a nursing home); died in the hospital; or other (including against medical advice [AMA] or discharge alive, destination unknown).

## About HCUP

The Healthcare Cost and Utilization Project (HCUP, pronounced “H-Cup”) is a family of healthcare databases and related software tools and products developed through a Federal-State-Industry partnership and sponsored by the Agency for Healthcare Research and Quality (AHRQ). HCUP databases bring together the data collection efforts of State data organizations, hospital associations, and private data organizations (HCUP Partners) and the Federal government to create a national information resource of encounter-level healthcare data. HCUP includes the largest collection of longitudinal hospital care data in the United States, with all-payer, encounter-level information beginning in 1988. These databases enable research on a broad range of health policy issues, including cost and quality of health services, medical practice patterns, access to healthcare programs, and outcomes of treatments at the national, State, and local market levels.

HCUP would not be possible without the contributions of the following data collection Partners from across the United States:

- Alaska Department of Health and Social Services
- Alaska State Hospital and Nursing Home Association
- Arizona Department of Health Services
- Arkansas Department of Health
- California Office of Statewide Health Planning and Development
- Colorado Hospital Association
- Connecticut Hospital Association
- Delaware Division of Public Health
- District of Columbia Hospital Association
- Florida Agency for Health Care Administration
- Georgia Hospital Association
- Hawaii Laulima Data Alliance
- Hawaii University of Hawai’i at Hilo
- Illinois Department of Public Health
- Indiana Hospital Association
- Iowa Hospital Association
- Kansas Hospital Association
- Kentucky Cabinet for Health and Family Services
- Louisiana Department of Health
- Maine Health Data Organization
- Maryland Health Services Cost Review Commission
- Massachusetts Center for Health Information and Analysis
- Michigan Health & Hospital Association
- Minnesota Hospital Association
- Mississippi State Department of Health
- Missouri Hospital Industry Data Institute
- Montana Hospital Association
- Nebraska Hospital Association
- Nevada Department of Health and Human Services
- New Hampshire Department of Health & Human Services
- New Jersey Department of Health
- New Mexico Department of Health
- New York State Department of Health
- North Carolina Department of Health and Human Services
- North Dakota (data provided by the Minnesota Hospital Association)
- Ohio Hospital Association
- Oklahoma State Department of Health
- Oregon Association of Hospitals and Health Systems
- Oregon Office of Health Analytics
- Pennsylvania Health Care Cost Containment Council
- Rhode Island Department of Health
- South Carolina Revenue and Fiscal Affairs Office
- South Dakota Association of Healthcare Organizations
- Tennessee Hospital Association
- Texas Department of State Health Services
- Utah Department of Health
- Vermont Association of Hospitals and Health Systems
- Virginia Health Information
- Washington State Department of Health
- West Virginia Department of Health and Human Resources, West Virginia Health Care Authority
- Wisconsin Department of Health Services
- Wyoming Hospital Association

## About the NIS

The HCUP National (Nationwide) Inpatient Sample (NIS) is a nationwide database of hospital inpatient stays. The NIS is nationally representative of all community hospitals (i.e., short-term, non-Federal, nonrehabilitation hospitals). The NIS includes all payers. It is drawn from a sampling frame that contains hospitals comprising more than 96 percent of all discharges in the United States. The vast size of the NIS allows the study of topics at the national and regional levels for specific subgroups of patients. In addition, NIS data are standardized across years to facilitate ease of use. Over time, the sampling frame for the NIS has changed; thus, the number of States contributing to the NIS varies from year to year. The NIS is intended for national estimates only; no State-level estimates can be produced. The unweighted sample size for the 2018 NIS is 7,105,498 (weighted, this represents 35,527,481 inpatient stays).

## For More Information

For other information on hospital inpatient procedures, refer to the HCUP Statistical Briefs located at www.hcup-us.ahrq.gov/reports/statbriefs/sb_procedures.jsp.

For additional HCUP statistics, visit:

- HCUP Fast Stats at www.hcup-us.ahrq.gov/faststats/landing.jsp for easy access to the latest HCUP-based statistics for healthcare information topics
- HCUPnet, HCUP’s interactive query system, at www.hcupnet.ahrq.gov/
- HCUP Summary Trend Tables at www.hcup-us.arhq.gov/reports/trendtables/summarytrendtables.jsp for monthly information on hospital utilization

For more information about HCUP, visit www.hcup-us.ahrq.gov/.

For a detailed description of HCUP and more information on the design of the National Inpatient Sample (NIS), please refer to the following database documentation:

Agency for Healthcare Research and Quality. Overview of the National (Nationwide) Inpatient Sample (NIS). Healthcare Cost and Utilization Project (HCUP). Rockville, MD: Agency for Healthcare Research and Quality. Updated December 2020. www.hcup-us.ahrq.gov/nisoverview.jsp. Accessed January 22, 2021.

## Acknowledgments

The authors would like to acknowledge the contributions of Nils Nordstrand of IBM Watson Health.

a This Statistical Brief represents an update to HCUP Statistical Brief #233, Overview of Operating Room Procedures During Inpatient Stays in U.S. Hospitals, 2014. However, Statistical Brief #233 applied earlier versions of HCUP software designed for use with International Classification of Diseases, Ninth Revision, Clinical Modification (ICD-9-CM) procedure codes (i.e., HCUP Clinical Classifications Software [CCS] for ICD-9-CM and HCUP Procedure Classes for ICD-9-CM). The present Statistical Brief applies updated tools for International Classification of Diseases, Tenth Revision, Procedure Coding System (ICD-10-PCS) codes, which in many cases use distinct terminology and clinical concepts to classify procedures. Because of these distinctions, direct comparisons of the estimates provided in the two reports are not recommended.

b Claritas. Claritas Demographic Profile by ZIP Code. https://claritas360.claritas.com/mybestsegments/. Accessed January 22, 2021.

c Agency for Healthcare Research and Quality. HCUP Clinical Classifications Software Refined (CCSR) for ICD-10-PCS Procedures. Healthcare Cost and Utilization Project (HCUP). Agency for Healthcare Research and Quality. Updated November 2020. www.hcup-us.ahrq.gov/toolssoftware/ccsr/prccsr.jsp. Accessed June 14, 2021.

d Procedure Classes Refined for ICD-10-PCS. Healthcare Cost and Utilization Project (HCUP). U.S. Agency for Healthcare Research and Quality. Rockville, MD. Updated March 2021. www.hcup-us.ahrq.gov/toolssoftware/procedureicd10/procedure_icd10.jsp Accessed June 28, 2021.

e Claritas. Claritas Demographic Profile by ZIP Code. https://claritas360.claritas.com/mybestsegments/. Accessed January 22, 2021.

f Agency for Healthcare Research and Quality. HCUP Cost-to-Charge Ratio (CCR) Files. Healthcare Cost and Utilization Project (HCUP). 2001–2017. Agency for Healthcare Research and Quality. Updated September 2020. www.hcup-us.ahrq.gov/db/state/costtocharge.jsp. Accessed January 22, 2021.

g For additional information about the NHEA, see Centers for Medicare & Medicaid Services (CMS). National Health Expenditure Data. CMS website. Updated December 17, 2019. www.cms.gov/Research-Statistics-Data-and-Systems/Statistics-Trends-and-Reports/NationalHealthExpendData/index.html?redirect=/NationalHealthExpendData/. Accessed January 22, 2021.

h American Hospital Association. TrendWatch Chartbook, 2020. Table 4.2. Distribution of Inpatient vs. Outpatient Revenues, 1995–2018. www.aha.org/system/files/media/file/2020/10/TrendwatchChartbook-2020-Appendix.pdf. Accessed January 22, 2021.

i Claritas. Claritas Demographic Profile by ZIP Code. https://claritas360.claritas.com/mybestsegments/. Accessed January 22, 2021.