# Statistical Brief #260 Social Determinants of Health and County Population Rates of Opioid-Related Inpatient Stays and Emergency Department Visits, 2016

## Introduction

Increased use of prescription and nonprescription opioids in the past 20 years has led to substantial increases in opioid-related deaths and hospitalizations. During this time, the number of opioid-related overdose deaths has increased nearly sixfold, from 8,048 in 1999 to 46,802 in 2018.^1^ Between 2005 and 2017, the rate of opioid-related emergency department (ED) visits nearly tripled from 89.1 to 249.1 per 100,000 population and the rate of opioid-related inpatient stays (IP) more than doubled from 136.8 to 299.7 per 100,000 population.^2^ In 2017, the U.S. Department of Health and Human Services declared the opioid crisis to be a public health emergency.^3^

To better understand how and where to target interventions for the opioid crisis, policymakers need to assess the impact of social determinants of health (SDOH) at the community level. SDOH comprise the conditions in which people live that may affect their health.^4^

From a community context, SDOH can be classified into three key areas:^5^

- Social, educational, and economic characteristics—such as demographics, education, income, employment, social factors, and safety
- Physical infrastructure—such as population density, urban-rural location, housing, and access to healthy food
- Healthcare characteristics—such as availability and access to quality healthcare, health behaviors, health promotion initiatives, attitudes toward healthcare in the community, and healthcare laws

This Healthcare Cost and Utilization Project (HCUP) Statistical Brief presents characteristics of U.S. counties based on population rates of opioid-related inpatient stays and treat-and-release ED visits for patients aged 15 years and older using comprehensive information from the 2016 State Inpatient Databases (SID) and State Emergency Department Databases (SEDD) from 35 States and the District of Columbia. County was defined based on patient ZIP Code of residence.

Each county’s population rate of opioid-related hospital utilization was compared with the national average: 369.7 inpatient stays per 100,000 population (95% confidence interval [CI]: 357.2, 382.2) and 304.9 ED visits per 100,000 population (95% CI: 278.7, 331.1). Based on whether the county population rates were statistically significantly higher than, lower than, or similar to (i.e., not statistically significantly different from) the national average, counties were categorized into five opioid-related hospital utilization groups: High IP & ED, High IP & Low ED, Low IP & High ED, Low IP & ED, and similar to the average. Additional details are provided under “County groups” in the Definitions section.

Table 1 summarizes the county groups in this analysis, including the region and population estimates. HCUP IP and ED data were available for 2,214 (70.5 percent) of the 3,142 counties in the United States in 2016. Of the 2,214 counties, 8.7 percent had higher-than-average population rates of opioid-related inpatient stays and treat-and-release ED visits (High IP & ED) and nearly half (48.4 percent) had lower-than-average population rates of opioid-related inpatient stays and ED visits (Low IP & ED).

Table 1 Population and region of counties with high and low population rates of opioid-related inpatient stays and treat-and-release ED visits across 35 States and the District of Columbia, 2016

Characteristic | All counties | County group based on population rates of opioid-related IP stays & ED visits
Characteristic | All counties | High IP & ED | High IP & Low ED | Low IP & High ED | Low IP & ED | Similar to average
Counties included in analysis (row percentages)
Number of counties | 2,214 | 193 | 27 | 50 | 1,071 | 873
Counties, % | 100.0 | 8.7 | 1.2 | 2.3 | 48.4 | 39.4
Total population aged 15+ years, no.^a^ | 200,348,800 | 43,568,600 | 6,318,700 | 5,092,000 | 90,676,300 | 54,693,200
Population aged 15+ years, % | 100.0 | 21.7 | 3.2 | 2.5 | 45.3 | 27.3
Counties included in analysis, by region, % (column percentages)
Northeast | 6.3 | 23.8 | 0.0 | 14.0 | 1.6 | 8.0
Midwest | 43.9 | 29.5 | 11.1 | 42.0 | 47.2 | 44.1
South | 39.0 | 36.3 | 74.1 | 30.0 | 43.0 | 34.1
West | 10.7 | 10.4 | 14.8 | 14.0 | 8.1 | 13.7

Abbreviations: ED, emergency department; IP, inpatient

a Population counts are rounded to the nearest hundred.

Sources: Agency for Healthcare Research and Quality (AHRQ), Healthcare Cost and Utilization Project (HCUP), State Inpatient Databases (SID) and State Emergency Department Databases (SEDD) for 35 States and the District of Columbia, 2016; U.S. Census Bureau American Community Survey for U.S. county and population data, 2016

The purpose of this Statistical Brief is to describe how counties that have high versus low population rates of opioid-related hospital use differ with regard to SDOH. Thus, differences are presented only for counties with high population rates of opioid-related inpatient stays and ED visits (High IP & ED) compared with counties with low population rates of opioid-related inpatient stays and ED visits (Low IP & ED) for the three community SDOH areas: social, educational, and economic characteristics; physical infrastructure; and healthcare characteristics. The High IP & ED and Low IP & ED groups (shaded columns in Table 1) are the only groups further addressed in this Statistical Brief. As noted in the tables, data values presented for each SDOH characteristic represent either the average value across counties or the percentage of counties with the characteristic. All differences between estimates noted in the text are statistically significant at the .05 level or better.

## Findings

Highlights

■ Among 2,214 counties (70.5 percent of all U.S. counties in 2016), 8.7 percent had population rates of opioid-related inpatient stays and emergency department (ED) visits that were high and 48.4 percent had rates that were low relative to the national average.
■ Counties with high population rates of opioid-related inpatient stays and ED visits had the following social determinants of health (SDOH) characteristics:
  ▪ Social, educational, and economic: lower population percentage of Hispanics/Latinos, higher percentage of economically disadvantaged residents, lower percentage of the population with religious congregation affiliation, and higher crime rates
  ▪ Physical infrastructure: more likely to be urban, more densely populated, and more racially segregated
  ▪ Healthcare: higher population rate of healthcare providers, greater pharmacy density, higher population percentage of Medicaid enrollment, more likely to have opioid-related State policies (e.g., permitting naloxone prescriptions for third parties), higher opioid prescribing rates, and higher State opioid mortality rates

### Social, educational, and economic characteristics of counties with high and low population rates of opioid-related inpatient stays and ED visits across 35 States and the District of Columbia, 2016

Table 2 presents the social, educational, and economic characteristics of counties with high and low population rates of opioid-related inpatient stays and treat-and-release ED visits in 2016.

Table 2 Social, educational, and economic characteristics of counties with high and low population rates of opioid-related inpatient stays and treat-and-release ED visits across 35 States and the District of Columbia, 2016

Characteristic | County group based on population rates of opioid-related inpatient stays and ED visits
Characteristic | High IP & ED; (N=193) | Low IP & ED; (N=1,071)
Demographics
Age, years, % of population aged 15+ years
15–17 | 4.7 | 5.0
18–44 | 40.7 | 40.4
45–64 | 34.1 | 33.2
65+ | 20.5 | 21.4
Female, % of population | 50.7 | 49.8
Race, % of population
White | 84.8 | 84.5
Black | 7.4 | 8.3
American Indian, Alaska Native | 1.5 | 1.4
Asian, Pacific Islander | 1.8 | 1.5
Other, 2+ races | 4.5 | 4.3
Ethnicity: Hispanic, Latino, % of population | 6.6 | 11.7
Education
Associate’s degree or higher in population aged 25+ years, % of population | 32.0 | 29.9
Poverty/income
County population in poverty, % of population | 16.8 | 15.6
Occupied units with housing costs at 30+% of household income, % of occupied units | 30.6 | 24.0
Employment
Unemployment rate, aged 16+ years | 5.4 | 4.8
Social factors
Children living in single parent households, % of children | 35.6 | 30.9
Affiliated with a religious congregation, % of population | 44.8 | 56.2
Community safety
Property crime rate per 1,000 population | 23.5 | 16.5
Violent crime rate per 1,000 population | 2.8 | 2.1

Abbreviations: ED, emergency department; IP, inpatient

Note: Data values are presented as the average value across the counties in the High IP & ED or Low IP & ED group.

Source: Agency for Healthcare Research and Quality (AHRQ), Healthcare Cost and Utilization Project (HCUP), 2016 State Inpatient Databases (SID) and State Emergency Department Databases (SEDD) from 35 States and the District of Columbia; supplemental data sources (see Appendix A.1)

■ Counties with high population rates of both opioid-related inpatient stays and ED visits had a smaller percentage of Hispanics/Latinos in the population than did counties with low rates.
  The percentage of Hispanics/Latinos was, on average, 6.6 percent in counties with high population rates of opioid-related inpatient stays and ED visits compared with 11.7 percent in counties with low opioid-related inpatient and ED rates.
■ Counties with high population rates of both opioid-related inpatient stays and ED visits were more likely to have an economically disadvantaged population than were counties with low rates.
  The poverty rate in counties with high population rates of opioid-related inpatient stays and ED visits averaged 16.8 percent compared with 15.6 percent in counties with low opioid-related inpatient and ED rates.
  The percentage of occupied units in the county with housing costs equal to or greater than 30 percent of household income averaged 30.6 percent in counties with high population rates of opioid-related inpatient stays and ED visits versus 24.0 percent in counties with low opioid-related inpatient and ED rates.
  Counties with high population rates of opioid-related inpatient stays and ED visits had a higher average unemployment rate than did counties with low opioid-related inpatient and ED rates (5.4 vs. 4.8 percent).
■ Social factors, specifically single-parent households and religious affiliation, were associated with population rates of opioid-related inpatient stays and ED visits.
  Counties with high population rates of opioid-related inpatient stays and ED visits had a higher average percentage of children living in single-parent households than did counties with low opioid-related inpatient and ED rates (35.6 vs. 30.9 percent).
  In counties with high population rates of opioid-related inpatient stays and ED visits, the percentage of the population with an affiliation to a religious congregation was 44.8 percent, on average, compared with 56.2 percent in counties with low opioid-related inpatient and ED rates.
■ Counties with high population rates of opioid-related inpatient stays and ED visits had higher crime rates than did counties with low rates.
  Compared with counties with low population rates of opioid-related inpatient stays and ED visits, counties with high opioid-related inpatient and ED rates had, on average, a 42 percent higher rate of property crime (23.5 vs. 16.5 per 1,000 population) and a 33 percent higher rate of violent crime (2.8 vs. 2.1 per 1,000 population).

### Physical infrastructure of counties with high and low population rates of opioid-related inpatient stays and ED visits across 35 States and the District of Columbia, 2016

Table 3 presents the physical infrastructure characteristics of counties with high and low opioid-related population rates of inpatient stays and treat-and-release ED visits in 2016.

Table 3 Physical infrastructure of counties with high and low population rates of opioid-related inpatient stays and treat-and-release ED visits across 35 States and the District of Columbia, 2016

Characteristic | County group based on population rates of opioid-related inpatient stays and ED visits
Characteristic | High IP & ED; (N=193) | Low IP & ED; (N=1,071)
Population
Population density per square mile | 789.1 | 152.8
Urban/rural designation, % of counties
Metro | 65.3 | 32.8
Rural-adjacent to metro | 24.4 | 31.3
Rural-remote | 10.4 | 35.9
Residential segregation index, % of counties
Low segregation (index value 0.6–23.9) | 11.9 | 23.3
Moderate segregation (index value 24.0–40.4) | 38.9 | 44.9
High segregation (index value 40.5–89.1) | 48.7 | 17.6
Segregation index not calculated^a^ | 0.5 | 14.1
Food access
Food environment index, 0 (worst) to 10 (best) | 7.1 | 7.0
Housing
Severe housing problems, % of households | 16.7 | 13.7

Abbreviations: ED, emergency department; IP, inpatient

Note: Unless otherwise noted, data values are presented as the average value across the counties in the High IP & ED or Low IP & ED group.

a No index value is calculated for counties with too little variation in the race of the population (i.e., fewer than 100 non-White people in the county in the time frame).

Source: Agency for Healthcare Research and Quality (AHRQ), Healthcare Cost and Utilization Project (HCUP), 2016 State Inpatient Databases (SID) and State Emergency Department Databases (SEDD) from 35 States and the District of Columbia; supplemental data sources (see Appendix A.1)

■ Counties with high population rates of opioid-related inpatient stays and ED visits were more densely populated, more likely to be urban, and more racially segregated than counties with low rates.
  Compared with counties with low population rates of opioid-related inpatient stays and ED visits, counties with high opioid-related inpatient and ED rates were more densely populated (an average of 789.1 vs. 152.8 people per square mile), more likely to be in metropolitan areas (65.3 vs. 32.8 percent of counties), and more racially segregated (48.7 vs. 17.6 percent of counties with high segregation).
  Counties with high population rates of opioid-related inpatient stays and ED visits also had a higher percentage of households with severe housing problems, on average, compared with counties with low opioid-related inpatient and ED rates (16.7 vs. 13.7 percent).

Figure 1 presents the distribution of counties with high and low population rates of opioid-related inpatient stays and treat-and-release ED visits in 2016 by urban-rural location (metro, rural-adjacent to a metro area, and rural-remote area) and poverty rate (high, low). Based on the national average, high poverty rate is defined as 15 percent or more of the population living in poverty.^6^

Figure 1 Urban-rural location and poverty level in counties with high and low population rates of opioid-related inpatient stays and treat-and-release ED visits across 35 States and the District of Columbia, 2016

Abbreviations: ED, emergency department; IP, inpatient

Note: Counties with a high poverty rate were defined as those with at least 15 percent of the population in poverty. As noted in Table 2, on average, 16.8 percent of the population in the High IP & ED counties and 15.6 percent of the population in the Low IP & ED counties lived in poverty. On average, 12.7 percent of the U.S. population lived in poverty in 2016.

Source: Agency for Healthcare Research and Quality (AHRQ), Healthcare Cost and Utilization Project (HCUP), 2016 State Inpatient Databases (SID) and State Emergency Department Databases (SEDD) from 35 States and the District of Columbia; supplemental data sources (see Appendix A.1)

Bar chart that shows the percentage of counties with high and low population rates of opioid-related inpatient stays and treat-and-release emergency department visits in metro, rural-adjacent, and rural-remote areas by poverty level in 2016. Data are provided in Supplemental Table 1.

Supplemental Table 1 Urban-rural location and poverty level in counties with high and low population rates of opioid-related inpatient stays and treat-and-release ED visits across 35 States and the District of Columbia, 2016, for data presented in Figure 1

Location | <15% of the population in poverty | High poverty rate: ≥15% of the population in poverty
Metro
High IP and ED (N=126) | 50.0 | 50.0
Low IP and ED (N=351) | 60.1 | 39.9
Rural-adjacent
High IP and ED (N=47) | 17.0 | 83.0
Low IP and ED (N=335) | 43.9 | 56.1
Rural-remote
High IP and ED (N=20) | 5.0 | 95.0
Low IP and ED (N=385) | 53.9 | 46.1

Abbreviations: ED, emergency department; IP, inpatient.

■ Rural-remote and rural-adjacent counties with high population rates of opioid-related inpatient stays and ED visits were more likely to have a high poverty rate than were counties with low rates.
  Nearly all rural-remote counties (95.0 percent) and 83.0 percent of rural-adjacent counties with high population rates of opioid-related inpatient stays and ED visits had high rates of poverty (greater than or equal to 15 percent) compared with less than 60 percent of rural-remote and rural-adjacent counties with low opioid-related inpatient and ED rates.

### Characteristics of healthcare in counties with high and low population rates of opioid-related inpatient stays and ED visits across 35 States and the District of Columbia, 2016

Table 4 describes the availability of and access to healthcare in counties with high and low population rates of opioid-related inpatient stays and treat-and-release ED visits in 2016.

Table 4 Availability of and access to healthcare in counties with high and low population rates of opioid-related inpatient stays and treat-and-release ED visits across 35 States and the District of Columbia, 2016

Characteristic | County group based on population rates of opioid-related IP stays & ED visits
Characteristic | High IP & ED; (N=193) | Low IP & ED; (N=1,071)
Availability of services
Total beds per 100,000 population | 231.5 | 222.5
Federally Qualified Health Centers, no. | 7.1 | 2.0
Primary care physicians per 100,000 population | 57.5 | 42.9
Psychiatrists per 100,000 population | 8.2 | 3.3
Psychiatric beds per 100,000 population | 13.3 | 7.5
Buprenorphine providers per 100,000 population^a^ | 11.8 | 2.9
Pharmacy density per 100 square miles | 15.0 | 2.4
Access to care: insurance, % of population
Medicare enrollment | 19.8 | 19.5
Medicaid enrollment | 22.2 | 18.2
Private insurance coverage | 64.6 | 66.3
Uninsured | 10.1 | 12.3

Abbreviations: ED, emergency department; IP, inpatient

Note: Data values are presented as the average value across the counties in the High IP & ED or Low IP & ED group.

a Buprenorphine is an opioid used to treat opioid use disorder, acute pain, and chronic pain.

Source: Agency for Healthcare Research and Quality (AHRQ), Healthcare Cost and Utilization Project (HCUP), 2016 State Inpatient Databases (SID) and State Emergency Department Databases (SEDD) from 35 States and the District of Columbia; supplemental data sources (see Appendix A.1)

■ Counties with high population rates of opioid-related inpatient stays and ED visits had greater availability of health service providers than did counties with low rates.
  Compared with counties with low population rates of opioid-related inpatient stays and ED visits, counties with high opioid-related inpatient and ED rates had more Federally Qualified Health Centers (mean of 7.1 vs. 2.0), primary care physicians (57.5 vs. 42.9 per 100,000 population), psychiatrists (8.2 vs. 3.3 per 100,000 population), psychiatric beds (13.3 vs. 7.5 per 100,000 population), and buprenorphine providers (11.8 vs. 2.9 per 100,000 population).
  Counties with high population rates of opioid-related inpatient stays and ED visits also had a greater average density of pharmacies than did counties with low opioid-related inpatient and ED rates (15.0 vs. 2.4 per 100 square miles).
■ Counties with high population rates of opioid-related inpatient stays and ED visits had a higher percentage of Medicaid enrollees than did counties with low rates.
  Counties with high population rates of opioid-related inpatient stays and ED visits had an average of 22.2 percent of the population enrolled in Medicaid, whereas counties with low population rates of opioid-related inpatient stays and ED visits had an average of 18.2 percent of the population enrolled in Medicaid.

Table 5 presents State-level opioid-related activities and healthcare policies, county-level opioid prescribing rates, and State-level opioid mortality rates in counties with high and low population rates of opioid-related inpatient stays and treat-and-release ED visits in 2016.

Table 5 Opioid-related activities, policies, prescribing rate, and mortality in counties with high and low population rates of opioid-related inpatient stays and treat-and-release ED visits across 35 States and the District of Columbia, 2016

Characteristic | County group based on population rates of opioid-related IP stays & ED visits
Characteristic | High IP & ED; (N=193) | Low IP & ED; (N=1,071)
State-level opioid-related activity and healthcare policies
Law enforcement seizures of fentanyl, no. | 1,852.2 | 336.3
Naloxone prescriptions permitted for third parties, % of counties^a^ | 92.2 | 82.7
Prescription drug monitoring program (PDMP) permitted to share data with other PDMPs, % of counties | 86.0 | 79.6
Prescribers required to check PDMP before prescribing controlled substances, % of counties | 58.5 | 10.6
Medicaid expansion State, % of counties | 73.1 | 39.4
County-level opioid prescribing rate
Opioid prescribing rate per 100 residents per year | 89.8 | 61.6
State-level opioid mortality rate
Opioid mortality rate per 100,000 population | 19.8 | 8.9

Abbreviations: ED, emergency department; IP, inpatient

Note: Unless otherwise noted, data values are presented as the average value across the counties in the High IP & ED or Low IP & ED group.

a Naloxone is an opioid antagonist and is designed to rapidly reverse the effects of an opioid overdose.

Source: Agency for Healthcare Research and Quality (AHRQ), Healthcare Cost and Utilization Project (HCUP), 2016 State Inpatient Databases (SID) and State Emergency Department Databases (SEDD) from 35 States and the District of Columbia; supplemental data sources (see Appendix A.1)

■ Counties with high population rates of opioid-related inpatient stays and ED visits were more likely to be located in States with opioid-related healthcare policies than were counties with low rates.
  Compared with counties with low population rates of opioid-related inpatient stays and ED visits, counties with high opioid-related inpatient and ED rates were more likely to be in States that permitted naloxone prescriptions for third parties (92.2 vs. 82.7 percent), permitted prescription drug monitoring programs (PDMPs) to share data with other PDMPs (86.0 vs. 79.6 percent), required prescribers to check the PDMP before prescribing controlled substances (58.5 vs. 10.6 percent), and had more law enforcement seizures of fentanyl, a synthetic opioid pain reliever (mean of 1,852.2 vs. 336.3).
  Counties with high population rates of opioid-related inpatient stays and ED visits were more likely to be in a Medicaid expansion State than were counties with low opioid-related inpatient and ED rates (73.1 vs. 39.4 percent).
■ Counties with high population rates of opioid-related inpatient stays and ED visits had higher opioid prescribing and opioid mortality rates than did counties with low rates.
  Compared with counties with low population rates of opioid-related inpatient stays and ED visits, counties with high opioid-related inpatient and ED rates had an average opioid prescribing rate that was nearly 50 percent higher (89.8 vs. 61.1 per 100 residents) and an average mortality rate that was more than twice as high (19.8 vs. 8.9 per 100,000 population).

## About Statistical Briefs

Healthcare Cost and Utilization Project (HCUP) Statistical Briefs provide basic descriptive statistics on a variety of topics using HCUP administrative healthcare data. Topics include hospital inpatient, ambulatory surgery, and emergency department use and costs, quality of care, access to care, medical conditions, procedures, and patient populations, among other topics. The reports are intended to generate hypotheses that can be further explored in other research; the reports are not designed to answer in-depth research questions using multivariate methods.

## Data Source

The estimates in this Statistical Brief are based upon data from the HCUP 2016 State Inpatient Databases (SID) and State Emergency Department Databases (SEDD) from 35 States and the District of Columbia: Arkansas, Arizona, California, Connecticut, District of Columbia, Florida, Hawaii, Illinois, Indiana, Iowa, Kansas, Kentucky, Maine, Maryland, Massachusetts, Minnesota, Mississippi, Missouri, Montana, North Carolina, North Dakota, Nebraska, Nevada, New Jersey, New York, Ohio, Oregon, Rhode Island, South Carolina, South Dakota, Tennessee, Texas, Utah, Vermont, Wisconsin, and Wyoming.

Supplemental data sources used for the county characteristics, including detailed descriptions of each county characteristic and data source websites, are presented in Appendix A.1, available as a separate, supplemental file associated with this Statistical Brief on the HCUP-US website at www.hcup-us.ahrq.gov/reports/statbriefs/sb260-appendix.pdf. Whenever possible, data from 2016 was used. In some cases, only data from an earlier or later time period were available.

## Definitions

### Diagnoses and ICD-10-CM

The principal diagnosis is that condition established after study to be chiefly responsible for the patient’s admission to the hospital. Secondary diagnoses are concomitant conditions that coexist at the time of admission or develop during the stay. All-listed diagnoses include the principal diagnosis plus these additional secondary conditions.

ICD-10-CM is the International Classification of Diseases, Tenth Revision, Clinical Modification. In October 2015, ICD-10-CM replaced the ICD-9-CM diagnosis with the ICD-10-CM diagnosis coding system for most inpatient and outpatient medical encounters. There are over 70,000 ICD-10-CM diagnosis codes.

### Case definition

The following ICD-10-CM diagnosis codes were used to define opioid-related inpatient stays and ED visits:

- F11 series: opioid-related disorders
  ○ All codes are included except remission code F11.21 (opioid dependence in remission).
- T40 series: poisoning by, adverse effect of, and underdosing of narcotics.
  ○ The following codes are included—encompassing accidental (unintentional) poisoning, intentional self-harm, assault, undetermined, and adverse effect (except heroin)—with the following characteristics in the 4th through 6th digits and a 7th digit indicating initial or subsequent encounter:
    ▪ 0X1, 0X2, 0X3, 0X4, 0X5: Opium
    ▪ 1X1, 1X2, 1X3, 1X4: Heroin
    ▪ 2X1, 2X2, 2X3, 2X4, 2X5: Other opioids
    ▪ 3X1, 3X2, 3X3, 3X4, 3X5: Methadone
    ▪ 4X1, 4X2, 4X3, 4X4, 4X5: Other synthetic narcotics
    ▪ 601, 602, 603, 604, 605: Unspecified narcotics
    ▪ 691, 692, 693, 694, 695: Other narcotics
  ○ Codes with a 6th digit of “6”, indicating underdosing, or a 7th digit of “S”, indicating sequela, are excluded.

The opioid diagnosis could be either a principal or secondary diagnosis. A full list of the individual ICD-10-CM codes used in the definition of opioid-related inpatient stays and ED visits is provided in Appendix A.2, available as a separate, supplemental file associated with this Statistical Brief on the HCUP-US website at www.hcup-us.ahrq.gov/reports/statbriefs/sb260-appendix.pdf.

### County assignment

Patient county was assigned based on the ZIP Code of the patient’s residence using the SAS function for ZIP Code to county assignment. For ZIP Codes that cross county boundaries, the SAS function used the geographic centroid of the ZIP Code to assign the county.^7^ If the patient’s ZIP Code indicated that the patient was homeless (HCUP data element ZIP = “H”), then the patient county was assigned to be the same as the hospital county. Records for patients with a ZIP Code that was missing, invalid, or indicated that the person was from a foreign country were excluded from the tabulated counts. This exclusion dropped less than 1 percent of records.

### County groups

Counties were classified into five opioid-related hospital utilization population rate groups based on comparison of the 95 percent confidence interval around each county’s population rate of opioid-related inpatient stays and emergency department (ED) visits compared with the 95 percent confidence interval around the national average rate (inpatient: 369.7 per 100,000 population; ED: 304.9 per 100,000 population), (see Table 6). Statistical significance was conservatively defined as nonoverlapping 95 percent confidence intervals. The focus of this Statistical Brief was the comparisons of counties described by the bolded text (High IP & ED and Low IP & ED groups).

- High IP & ED: counties with population rates of opioid-related hospital utilization that were statistically significantly above the national average for both IP stays and ED visits (N=193)
- High IP & Low ED: counties with population rates of opioid-related hospital utilization that were statistically significantly above the national average for IP stays and statistically significantly below the national average for ED visits (N=27)
- Low IP & High ED: counties with population rates of opioid-related hospital utilization that were statistically significantly below the national average for IP stays and statistically significantly above the national average for ED visits (N=50)
- Low IP & ED: counties with population rates of opioid-related hospital utilization that were statistically significantly below the national average for both IP stays and ED visits (N=1,071)
- Similar to average: counties with opioid-related hospital utilization rates that were not statistically significantly different from the national average for IP stays and/or ED visits (N=873)

Table 6 Distribution of counties based on population rates of opioid-related inpatient stays and treat-and-release ED visits compared with the national average across 35 States and the District of Columbia, 2016

Number of counties based on comparison of opioid-related inpatient stay population rate to national average | Number of counties based on comparison of opioid-related ED visit population rate to national average
Number of counties based on comparison of opioid-related inpatient stay population rate to national average | Above U.S. average | Similar to U.S. average | Below U.S. average | Total
Above U.S. average | 193^a^ | 80^e^ | 27^b^ | 300
Similar to U.S. average | 102^e^ | 209^e^ | 173^e^ | 484
Below U.S. average | 50^c^ | 309^e^ | 1,071^d^ | 1,430
Total | 345 | 598 | 1,271 | 2,214

Abbreviations: ED, emergency department; IP, inpatient

Note: Classification was based on comparison of county-level population rates to the U.S. average rate. Counties with population rates that were statistically significantly above the U.S. average rate were classified as “above U.S. average.” Counties with population rates that were statistically significantly below the U.S. average rate were classified as “below U.S. average.” Counties that were not statistically significantly different from the national average were classified as “similar to U.S. average.”

a These counties were classified as having high population rates of opioid-related inpatient stays and ED visits (High IP & ED county group).

b These counties were classified as having high population rates of opioid-related inpatient stays and low population rates of opioid-related ED visits (High IP & Low ED county group).

c These counties were classified as having low population rates of opioid-related inpatient stays and high population rates of opioid-related ED visits (Low IP & High ED county group).

d These counties were classified as having low population rates of opioid-related inpatient stays and ED visits (Low IP & ED county group).

e These counties were classified as having population rates of opioid-related inpatient stays and/or ED visits that were similar to the U.S. national average population rates (similar to average county group).

Source: Agency for Healthcare Research and Quality (AHRQ), Healthcare Cost and Utilization Project (HCUP), State Inpatient Databases (SID) and State Emergency Department Databases (SEDD) for 35 States and the District of Columbia, 2016

Figure 2 provides the county-level mean and range of the population rates of opioid-related inpatient stays and ED visits in the four county groups classified as having high and/or low opioid-related hospitalization. Counties with extreme outliers were not removed from this analysis in order to include all counties; however, it is important to note that the high-end outliers may increase the overall mean.

Figure 2 County-level mean and range of the population rates of opioid-related inpatient stays and treat-and-release ED visits among counties with high and low population rates of opioid-related hospital utilization across 35 States and the District of Columbia, 2016

Abbreviations: ED, emergency department; IP, inpatient

Source: Agency for Healthcare Research and Quality (AHRQ), Healthcare Cost and Utilization Project (HCUP), 2016 State Inpatient Databases (SID) and State Emergency Department Databases (SEDD) from 35 States and the District of Columbia

Line chart that shows the maximum, minimum, and mean of the population rate of opioid-related hospital utilization per 100,000 population aged 15+ years for inpatient stays and emergency department visits in counties with high and low population rates across 35 States and the District of Columbia in 2016. Data are provided in Supplemental Table 2.

Supplemental Table 2 County-level mean and range of the population rates of opioid-related inpatient stays and treat-and-release ED visits among counties with high and low population rates of opioid-related hospital utilization across 35 States and the District of Columbia, 2016, for data presented in Figure 2

Measure | High IP and ED | | High IP and low ED | | Low IP and high ED | | Low IP and ED
Measure | IP | ED | IP | ED | IP | ED | IP | ED
Max | 4122.0 | 2224.3 | 928.9 | 260.7 | 336.5 | 736.1 | 341.2 | 256.6
Mean | 656.8 | 634.0 | 528.9 | 195.1 | 264.0 | 469.5 | 153.0 | 115.7
Min | 403.6 | 360.3 | 409.4 | 130.3 | 179.1 | 354.1 | 0.0 | 0.0

Abbreviations: ED, emergency department; IP, inpatient.

### Types of hospitals included in HCUP State Inpatient Databases

This analysis used State Inpatient Databases (SID) limited to data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). Community hospitals include obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical center hospitals. Excluded for this analysis are long-term care facilities such as rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. However, if a patient received long-term care, rehabilitation, or treatment for a psychiatric or chemical dependency condition in a community hospital, the discharge record for that stay was included in the analysis.

### Types of hospitals included in HCUP State Emergency Department Databases

This analysis used State Emergency Department Databases (SEDD) limited to data from community hospitals with a hospital-owned emergency department. Community hospitals are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). Community hospitals include specialty, pediatric, public, and academic medical center hospitals. Excluded for this analysis are long-term care facilities such as rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals.

### Unit of analysis

The unit of analysis in this Statistical Brief is the county. The county groups, defined by population rates of opioid-related hospital utilization, are based on the hospital discharge (i.e., the hospital stay) or emergency department (ED) visit, not individual patients. A patient admitted to the hospital multiple times in 1 year will be counted each time as a separate discharge from the hospital, and a patient seen in the ED multiple times in 1 year will be counted each time as a separate ED visit.

### Region

Region is one of the four regions defined by the U.S. Census Bureau:

- Northeast: Maine, New Hampshire, Vermont, Massachusetts, Rhode Island, Connecticut, New York, New Jersey, and Pennsylvania
- Midwest: Ohio, Indiana, Illinois, Michigan, Wisconsin, Minnesota, Iowa, Missouri, North Dakota, South Dakota, Nebraska, and Kansas
- South: Delaware, Maryland, District of Columbia, Virginia, West Virginia, North Carolina, South Carolina, Georgia, Florida, Kentucky, Tennessee, Alabama, Mississippi, Arkansas, Louisiana, Oklahoma, and Texas
- West: Montana, Idaho, Wyoming, Colorado, New Mexico, Arizona, Utah, Nevada, Washington, Oregon, California, Alaska, and Hawaii

## About HCUP

The Healthcare Cost and Utilization Project (HCUP, pronounced “H-Cup”) is a family of healthcare databases and related software tools and products developed through a Federal-State-Industry partnership and sponsored by the Agency for Healthcare Research and Quality (AHRQ). HCUP databases bring together the data collection efforts of State data organizations, hospital associations, and private data organizations (HCUP Partners) and the Federal government to create a national information resource of encounter-level healthcare data. HCUP includes the largest collection of longitudinal hospital care data in the United States, with all-payer, encounter-level information beginning in 1988. These databases enable research on a broad range of health policy issues, including cost and quality of health services, medical practice patterns, access to healthcare programs, and outcomes of treatments at the national, State, and local market levels.

HCUP would not be possible without the contributions of the following data collection Partners from across the United States:

- Alaska Department of Health and Social Services
- Alaska State Hospital and Nursing Home Association
- Arizona Department of Health Services
- Arkansas Department of Health
- California Office of Statewide Health Planning and Development
- Colorado Hospital Association
- Connecticut Hospital Association
- Delaware Division of Public Health
- District of Columbia Hospital Association
- Florida Agency for Health Care Administration
- Georgia Hospital Association
- University of Hawaii, Hilo, Center for Rural Health Science
- Hawaii Laulima Data Alliance
- Illinois Department of Public Health
- Indiana Hospital Association
- Iowa Hospital Association
- Kansas Hospital Association
- Kentucky Cabinet for Health and Family Services
- Louisiana Department of Health
- Maine Health Data Organization
- Maryland Health Services Cost Review Commission
- Massachusetts Center for Health Information and Analysis
- Michigan Health & Hospital Association
- Minnesota Hospital Association
- Mississippi State Department of Health
- Missouri Hospital Industry Data Institute
- Montana Hospital Association
- Nebraska Hospital Association
- Nevada Department of Health and Human Services
- New Hampshire Department of Health & Human Services
- New Jersey Department of Health
- New Mexico Department of Health
- New York State Department of Health
- North Carolina Department of Health and Human Services
- North Dakota (data provided by the Minnesota Hospital Association)
- Ohio Hospital Association
- Oklahoma State Department of Health
- Oregon Association of Hospitals and Health Systems
- Oregon Office of Health Analytics
- Pennsylvania Health Care Cost Containment Council
- Rhode Island Department of Health
- South Carolina Revenue and Fiscal Affairs Office
- South Dakota Association of Healthcare Organizations
- Tennessee Hospital Association
- Texas Department of State Health Services
- Utah Department of Health
- Vermont Association of Hospitals and Health Systems
- Virginia Health Information
- Washington State Department of Health
- West Virginia Department of Health and Human Resources, West Virginia Health Care Authority
- Wisconsin Department of Health Services
- Wyoming Hospital Association

## About the SID

The HCUP State Inpatient Databases (SID) are hospital inpatient databases from data organizations participating in HCUP. The SID contain the universe of the inpatient discharge abstracts in the participating HCUP States, translated into a uniform format to facilitate multistate comparisons and analyses. Together, the SID encompass more than 95 percent of all U.S. community hospital discharges. The SID can be used to investigate questions unique to one State, to compare data from two or more States, to conduct market-area variation analyses, and to identify State-specific trends in inpatient care utilization, access, charges, and outcomes.

## About the SEDD

The HCUP State Emergency Department Databases (SEDD) include information from hospital-owned emergency departments (EDs) from data organizations participating in HCUP, translated into a uniform format to facilitate multistate comparisons and analyses. The SEDD capture the universe of records on ED visits in participating HCUP States that do not result in an admission to the same hospital (i.e., patients who are treated in the ED and then discharged, transferred to another hospital, left against medical advice, or died). The SEDD contain a core set of clinical and nonclinical information on all patients, including individuals covered by Medicare, Medicaid, or private insurance, as well as those whose stays were not expected to be covered by insurance. The SEDD can be used to investigate questions unique to one State, to compare data from two or more States, to conduct market-area variation analyses, and to identify State-specific trends in injury surveillance, emerging infections, and other conditions treated in the ED.

## For More Information

For other information on mental and substance use disorders, including opioids, refer to the HCUP Statistical Briefs located at www.hcup-us.ahrq.gov/reports/statbriefs/sb_mhsa.jsp.

For additional HCUP statistics, visit:

- HCUP Fast Stats at www.hcup-us.ahrq.gov/faststats/landing.jsp for easy access to the latest HCUP-based statistics for healthcare information topics
- HCUPnet, HCUP’s interactive query system, at www.hcupnet.ahrq.gov/

For more information about HCUP, visit www.hcup-us.ahrq.gov/.

For a detailed description of HCUP and more information on the design of the State Inpatient Databases (SID) and State Emergency Department Databases (SEDD), please refer to the following database documentation:

Agency for Healthcare Research and Quality. Overview of the State Inpatient Databases (SID). Healthcare Cost and Utilization Project (HCUP). Rockville, MD: Agency for Healthcare Research and Quality. Updated November 2019. www.hcup-us.ahrq.gov/sidoverview.jsp. Accessed February 3, 2020.

Agency for Healthcare Research and Quality. Overview of the State Emergency Department Databases (SEDD). Healthcare Cost and Utilization Project (HCUP). Rockville, MD: Agency for Healthcare Research and Quality. Updated January 2020. www.hcup-us.ahrq.gov/seddoverview.jsp. Accessed February 3, 2020.

## Acknowledgments

The authors would like to acknowledge the contributions of Kim McDermott and Minya Sheng of IBM Watson Health.

1 National Institute on Drug Abuse. Overdose Death Rates. Revised March 2020. www.drugabuse.gov/related-topics/trends-statistics/overdose-death-rates. Accessed May 15, 2020.

2 Healthcare Cost and Utilization Project. HCUP Fast Stats – Opioid-Related Hospital Use. www.hcup-us.ahrq.gov/faststats/OpioidUseServlet?setting1=IP. Accessed May 15, 2020.

3 U.S. Department of Health and Human Services. What Is the U.S. Opioid Epidemic? Updated September 4, 2019. www.hhs.gov/opioids/about-the-epidemic/index.html. Accessed October 14, 2019.

4 World Health Organization. About Social Determinants of Health. www.who.int/social_determinants/sdh_definition/en/. Accessed October 14, 2019.

5 Agency for Healthcare Research and Quality. Social Determinants of Health (SDOH). www.ahrq.gov/sdoh/index.html. Accessed February 25, 2020.

6 Percentage of the county population in poverty was obtained from the American Community Survey, U.S. Census Bureau, 2016. The national average poverty rate in 2016 was obtained from the U.S. Census Bureau Report #P60-259, Income and Poverty in the United States: 2016, published September 12, 2017. www.census.gov/library/publications/2017/demo/p60-259.html. Accessed May 5, 2020.

7 Additional information from SAS on the geocode procedure is available at SAS. Understanding ZIP Code Geocoding. support.sas.com/documentation/cdl/en/graphref/65389/HTML/default/viewer.htm#n1cqwrpowwd4l6n1lmw39ughjpuh.htm (https://urldefense.proofpoint.com/v2/url?u=http-3A__support.sas.com_documentation_cdl_en_graphref_65389_HTML_default_viewer.htm-23n1cqwrpowwd4l6n1lmw39ughjpuh.htm&d=DwMFaQ&c=jf_iaSHvJObTbx-siA1ZOg&r=2qQwVBn6hVQgR7RNjEA4Tc2Yt-lUl674IM-sBUsuioI&m=w2DmK_jDkhOc5tAeOKI4cGOxmCCyv609zS7SEIk3eaI&s=Zdi8Iw-z96dLAsyraRxsZo5PWpQnndNcOlwYuLSXNW0&e=). Accessed January 25, 2020.

## Appendix A.1 Supplemental data sources for county characteristics

Characteristic | Description | Data source | Website | Year
Social, educational, and economic characteristics
Demographics
Age distribution | Percentage of county population who were in the following age groups: 15–17 years, 18–44 years, 45–64 years, and 65+ years | American Community Survey, U.S. Census Bureau | data.census.gov | 2016
Sex distribution | Percentage of county population who were female | American Community Survey, U.S. Census Bureau | data.census.gov | 2016
Race distribution | Percentage of county population who were in the following racial groups: White; Black or African American; American Indian or Alaska Native; Asian; Native Hawaiian or Other Pacific Islander; Other, 2 or more races | American Community Survey, U.S. Census Bureau | data.census.gov | 2016
Ethnicity | Percentage of county population who were Hispanic/Latino | American Community Survey, U.S. Census Bureau | data.census.gov | 2016
Education
Associate’s degree or higher | Percentage of county population aged 25 years or older with an associate’s degree or higher | American Community Survey, U.S. Census Bureau | data.census.gov | 2016
Poverty/income
Poverty | Percentage of county population in poverty | American Community Survey, U.S. Census Bureau | data.census.gov | 2016
Housing costs | Percentage of occupied units in the county with housing costs equal to or greater than 30 percent of household income | American Community Survey, U.S. Census Bureau | data.census.gov | 2016
Employment
Unemployment rate | Percentage of county population aged 16 years or older who were unemployed | Local Area Unemployment Statistics, U.S. Department of Labor Bureau of Labor Statistics | www.bls.gov | 2016
Social factors
Single parent households | Percentage of children in family households in the county living in single parent households | American Community Survey, U.S. Census Bureau | data.census.gov | 2016
Religious affiliation | Percentage of the county population affiliated with a religious congregation | U.S. Religion Census, Association of Statisticians of American Religious Bodies | www.usreligioncensus.org | 2010
Community safety
Property crime | Property crimes reported per 1,000 county population for which crimes are reported | Uniform Crime Reporting Program Data, Inter-university Consortium for Political and Social Research | www.icpsr.umich.edu | 2014
Violent crime | Violent crimes reported per 1,000 county population for which crimes are reported | Uniform Crime Reporting Program Data, Inter-university Consortium for Political and Social Research | www.icpsr.umich.edu | 2014
Physical infrastructure
Population
Population density | Number of residents in the county per square mile of land | American Community Survey, U.S. Census Bureau | data.census.gov | 2016 (land area data from 2010)
Urban/rural designation | County designation as metropolitan (counties in metro areas regardless of population size); rural, adjacent to metropolitan (counties adjacent to metro areas, regardless of population size); or rural, remote (counties in areas not adjacent to metro areas regardless of population size) | Rural-Urban Continuum Codes, U.S. Department of Agriculture Economic Research Service | www.ers.usda.gov/data-products/rural-urban-continuum-codes/ | 2016
Residential segregation | Non-White/White residential segregation index value (low, moderate, high, or none) for the county. The index of dissimilarity is a demographic measure of the evenness with which non-White and White residents are distributed across census tracts that make up a county. The index score can be interpreted as the percentage of White or non-White population who would have to move to a different census tract to produce a distribution that matches that of the county. | County Health Rankings & Roadmaps, Robert Wood Johnson Foundation and the University of Wisconsin Population Health Institute | www.countyhealthrankings.org | 2010–2014
Food access
Food environment | Food Environment Index score for the county. The index ranges from 0 (worst) to 10 (best) and equally weights two indicators: limited access to healthy foods (i.e., the percentage of the population that is low income and does not live close to a grocery store) and food insecurity (i.e., the percentage of the population without access to a reliable source of food). | County Health Rankings & Roadmaps, Robert Wood Johnson Foundation and the University of Wisconsin Population Health Institute | www.countyhealthrankings.org | 2013
Housing
Severe housing problems | Percentage of households in the county living with overcrowding, high housing costs, lack of kitchen facilities, or lack of plumbing facilities | County Health Rankings & Roadmaps, Robert Wood Johnson Foundation and the University of Wisconsin Population Health Institute | www.countyhealthrankings.org | 2008–2012
Healthcare characteristics
Availability of services
Total hospital beds | Number of hospital beds per 100,000 county population^1^ | Annual Survey of Hospitals, American Hospital Association | www.ahadata.com/aha-annual-survey-database | 2016
Federally Qualified Health Centers (FQHCs) | Number of FQHCs in the county | Area Health Resources Files, Health Resources & Services Administration | data.hrsa.gov/topics/health-workforce/ahrf | 2016
Primary care physician availability | Number of primary care physicians per 100,000 county population^1^ | Area Health Resources Files, Health Resources and Services Administration | data.hrsa.gov/topics/health-workforce/ahrf | 2015
Psychiatrist availability | Number of psychiatrists per 100,000 county population^1^ | Area Health Resources Files, Health Resources and Services Administration | data.hrsa.gov/topics/health-workforce/ahrf | 2015
Psychiatric hospital beds | Number of psychiatric hospital beds per 100,000 county population^1^ | Annual Survey of Hospitals, American Hospital Association | www.ahadata.com/aha-annual-survey-database | 2016
Buprenorphine provider availability | Number of practitioners waived to provide buprenorphine for the treatment of opioid use disorder per 100,000 county population^1^ | Buprenorphine Treatment Practitioner Locator, Substance Abuse and Mental Health Services Administration | www.samhsa.gov/medication-assisted-treatment/physician-program-data/treatment-physician-locator | 2018
Pharmacy density | Number of pharmacies in the county per 100 square miles^2^ | County Business Patterns, U.S. Census Bureau | www.census.gov/programs-surveys/cbp.html | 2016
Access to care: insurance
Insurance enrollment | Percentage of county population enrolled in Medicare, Medicaid, or private insurance, or with no insurance | American Community Survey, U.S. Census Bureau | data.census.gov | 2016
State-level opioid-related activity and healthcare policies
Law enforcement seizures of fentanyl | Number of law enforcement illicit drug seizures in the state that were tested and confirmed to contain fentanyl | Opioid & Health Indicators Database, amfAR | opioid.amfar.org/indicator/fentanyl_seize | 2016
Naloxone prescription availability | State permitted naloxone prescriptions for third parties (i.e., people with whom the prescriber does not have a prescriber-patient relationship), either for a portion of the year or for the entire year | Naloxone Overdose Prevention Laws Dataset, Prescription Drug Abuse Policy System | pdaps.org | 2016
Prescription drug monitoring program (PDMP) data sharing | State permitted the PDMP to share data with other State PDMPs, either for a portion of the year or for the entire year | PDMP Reporting and Authorized Use Dataset, Prescription Drug Abuse Policy System | pdaps.org | 2016
Prescribers required to check PDMP | State required prescribers to check the PDMP before prescribing controlled substances, for the entire year | PDMP Reporting and Authorized Use Dataset, Prescription Drug Abuse Policy System | pdaps.org | 2016
Medicaid expansion | State had adopted Medicaid Expansion | State Health Facts: Status of State Action on the Medicaid Expansion, Kaiser Family Foundation | www.kff.org/health-reform/state-indicator/state-activity-around-expanding-medicaid-under-the-affordable-care-act/ | 2016
County-level opioid prescribing rate
Opioid prescribing | Opioid prescriptions per 100 county residents per year | U.S. Opioid Prescribing Rate Maps, Centers for Disease Control and Prevention | www.cdc.gov/drugoverdose/maps/rxcounty2016.html | 2016
State-level opioid mortality rate
Opioid mortality | Opioid-related deaths per 100,000 State population (age-adjusted) | State Health Facts: Opioid Overdose Death Rates and All Drug Overdose Death Rates, Kaiser Family Foundation (analysis of data from Centers for Disease Control and Prevention WONDER Online Database) | www.kff.org/other/state-indicator/opioid-overdose-death-rates | 2016

1 Characteristic was calculated “per 100,000 county population” using county population data from the U.S. Census Bureau American Community Survey, 2016, [underlined: data.census.gov].

2 Characteristic was calculated “per 100 square miles” using land area data from the U.S. Census Bureau American Community Survey, 2010, [underlined: data.census.gov].

## Appendix A.2 ICD-10-CM diagnosis codes defining opioid-related inpatient stays and emergency department visits

ICD-10-CM diagnosis code | Description
F11.10 | Opioid abuse, uncomplicated
F11.120 | Opioid abuse with intoxication, uncomplicated
F11.121 | Opioid abuse with intoxication, delirium
F11.122 | Opioid abuse with intoxication, with perceptual disturbance
F11.129 | Opioid abuse with intoxication, unspecified
F11.14 | Opioid abuse with opioid-induced mood disorder
F11.150 | Opioid abuse with opioid-induced psychotic disorder, with delusions
F11.151 | Opioid abuse with opioid-induced psychotic disorder, with hallucinations
F11.159 | Opioid abuse with opioid-induced psychotic disorder, unspecified
F11.181 | Opioid abuse with opioid-induced sexual dysfunction
F11.182 | Opioid abuse with opioid-induced sleep disorder
F11.188 | Opioid abuse with other opioid-induced disorder
F11.19 | Opioid abuse with unspecified opioid-induced disorder
F11.20 | Opioid dependence, uncomplicated
F11.220 | Opioid dependence with intoxication, uncomplicated
F11.221 | Opioid dependence with intoxication, delirium
F11.222 | Opioid dependence with intoxication, with perceptual disturbance
F11.229 | Opioid dependence with intoxication, unspecified
F11.23 | Opioid dependence with withdrawal
F11.24 | Opioid dependence with opioid-induced mood disorder
F11.250 | Opioid dependence with opioid-induced psychotic disorder, with delusions
F11.251 | Opioid dependence with opioid-induced psychotic disorder, with hallucinations
F11.259 | Opioid dependence with opioid-induced psychotic disorder, unspecified
F11.281 | Opioid dependence with opioid-induced sexual dysfunction
F11.282 | Opioid dependence with opioid-induced sleep disorder
F11.288 | Opioid dependence with other opioid-induced disorder
F11.29 | Opioid dependence with unspecified opioid-induced disorder
F11.90 | Opioid use, unspecified, uncomplicated
F11.920 | Opioid use, unspecified with intoxication, uncomplicated
F11.921 | Opioid use, unspecified with intoxication delirium
F11.922 | Opioid use, unspecified with intoxication, with perceptual disturbance
F11.929 | Opioid use, unspecified with intoxication, unspecified
F11.93 | Opioid use, unspecified, with withdrawal
F11.94 | Opioid use, unspecified, with opioid-induced mood disorder
F11.950 | Opioid use, unspecified with opioid-induced psychotic disorder, with delusions
F11.951 | Opioid use, unspecified with opioid-induced psychotic disorder, with hallucinations
F11.959 | Opioid use, unspecified with opioid-induced psychotic disorder, unspecified
F11.981 | Opioid use, unspecified with opioid-induced sexual dysfunction
F11.982 | Opioid use, unspecified with opioid-induced sleep disorder
F11.988 | Opioid use, unspecified with other opioid-induced disorder
F11.99 | Opioid use, unspecified, with unspecified opioid-induced disorder
T40.0X1A | Poisoning by opium, accidental (unintentional), initial encounter
T40.0X1D | Poisoning by opium, accidental (unintentional), subsequent encounter
T40.0X2A | Poisoning by opium, intentional self-harm, initial encounter
T40.0X2D | Poisoning by opium, intentional self-harm, subsequent encounter
T40.0X3A | Poisoning by opium, assault, initial encounter
T40.0X3D | Poisoning by opium, assault, subsequent encounter
T40.0X4A | Poisoning by opium, undetermined, initial encounter
T40.0X4D | Poisoning by opium, undetermined, subsequent encounter
T40.0X5A | Adverse effect of opium, initial encounter
T40.0X5D | Adverse effect of opium, subsequent encounter
T40.1X1A | Poisoning by heroin, accidental (unintentional), initial encounter
T40.1X1D | Poisoning by heroin, accidental (unintentional), subsequent encounter
T40.1X2A | Poisoning by heroin, intentional self-harm, initial encounter
T40.1X2D | Poisoning by heroin, intentional self-harm, subsequent encounter
T40.1X3A | Poisoning by heroin, assault, initial encounter
T40.1X3D | Poisoning by heroin, assault, subsequent encounter
T40.1X4A | Poisoning by heroin, undetermined, initial encounter
T40.1X4D | Poisoning by heroin, undetermined, subsequent encounter
T40.2X1A | Poisoning by other opioids, accidental (unintentional), initial encounter
T40.2X1D | Poisoning by other opioids, accidental (unintentional), subsequent encounter
T40.2X2A | Poisoning by other opioids, intentional self-harm, initial encounter
T40.2X2D | Poisoning by other opioids, intentional self-harm, subsequent encounter
T40.2X3A | Poisoning by other opioids, assault, initial encounter
T40.2X3D | Poisoning by other opioids, assault, subsequent encounter
T40.2X4A | Poisoning by other opioids, undetermined, initial encounter
T40.2X4D | Poisoning by other opioids, undetermined, subsequent encounter
T40.2X5A | Adverse effect of other opioids, initial encounter
T40.2X5D | Adverse effect of other opioids, subsequent encounter
T40.3X1A | Poisoning by methadone, accidental (unintentional), initial encounter
T40.3X1D | Poisoning by methadone, accidental (unintentional), subsequent encounter
T40.3X2A | Poisoning by methadone, intentional self-harm, initial encounter
T40.3X2D | Poisoning by methadone, intentional self-harm, subsequent encounter
T40.3X3A | Poisoning by methadone, assault, initial encounter
T40.3X3D | Poisoning by methadone, assault, subsequent encounter
T40.3X4A | Poisoning by methadone, undetermined, initial encounter
T40.3X4D | Poisoning by methadone, undetermined, subsequent encounter
T40.3X5A | Adverse effect of methadone, initial encounter
T40.3X5D | Adverse effect of methadone, subsequent encounter
T40.4X1A | Poisoning by other synthetic narcotics, accidental (unintentional), initial encounter
T40.4X1D | Poisoning by other synthetic narcotics, accidental (unintentional), subsequent encounter
T40.4X2A | Poisoning by other synthetic narcotics, intentional self-harm, initial encounter
T40.4X2D | Poisoning by other synthetic narcotics, intentional self-harm, subsequent encounter
T40.4X3A | Poisoning by other synthetic narcotics, assault, initial encounter
T40.4X3D | Poisoning by other synthetic narcotics, assault, subsequent encounter
T40.4X4A | Poisoning by other synthetic narcotics, undetermined, initial encounter
T40.4X4D | Poisoning by other synthetic narcotics, undetermined, subsequent encounter
T40.4X5A | Adverse effect of other synthetic narcotics, initial encounter
T40.4X5D | Adverse effect of other synthetic narcotics, subsequent encounter
T40.601A | Poisoning by unspecified narcotics, accidental (unintentional), initial encounter
T40.601D | Poisoning by unspecified narcotics, accidental (unintentional), subsequent encounter
T40.602A | Poisoning by unspecified narcotics, intentional self-harm, initial encounter
T40.602D | Poisoning by unspecified narcotics, intentional self-harm, subsequent encounter
T40.603A | Poisoning by unspecified narcotics, assault, initial encounter
T40.603D | Poisoning by unspecified narcotics, assault, subsequent encounter
T40.604A | Poisoning by unspecified narcotics, undetermined, initial encounter
T40.604D | Poisoning by unspecified narcotics, undetermined, subsequent encounter
T40.605A | Adverse effect of unspecified narcotics, initial encounter
T40.605D | Adverse effect of unspecified narcotics, subsequent encounter
T40.691A | Poisoning by other narcotics, accidental (unintentional), initial encounter
T40.691D | Poisoning by other narcotics, accidental (unintentional), subsequent encounter
T40.692A | Poisoning by other narcotics, intentional self-harm, initial encounter
T40.692D | Poisoning by other narcotics, intentional self-harm, subsequent encounter
T40.693A | Poisoning by other narcotics, assault, initial encounter
T40.693D | Poisoning by other narcotics, assault, subsequent encounter
T40.694A | Poisoning by other narcotics, undetermined, initial encounter
T40.694D | Poisoning by other narcotics, undetermined, subsequent encounter
T40.695A | Adverse effect of other narcotics, initial encounter
T40.695D | Adverse effect of other narcotics, subsequent encounter

Abbreviation: ICD-10-CM, International Classification of Diseases, Tenth Revision, Clinical Modification