# Statistical Brief #24 Hospitalizations for Birth Defects, 2004

## Introduction

Each year, birth defects (or congenital anomalies) affect one out of every 33 babies born in the United States.^1^ A birth defect occurs when the fetus is developing in the mother’s body, usually within the first three months of pregnancy. Birth defects are often found within the first year of life, and their effects can range from mild to severe. Some defects result in debilitating illness or death at a very young age, while others may be successfully treated with surgery or other medical treatments. Some birth defects may not be discovered or treated until adulthood. In any case, inpatient hospital care is often necessary for persons affected by birth defects.

This Statistical Brief provides data from the Healthcare Cost and Utilization Project (HCUP) on hospital care for birth defects in 2004. Hospital utilization and costs for the treatment of birth defects are compared with hospital stays for all other non-obstetrical conditions. Additionally, the most common birth defects resulting in hospital admission are described. Finally, changes in the hospitalization rate for birth defects between 1997 and 2004 are examined. All differences between estimates noted in the text are statistically significant at the 0.05 level or better.

## Findings

Highlights

- In 2004, birth defects accounted for more than 139,000 hospitalizations, representing 47.4 stays per 100,000 persons. Hospital costs for these conditions totaled $2.6 billion.
- The highest aggregate costs were for stays related to cardiac and circulatory congenital anomalies, which accounted for about $1.4 billion—more than half of all hospital costs for birth defects. Cardiac and circulatory congenital anomalies, which include conditions such as atrial and ventricular septal defects, accounted for more than one-third of all hospital stays for birth defects and had the highest in-hospital mortality rate.
- Between 1997 and 2004, hospitalization rates increased by 28.5 percent for cardiac and circulatory congenital anomalies and 25.3 percent for digestive congenital anomalies (when noted as either the principal or a coexisting condition).
- Pyloric stenosis was the most common principal reason for birth defect hospital stays, accounting for 9.0 percent of all birth defect-related hospitalizations.
- Atrial septal defect was noted during almost 86,300 hospitalizations as the principal reason for the hospital stay or as a coexisting, or secondary, condition.

In 2004, there were more than 139,000 hospital stays principally for the treatment of birth defects. This represented a hospitalization rate of 47.4 stays per 100,000 persons and totaled $2.6 billion in hospital costs.

### General characteristics of hospital stays for birth defects

Table 1 describes the general characteristics of hospitalizations for birth defects. In general, stays principally for the treatment of birth defects were longer, more costly, occurred more often among males and younger patients, and resulted in a lower in-hospital death rate when compared with hospital stays for all other non-obstetrical conditions.

Table 1 Hospitalizations for birth defects compared with hospitalizations for all other conditions, 2004^*^

| Hospital stays for birth defect^*^ | All other hospital stays^†^
Number of hospital stays (percentage of all hospital stays) | 139,100 (0.4%) | 33,759,500 (99.6%)
Mean length of stay, days | 6.3 | 4.9
Mean hospital cost | $18,600 | $8,200
Aggregate costs (percentage of total national cost) | $2.6 billion (0.9%) | $276.4 billion (99.1%)
Percent male | 53.3% | 46.5%
Mean age | 17.6 | 49.9
Percent died in hospital | 1.3% | 2.4%

* Based on principal diagnosis.

† Excludes stays for obstetrical conditions.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2004.

On average, birth defect hospitalizations were about 1.5 days longer than stays for all other conditions (6.3 days versus 4.9 days), while a birth defect admission was on average more than twice as costly ($18,600 versus $8,200). Compared with stays for all other non-obstetrical conditions, patients hospitalized principally for the treatment of birth defects were disproportionately male (53.3 percent versus 46.5 percent) and had a mean age that was more than 30 years younger (17.6 years versus 49.9 years). However, the in-hospital death rate for patients hospitalized for birth defects was lower than the in-hospital death rate for all other conditions—1.3 percent versus 2.4 percent.

### Birth defects causing hospitalization

Table 2 highlights both general categories and specific birth defects that resulted in hospitalization. In 2004, cardiac and circulatory congenital anomalies accounted for 33.5 percent of birth defect hospitalizations, digestive congenital anomalies accounted for 18.5 percent of birth defect stays, and congenital genitourinary and nervous system anomalies accounted for 9.3 percent and 5.0 percent, respectively, of admissions for birth defects. All remaining birth defects accounted for about 33.8 percent of stays.

Table 2 Birth defects commonly causing hospitalization, 2004^*^

Principal diagnosis | Total number of hospital stays | Percentage of all stays for birth defects | Mean length of stay (days) | Mean costs (dollars) | Aggregate costs (dollars) | Percent male | Mean age | Percent died
All cardiac and circulatory congenital anomalies | 46,500 | 33.5% | 8.2 | $29,600 | $1,368,822,600 | 50.9% | 19.8 | 2.6%
Cerebrovascular anomalies | 3,500 | 2.5% | 4.7 | $18,800 | 65,980,500 | 50.7% | 39.4 | 1.0%
Tetralogy of fallot | 2,500 | 1.8% | 11.4 | $40,100 | 100,735,900 | 54.0% | 2.7 | 2.2%
Ventricular septal defect | 3,700 | 2.7% | 8.1 | $27,900 | 104,435,100 | 50.8% | 5.8 | 1.6%
Atrial septal defect | 8,800 | 6.4% | 3.1 | $15,000 | 132,584,700 | 40.7% | 38.0 | 0.3%
Patent ductus arteriosus | 2,500 | 1.8% | 12.7 | $31,300 | 77,595,700 | 39.5% | 3.5 | 1.6%
Coarctation of aorta | 2,600 | 1.9% | 8.7 | $29,300 | 75,468,300 | 63.0% | 6.4 | 1.2%
All digestive congenital anomalies | 25,800 | 18.5% | 6.3 | $11,700 | $303,173,100 | 67.8% | 7.5 | 0.4%
Pyloric stenosis | 12,500 | 9.0% | 2.5 | $4,100 | $51,256,200 | 80.8% | 0.0 | 0.0%
Rectal and large intestine atresia/stenosis | 2,100 | 1.5% | 9.1 | $18,400 | $37,856,000 | 56.5% | 0.6 | 0.6%
Meckel’s diverticulum | 2,400 | 1.7% | 6.1 | $11,800 | $28,174,000 | 70.4% | 31.7 | 0.2%
All genitourinary congenital anomalies | 12,900 | 9.3% | 4.1 | $8,900 | $114,709,700 | 52.0% | 23.3 | 0.3%
Obstructive genitourinary defect | 4,100 | 3.0% | 3.3 | $7,400 | $30,548,200 | 59.4% | 14.0 | 0.0%
Polycystic kidney | 2,700 | 2.0% | 4.8 | $11,900 | $32,434,300 | 51.7% | 44.6 | 0.4%
All nervous system congenital anomalies | 6,900 | 5.0% | 7.5 | $16,200 | $112,164,200 | 44.8% | 15.2 | 1.8%
All other congenital anomalies | 47,000 | 33.8% | 5.0 | $14,400 | $667,198,000 | 49.1% | 19.8 | 0.7%
Cleft palate without cleft lip | 2,900 | 2.1% | 2.1 | $5,400 | $15,506,700 | 49.8% | 2.4 | 0.0%
Congenital hip deformity | 2,200 | 1.5% | 3.6 | $12,500 | $26,930,200 | 28.6% | 27.4 | 0.0%
Congenital anomalies of skull and facial bones | 3,700 | 2.6% | 5.5 | $16,800 | $61,329,500 | 60.9% | 3.8 | 0.3%
Spondylolisthesis | 8,000 | 5.7% | 4.1 | $18,800 | $149,954,500 | 38.7% | 56.3 | 0.0%
Cleft lip with or without cleft palate | 4,900 | 3.6% | 1.9 | $5,500 | $27,155,800 | 59.4% | 4.2 | 0.1%
Pectus excavatum | 1,700 | 1.2% | 4.4 | $9,900 | $16,621,600 | 79.1% | 14.8 | 0.0%
Congenital anomalies of larynx, trachea and bronchus | 2,300 | 1.7% | 7.5 | $13,900 | $32,646,500 | 58.5% | 3.9 | 0.2%
Foot deformities | 2,900 | 2.1% | 1.8 | $5,900 | $16,873,900 | 56.0% | 11.6 | 0.0%
All birth defects | 139,100 | 100.0% | 6.3 | $18,600 | $2,566,067,700 | 53.3% | 17.6 | 1.3%

* Based on principal diagnosis. Birth defects with less than 2,000 hospitalizations are not shown.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2004.

In 2004, pyloric stenosis (a narrowing of the stomach that leads to vomiting) was the most common specific congenital anomaly causing hospitalization, accounting for 9.0 percent of all stays for birth defects. This was followed by atrial septal defects (a hole between the two smaller chambers in the heart) and spondylolisthesis (a condition where one vertebra slips forward), each of which resulted in about 6 percent of all hospitalizations for birth defects. Other common birth defects included cleft lip with or without cleft palate, obstructive genitourinary defects, ventricular septal defects (a hole between the two larger chambers of the heart), congenital anomalies of the skull and facial bones, cerebrovascular anomalies (such as cerebral aneurysm), cleft palate without cleft lip, and foot deformities.

Among the most common birth defects, the longest hospital stays were for patent ductus arteriosus (a persistent connection between the aorta and the pulmonary artery that normally closes shortly after birth, 12.7 days), tetralogy of fallot (a complex heart defect that is the most common cause of “blue baby syndrome,” 11.4 days), and rectal and large intestine atresia/stenosis (absence, closure, or constriction of the large intestine or rectum, 9.1 days).

Males predominated among hospitalizations for birth defects such as coarctation of the aorta (narrowing of the aorta, 63.0 percent), pyloric stenosis (80.8 percent male), Meckel’s diverticulum (a pouch of tissue on the wall of the small intestine, 70.4 percent), and pectus excavatum (sunken or funnel chest, 79.1 percent male). Conversely, females accounted for more hospitalizations for patent ductus arteriosus (39.5 percent male), congenital hip deformities (28.6 percent male), and spondylolisthesis (38.7 percent male).

Some birth defects are discovered and treated at birth or during infancy and early childhood. Other birth defects may be discovered much later. The mean age for patients admitted for the treatment of pyloric stenosis, rectal and large intestine atresia/stenosis, cleft palate without cleft lip, and tetralogy of fallot was less than 3 years. However, for other conditions such as Meckel’s diverticulum, atrial septal defect, cerebrovascular anomalies, polycystic kidney (clusters of cysts forming on the kidneys), and spondylolisthesis, patients were, on average, 30 years or older.

The highest aggregate costs were for stays related to cardiac and circulatory congenital anomalies, which accounted for about $1.4 billion—more than half of all hospital costs for birth defects. Similarly, the highest mean costs and the highest death rates were for cardiac and circulatory anomalies.

### Birth defects commonly noted during hospitalization

Table 3 lists birth defect diagnoses commonly noted during hospitalization as the principal or secondary diagnosis. In 2004, almost 86,300 hospital stays occurred among patients with an atrial septal defect, while patients with patent ductus arteriosus accounted for 59,500 admissions. About 40,000 hospital stays occurred among patients noted to have congenital pigmentary anomaly of the skin (discolorations of skin or hair), ventricular septal defect, or Down’s syndrome. Other birth defects commonly noted as either the principal reason for admission or a coexisting condition included spina bifida (incomplete development of the brain, spinal cord, and/or their protective coverings), polycystic kidney, spondylolisthesis, undescended testicle, and obstructive genitourinary defects.

Table 3 Birth defects commonly noted during hospitalization, 2004^*^

Rank | All-listed diagnoses | Total number of hospital stays
1 | Atrial septal defect | 86,300
2 | Patent ductus arteriosus | 59,500
3 | Congenital pigmentary anomalies of skin | 40,900
4 | Ventricular septal defect | 40,000
5 | Down’s syndrome | 38,000
6 | Spina bifida | 28,300
7 | Polycystic kidney | 27,300
8 | Spondylolisthesis | 23,200
9 | Undescended testicle | 20,900
10 | Obstructive genitourinary defect | 20,100
11 | Hypospadias and epispadias | 18,100
12 | Congenital anomalies of skull and facial bones | 17,500
13 | Foot deformities | 16,700
14 | Polydactyly (extra digits) and syndactyly (webbing between digits) | 16,100
15 | Pulmonary artery anomalies | 15,700
16 | Congenital hydrocephalus | 13,300
17 | Congenital insufficiency of aortic valve | 13,200
18 | Pyloric stenosis | 13,200
19 | Congenital anomalies of larynx, trachea and bronchus | 12,900
20 | Persistent fetal circulation | 12,400

* Based on all-listed diagnoses.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2004.

### Changes in hospitalizations for birth defects, 1997–2004

Figures 1 through 4 demonstrate changes in the hospitalization rates for general categories of birth defects between 1997 and 2004. When listed as the principal reason for admission, the hospitalization rate for cardiac and circulatory congenital anomalies remained relatively stable between 1997 and 2004 (figure 1). However, when noted as either the principal or coexisting condition (i.e., all-listed diagnoses), the hospitalization rate for these birth defects increased by 28.5 percent. Similarly, figure 2 shows that the hospitalization rate for all-listed digestive congenital anomalies increased significantly between 1997 and 2004—rising by 25.3 percent.

Figure 1 Hospitalization rates for cardiac and circulatory congenital anomalies, 1997–2004

*U.S. Census Bureau, Population Division, Census 1997–2004.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 1997–2004.

Figure 2 Hospitalization rates for digestive congenital anomalies, 1997–2004

*U.S. Census Bureau, Population Division, Census 1997–2004.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 1997–2004.

Figure 3 Hospitalization rates for genitourinary congenital anomalies, 1997–2004

*U.S. Census Bureau, Population Division, Census 1997–2004.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 1997–2004.

Figure 4 Hospitalization rates for nervous system congenital anomalies, 1997–2004

*U.S. Census Bureau, Population Division, Census 1997–2004.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 1997–2004.

Between 1997 and 2004, the hospitalization rate for genitourinary congenital anomalies decreased by 17.0 percent when listed as the principal diagnosis, but increased by 13.0 percent when noted as either a principal or coexisting condition (figure 3). When noted as the principal reason for treatment, the hospitalization rate for nervous system congenital anomalies remained stable over the eight-year time period, even though all-listed diagnoses increased by 11.9 percent (figure 4).

## Data Source

The estimates in this Statistical Brief are based on data from the HCUP 2004 Nationwide Inpatient Sample (NIS). Historical data were drawn from the 1997, 1998, 1999, 2000, 2001, 2002, and 2003 NIS. Supplemental sources included data on national population estimates from Table 8: Annual Estimates of the Population for the United States, Regions, and Divisions: April 1, 2000 to July 1, 2005 (NST-EST2005-08), Population Division, U.S. Census Bureau, Release Date: December 22, 2005 (http://www.census.gov/popest/states/tables/NST-EST2005-08.xls) and Historical National Population Estimates: July 1, 1900 to July 1, 1999, Population Division, U.S. Census Bureau, Release Date: April 11, 2000 (http://www.census.gov/popest/archives/1990s/popclockest.txt).

## Definitions

### Types of hospitals included in HCUP

HCUP is based on data from community hospitals, defined as short-term, non-Federal, general and other hospitals, excluding hospital units of other institutions (e.g., prisons). HCUP data include OB-GYN, ENT, orthopedic, cancer, pediatric, public, and academic medical hospitals. They exclude long-term care, rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals, but these types of discharges are included if they are from community hospitals.

### Unit of analysis

The unit of analysis is the hospital discharge (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the hospital multiple times in one year will be counted each time as a separate “discharge” from the hospital.

### Costs and charges

Total hospital charges were converted to costs using HCUP cost-to-charge ratios based on hospital accounting reports from the Centers for Medicare and Medicaid Services (CMS).^2^ Costs will tend to reflect the actual costs of production, while charges represent what the hospital billed for the case. For each hospital, a hospital-wide cost-to-charge ratio is used because detailed charges are not available across all HCUP States. Hospital charges reflect the amount the hospital charged for the entire hospital stay and does not include professional (physician) fees. For the purposes of this Statistical Brief, costs are reported to the nearest hundreds.

### Diagnoses, ICD-9-CM, and Clinical Classifications Software (CCS)

The principal diagnosis is that condition established after study to be chiefly responsible for the patient’s admission to the hospital. Secondary diagnoses are concomitant conditions that coexist at the time of admission or that develop during the stay. All-listed diagnoses include the principal diagnosis plus these additional secondary conditions.

ICD-9-CM is the International Classification of Diseases, Ninth Revision, Clinical Modification, which assigns numeric codes to diagnoses. There are about 12,000 ICD-9-CM diagnosis codes.

CCS categorizes ICD-9-CM diagnoses into 260 clinically meaningful categories.^3^ This “clinical grouper” makes it easier to quickly understand patterns of diagnoses and procedures.

### Discharge status

Discharge status indicates the disposition of the patient at discharge from the hospital, and includes the following six categories: routine (to home), transfer to another short-term hospital, other transfers (including skilled nursing facility, intermediate care, and another type of facility such as a nursing home), home health care, against medical advice (AMA), or died in the hospital.

## For More Information

For a detailed description of HCUP and more information on the design of the NIS and methods to calculate estimates, please refer to the following publications:

Steiner, C., Elixhauser, A., Schnaier, J. The Healthcare Cost and Utilization Project: An Overview. Effective Clinical Practice 5(3):143–51, 2002.

Design of the HCUP Nationwide Inpatient Sample, 2004. Online. August 8, 2006. U.S. Agency for Healthcare Research and Quality. http://www.hcup-us.ahrq.gov/db/nation/nis/reports/NIS_2004_Design_Report.pdf

Houchens, R., Elixhauser, A. Final Report on Calculating Nationwide Inpatient Sample (NIS) Variances, 2001. HCUP Methods Series Report #2003-2. Online. June 2005 (revised June 6, 2005). U.S. Agency for Healthcare Research and Quality. http://www.hcup-us.ahrq.gov/reports/CalculatingNISVariances200106092005.pdf

Houchens R. L., and Elixhauser, A. Using the HCUP Nationwide Inpatient Sample to Estimate Trends. (Updated for 1988–2004). HCUP Methods Series Report #2006-05. Online. August 18, 2006. U.S. Agency for Healthcare Research and Quality. http://www.hcup-us.ahrq.gov/reports/2006_05_NISTrendsReport_1988-2004.pdf

1 Centers for Disease Control and Prevention, National Center on Birth Defects and Developmental Disabilities. http://www.cdc.gov/node.do/id/0900f3ec8000dffe (Accessed on December 21, 2006)

2 HCUP Cost-to-Charge Ratio Files (CCR). Healthcare Cost and Utilization Project (HCUP). 2001–2003. U.S. Agency for Healthcare Research and Quality, Rockville, MD. www.hcup-us.ahrq.gov/db/state/costtocharge.jsp.

3 HCUP Clinical Classifications Software (CCS). Healthcare Cost and Utilization Project (HCUP). August 2006. U.S. Agency for Healthcare Research and Quality, Rockville, MD. www.hcup-us.ahrq.gov/toolssoftware/ccs/ccs.jsp