# Statistical Brief #235 Trends in Hospital Inpatient Stays by Age and Payer, 2000–2015

## Introduction

The utilization of hospital care is related to and affected by changes in population characteristics, as well as market forces. In terms of population characteristics, growth in general and growth of the older adult population in particular may contribute to hospital visits.^1^ The U.S. population has grown in the past decades, and the population of older adults has grown disproportionately.^2^ Projections show that one in five Americans will be 65 years or older by 2030.^3^

In terms of market forces, factors such as efforts to reduce unnecessary hospitalization^4^ and adjustments in reimbursement incentives may decrease utilization of inpatient care.^5^ Market forces also may vary across age groups and eventually shift hospital utilization in terms of payer mix for those who seek care. Examples of such factors include employment status^6^ and changes in health care policy that target age groups differently.

This Healthcare Cost and Utilization Project (HCUP) Statistical Brief presents data on hospital inpatient stays from 2000 through 2015 by age group and primary payer. First, trends in the population rate of inpatient stays by age group are presented. Second, trends in expected primary payer among inpatient stays by age group are examined. The National Inpatient Sample (NIS) from 2000 to 2015 was used to generate national estimates of inpatient stays. The total number of inpatient stays related to maternal and neonatal diagnoses accounted for 22–25 percent of all inpatient stays, and for 34–46 percent of those stays, Medicaid was the primary expected payer. Because of the relative size of this subpopulation and the high concentration in the distribution of expected payer, maternal and neonatal stays were excluded from the analysis.

## Findings

Highlights

■ Between 2000 and 2015, the population rate of nonneonatal, nonmaternal inpatient stays dropped for all age groups; the largest percentage decrease (25 percent) was among patients aged 65 years and over.
■ Between 2000 and 2015, for all age groups under 65 years old the share of uninsured stays reached its 16-year low in 2015.
■ From 2007 to 2015, Medicaid was the top primary payer for patients under age 18 years with nonneonatal, nonmaternal inpatient stays; its share exceeded 50 percent starting in 2012.
■ From 2000 to 2015, the share of Medicaid among nonneonatal, nonmaternal inpatient stays for those aged 18–44 years and 45–64 years increased by 74 percent and 68 percent, respectively.
■ Among patients aged 18–44 years, the share of nonneonatal, nonmaternal inpatient stays covered by Medicare increased by 21 percent from 2000 to 2015.
■ Among patients aged 45–64 years, the share of nonneonatal, nonmaternal stays covered by Medicare increased by 43 percent from 2000 to 2015.
■ Among patients aged 65 years and over, Medicare and private insurance together accounted for about 97 percent of inpatient stays each year.

### National rate of inpatient stays by patient age, 2000–2015

Figure 1 presents the rate of nonneonatal, nonmaternal inpatient stays per 100,000 population from 2000 to 2015. Results are shown by four age groups.

Figure 1 Rate of nonneonatal, nonmaternal inpatient stays, per 100,000 population by age group, 2000–2015

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets. Healthcare Cost and Utilization Project (HCUP), National (Nationwide) Inpatient Sample (NIS), 2000–2015

Line graph that shows the rate of nonneonatal, nonmaternal inpatient stays per 100,000 by age from 2000 to 2015. <18 years: 2000, 2,603; 2001, 2,731; 2002, 2,661; 2003, 2,832; 2004, 2,778; 2005, 3,236; 2006, 2,623; 2007, 2,492; 2008, 2,354; 2009, 2,399; 2010, 2,632; 2011, 2,104; 2012, 2,338; 2013, 2,220; 2014, 2,133; 2015, 2,117; net change −19%. 18–44 years: increased steadily from 4,771 in 2000 to 4,971 in 2004; decreased to 4,773 in 2005; increased to 4,837 in 2006; decreased steadily to 4,684 in 2009; increased to 4,702 in 2010; decreased steadily to 4,023 in 2014; increased to 4,024 in 2015; net change −16%. 45–64 years: increased steadily from 11,459 in 2000 to 11,738 in 2003; decreased steadily to 11,437 in 2005; increased to 11,662 in 2006; decreased to 11,422 in 2007, increased to 11,572 in 2008; decreased steadily to 10,416 in 2014; increased to 10,437 in 2015; net change −9%. 65+ years: increased from 35,214 in 2000 to 36,620 in 2001; decreased steadily to 34,938 in 2004; increased to 35,170 in 2005; decreased to 33,649 in 2007; increased to 34,380 in 2008; decreased steadily to 31,332 in 2010; increased to 31,861 in 2011; decreased steadily to 26,480 in 2015; net change −25%.

■ Older age groups have higher rates of nonneonatal and nonmaternal inpatient rates.
  During the 16-year time period, patients aged 65 years and over had the highest rate of inpatient stays (above 26,400 per 100,000 population every year), followed by those aged 45–64 years (ranging from about 10,400 to 11,700 per 100,000 population). Patients aged 18 years and under were the most infrequent visitors for nonneonatal and nonmaternal inpatient stays, with a rate below 3,300 per 100,000 population every year.
■ The rate of nonneonatal and nonmaternal inpatient stays reached the lowest levels in 2014 or 2015 for all age groups.
  Among patients aged 65 years and over, the rate of inpatient stays was 35,214 per 100,000 population in 2000. The rate stayed at or above 35,000 until 2005 when it started to drop. By 2015, the rate had decreased to its lowest level during this period—26,480 per 100,000 population—a 25 percent reduction compared with 2000.
  Among patients aged 45–64 years, the rate of nonneonatal, nonmaternal inpatient stays was 11,459 per 100,000 population in 2000 and remained above 11,400 through 2010 after which it began to drop. By 2015, the rate has decreased to 10,437 per 100,000 population, a 9 percent decrease since 2000.
  Among patients aged 18–44 years, the rate was 4,771 per 100,000 population in 2000 and stayed at or above 4,700 per 100,000 through 2010. The rate began to drop below this level in 2011, and by 2015 the rate had decreased to 4,024, a 16 percent reduction since 2000.
  Among patients aged 18 years and under, the rate stayed above 2,600 from 2000 to 2006, with the highest rate reached in 2005 (3,236 per 100,000 population). In 2015, the rate reached its lowest level in 16 years at 2,117 per 100,000 population, a decrease of 19 percent since 2000.

### Trends in primary payer among nonneonatal, nonmaternal inpatient stays by patient age, 2000–2015

Figures 2 to 5 present national trends in expected primary payer for nonneonatal, nonmaternal inpatient care for each age group from 2000 to 2015.

Figure 2 National trends in primary payer among nonneonatal, nonmaternal inpatient stays for patients under age 18 years, 2000–2015

Note: Shares of “Missing” and “Other” payers are not presented.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets. Healthcare Cost and Utilization Project (HCUP), National (Nationwide) Inpatient Sample (NIS), 2000–2015

Line graph that shows the share of each payer among neonatal and nonmaternal inpatient stays for patients aged <18 years from 2000 to 2015. Medicaid: increased steadily from 38.9% in 2000 to 44.9% in 2004; decreased to 43.5% in 2005; increased steadily to 50.8% in 2010; decreased to 48.8% in 2011; increased steadily to 53.7% in 2015; net change +38%. Private insurance: increased from 52.5% in 2000 to 52.8% in 2001; decreased steadily to 46.7% in 2004; increased to 47.8% in 2005; decreased steadily to 45.0% in 2007; increased to 46.0% in 2008; decreased steadily to 41.7% in 2010; increased to 43.7% in 2011; decreased steadily to 39.5% in 2015; net change −25%. Uninsured: decreased steadily from 4.9% in 2000 to 3.8% in 2003; increased to 4.5% in 2004; decreased steadily to 3.9% in 2006; increased to 4.3% in 2007; decreased to 3.5% in 2008; increased to 4.2% in 2009; decreased steadily to 2.6% in 2011; increased steadily to 2.8% in 2013; decreased steadily to 2.5% in 2015; net change −49%. Medicare: fluctuated between 0.2 and 0.5 between 2000 and 2015; began and ended at 0.3%; net change −26%.

Figure 3 National trends in primary payer among nonneonatal, nonmaternal inpatient stays for patients aged 18–44 years, 2000–2015

Note: Shares of “Missing” and “Other” payers are not presented.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets. Healthcare Cost and Utilization Project (HCUP), National (Nationwide) Inpatient Sample (NIS), 2000–2015

Line graph that shows the share of each payer among neonatal and nonmaternal inpatient stays for patients aged 18–44 years from 2000 to 2015. Medicaid: increased steadily from 19.9% in 2000 to 22.9% in 2005; decreased steadily to 21.6% in 2007; increased steadily to 26.3% in 2010; decreased to 25.7% in 2011; increased steadily to 34.6% in 2015; net change +74%. Private insurance: increased from 50.5% in 2000 to 50.7% in 2001; decreased steadily to 45.4% in 2004; increased to 45.5% in 2005; decreased steadily to 43.7% in 2007; increased to 45.6% in 2008; decreased steadily to 38.3% in 2010; increased to 39.6% in 2011; decreased steadily to 37.1% in 2014 and 2015; net change −27%. Uninsured: increased from 12.7 in 2000 and 2001 to 13.3% in 2002; decreased to 12.9% in 2003; increased steadily to 16.6% in 2007; decreased to 15.0% in 2008; increased steadily to 17.4% in 2010; decreased to 16.5% in 2011; increased steadily to 17.6% in 2013; decreased steadily to 11.9% in 2015; net change −6%. Medicare: decreased steadily from 9.5% in 2000 to 9.3% in 2002; increased steadily to 11.9% in 2013; decreased steadily to 11.5% in 2015; net change +21%.

Figure 4 National trends in primary payer among nonneonatal, nonmaternal inpatient stays for patients aged 45–64 years, 2000–2015

Note: Shares of “Missing” and “Other” payers are not presented.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets. Healthcare Cost and Utilization Project (HCUP), National (Nationwide) Inpatient Sample (NIS), 2000–2015

Line graph that shows the share of each payer among neonatal and nonmaternal inpatient stays for patients aged 45–64 years from 2000 to 2015. Medicaid: fluctuated between 13.2% and 13.3% from 2000 to 2002; increased steadily 14.9% in 2006; decreased to 14.4% in 2007 and 2008; increased steadily to 17.1% in 2010; decreased to 16.8% in 2011; increased steadily to 22.1% in 2015; net change +68%. Private insurance: increased from 57.0% in 2000 to 57.1% in 2001; decreased steadily to 50.3% in 2007; increased to 51.3% in 2008; decreased steadily to 41.9% in 2014; increased to 42.0% in 2015; net change −26%. Uninsured: increased from 6.4% in 2000 and 2001 to 6.8% in 2002; decreased to 6.4% in 2003; increased steadily to 8.2% in 2007; decreased to 7.7% in 2008; increased steadily to 9.3% in 2010; decreased to 8.6% in 2011; increased steadily to 9.6% in 2013; decreased steadily to 6.1% in 2015; net change −4%. Medicare: increased steadily from 17.9% in 2000 to 25.5% in 2015; net change +43%.

Figure 5 National trends in primary payer among nonneonatal, nonmaternal inpatient stays for patients aged 65 years and over, 2000–2015

Note: Shares of “Missing” and “Other” payers are not presented.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets. Healthcare Cost and Utilization Project (HCUP), National (Nationwide) Inpatient Sample (NIS), 2000–2015

Line graph that shows the share of each payer among stays for patients aged 65 years and over from 2000 to 2015. Medicaid: fluctuated between 1.3% and 1.8% between 2000 and 2015, starting at 1.5% in 2000 and ending at 1.4% in 2015; net change −7%. Private insurance: decreased from 8.2% in 2000 and 2001 to 6.2% in 2003; increased to 7.3% in 2004; decreased to 6.5% in 2005; increased steadily to 8.9% in 2008; decreased steadily to 7.1% in 2012; increased steadily to 7.6% in 2014; decreased to 7.5% in 2015; net change −9%. Uninsured: fluctuated between 0.4% and 0.7% between 2000 and 2015, starting and ending at 0.6%; net change −3%. Medicare: decreased from 88.6% in 2000 to 88.5% in 2001; increased steadily to 90.9% in 2003; decreased to 89.7% in 2004; increased to 90.9% in 2005; decreased steadily to 87.7% in 2008; increased to 88.1 in 2009; decreased to 88.0% in 2010; increased steadily to 89.8% in 2012; decreased steadily to 89.1% in 2014 and 2015; net change +1%.

■ Starting in 2007, Medicaid replaced private insurance as the most common primary payer for nonneonatal and nonmaternal inpatient stays among those under age 18 years.
  In 2000, the most common payer for nonneonatal and nonmaternal inpatient stays among patients under age 18 years was private insurance (52.5 percent), followed by Medicaid (38.9 percent). By 2015, the share of Medicaid had reached 53.7 percent, which is an increase of 38 percent since 2000. By 2015, the share of private insurance had dropped to 39.5 percent, its lowest level in 16 years—a decrease of 25 percent since 2000.
  The share of uninsured patients within this age group fluctuated between 3.2 and 4.9 percent from 2000 to 2010 and dropped to 2.8 percent or below thereafter. The share of Medicare within this age group stayed below 0.5 percent in all years.
■ Among nonneonatal, nonmaternal inpatient stays for 18-to-44-year-olds, private insurance was the most common primary payer, followed by Medicaid.
  The most common primary payer for nonneonatal and nonmaternal inpatient stays among patients aged 18–44 years was private insurance, which accounted for 50.5 percent of stays in 2000 and dropped to 37.5 percent in 2013. During the same period, the share of Medicaid increased from 19.9 percent to 26.5 percent, the share of uninsured increased from 12.7 percent to 17.6 percent, and the share of Medicare increased from 9.5 percent to 11.9 percent.
■ From 2013 to 2015, the share of Medicaid within this age group increased and the share of uninsured decreased.
  The share of Medicaid in 2015 was 34.6 percent, which is an increase of 74 percent since 2000. The share of uninsured in 2015 dropped to 11.9 percent, its lowest level during these 16 years.
  The share of private insurance dropped to 37.1 percent in 2015 and remained as the most common payer within this age group. The share of Medicare in 2015 was 11.5, an increase of 21 percent since 2000.
■ Among nonneonatal, nonmaternal inpatient stays for patients aged 45–64 years, private insurance was the most common primary payer, followed by Medicare.
  The share of private insurance among inpatient stays for patients aged 45–64 years dropped from 57.0 percent in 2000 to 42.1 percent in 2013. During the same period, the share of Medicare increased from 17.9 percent to 25.1 percent, the share of Medicaid increased from 13.2 percent to 17.6 percent, and the share of uninsured increased from 6.4 percent to 9.6 percent, which remained the lowest among all payers for this age group.
■ From 2013 to 2015, the share of inpatient stays covered by Medicaid increased and the share that were uninsured decreased.
  By 2015, the share of inpatient stays covered by Medicaid in this age group had increased to 22.1 percent, an increase of 68 percent since 2000. The share of stays that were uninsured had dropped to 6.1 percent, its lowest level during this period.
  The share of inpatient stays covered by private insurance in 2014 and 2015 was at about the same level as it had been in 2013. From 2000 to 2015, the share of stays covered by private insurance decreased by 26 percent, but private insurance remained the most common primary payer. The share of stays covered by Medicare reached 25.5 percent in 2015, an increase of 43 percent since 2000.
■ Medicare and private insurance accounted for about 97 percent of nonneonatal and nonmaternal inpatient stays among patients aged 65 years and over.
  Among patients aged 65 years and over, the share of inpatient stays covered by Medicare fluctuated between 88 and 91 percent during the 2000–2015 period; at the same time, the share of stays covered by private insurance fluctuated between 6 and 9 percent. These two payers together consistently covered about 97 percent of the inpatient stays within this age group during the 16-year period.
  Within this age group, the share of stays covered by Medicaid remained under 2 percent, and the share of stays that were uninsured remained under 0.8 percent.

To summarize across age groups, from 2000 to 2015, for patients aged 64 years or younger, the share of inpatient stays with an expected primary payer of private insurance decreased and the share of stays with Medicaid increased. The share of uninsured stays reached its 16-year low in 2015. For patients aged 18–64 years, the share of stays with Medicare increased during the 16-year period.

## Data Source

The estimates in this Statistical Brief are based upon data from the Healthcare Cost and Utilization Project (HCUP) 2000–2015 National (Nationwide) Inpatient Sample (NIS). Supplemental sources included population denominator data for use with HCUP databases, derived from information available from the Bureau of the Census.^7^

## Definitions

### Unit of analysis

The unit of analysis is the hospital discharge (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the hospital multiple times in 1 year will be counted each time as a separate discharge from the hospital.

### Payer

Payer is the expected primary payer for the hospital stay. To make coding uniform across all HCUP data sources, payer combines detailed categories into general groups:

- Medicare: includes patients covered by fee-for-service and managed care Medicare
- Medicaid: includes patients covered by fee-for-service and managed care Medicaid
- Private Insurance: includes Blue Cross, commercial carriers, and private health maintenance organizations (HMOs) and preferred provider organizations (PPOs)
- Uninsured: includes an insurance status of self-pay and no charge
- Other: includes Workers' Compensation, TRICARE/CHAMPUS, CHAMPVA, Title V, and other government programs

Hospital stays billed to the State Children's Health Insurance Program (SCHIP) may be classified as Medicaid, Private Insurance, or Other, depending on the structure of the State program. Because most State data do not identify patients in SCHIP specifically, it is not possible to present this information separately.

### Diagnosis-related groups (DRGs) and major diagnostic categories (MDCs)

DRGs comprise a patient classification system that categorizes patients into groups that are clinically coherent and homogeneous with respect to resource use. DRGs group patients according to diagnosis, type of treatment (procedures), age, and other relevant criteria. Each hospital stay has one assigned DRG.

Coding criteria for the types of hospitalization are based on MDCs. MDCs are broad groups of DRGs that relate to an organ or a body system (e.g., digestive system) and not to an etiology. For example, MDC 01 – Diseases and Disorders of the Nervous System and MDC 02 – Diseases and Disorders of the Eye. Each hospital stay has one DRG and one MDC assigned to it.

In this Statistical Brief, nonneonatal and nonmaternal hospitalizations are identified using the MDCs that are not equal to 14 (Pregnancy, Childbirth and the Puerperium) or 15 (Newborns and Other Neonates with Conditions Originating in the Perinatal Period).

### Types of hospitals included in the HCUP National (Nationwide) Inpatient Sample

The National (Nationwide) Inpatient Sample (NIS) is based on data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). The NIS includes obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded are long-term care facilities such as rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. Beginning in 2012, long-term acute care hospitals are also excluded. However, if a patient received long-term care, rehabilitation, or treatment for a psychiatric or chemical dependency condition in a community hospital, the discharge record for that stay will be included in the NIS.

## For More Information

For other information on hospitalizations in the United States, refer to the HCUP Statistical Briefs located at www.hcup-us.ahrq.gov/reports/statbriefs/sb_hospoverview.jsp.

For additional HCUP statistics, visit:

- HCUP Fast Stats at www.hcup-us.ahrq.gov/faststats/landing.jsp for easy access to the latest HCUP-based statistics for health information topics
- HCUPnet, HCUP's interactive query system, at www.hcupnet.ahrq.gov/

For more information about HCUP, visit www.hcup-us.ahrq.gov/.

For a detailed description of HCUP and more information on the design of the National (Nationwide) Inpatient Sample (NIS), please refer to the following database documentation:

Agency for Healthcare Research and Quality. Overview of the National (Nationwide) Inpatient Sample (NIS). Healthcare Cost and Utilization Project (HCUP). Rockville, MD: Agency for Healthcare Research and Quality. Updated December 2016. www.hcup-us.ahrq.gov/nisoverview.jsp. Accessed January 31, 2017 .

1 Bernstein AB, Hing E, Moss AJ, Allen KF, Siller AB, Tiggle RB. Health Care in America: Trends in Utilization. 2003. National Center for Health Statistics. www.cdc.gov/nchs/data/misc/healthcare.pdf. Accessed December 19, 2017 .

2 Howden LM, Meyer JA. Age and Sex Composition: 2010. 2010 Census Briefs, May 2011. U.S. Census Bureau. www.census.gov/content/dam/Census/library/publications/2011/dec/c2010br-03.pdf. Accessed December 19, 2017 .

3 Colby SL, Ortman JM. Projections of the Size and Composition of the U.S. population: 2014 to 2060. Current Population Reports. March 2015. U.S. Census Bureau. www.census.gov/content/dam/Census/library/publications/2015/demo/p25-1143.pdf. Accessed December 19, 2017 .

4 Leslie DL, Rosenheck R. Shifting to outpatient care? mental health care use and cost under private insurance. American Journal of Psychiatry. 1999;156(8):1250–7 10450268 .

5 Bernstein et al., 2003. Op. cit.

6 Maeda JL, Henke RM, Marder WD, Karaca Z, Friedman BS, Wong HS. Association between the unemployment rate and inpatient cost per discharge by payer in the United States, 2005–2010. BMC Health Services Research. 2014;14:378 25311258 .

7 Barrett M, Coffey R, Levit K. Population Denominator Data for Use With the HCUP Databases (Updated With 2016 Population Data). HCUP Methods Series Report # 2017-04 ONLINE. October 17, 2017. U.S. Agency for Healthcare Research and Quality. www.hcup-us.ahrq.gov/reports/methods/methods.jsp. Accessed November 22, 2017 .