# Statistical Brief #233 Overview of Operating Room Procedures During Inpatient Stays in U.S. Hospitals, 2014

## Introduction

The majority of patients admitted to the hospital undergo at least one type of procedure during their stay.^1^ Many diagnostic and therapeutic procedures, such as x-rays and blood transfusions, are performed outside of the operating room (OR), whereas surgical procedures, such as Cesarean sections and hip replacements, take place in the OR. On average, hospital costs for stays with OR procedures are more than double the costs for inpatient stays without OR procedures.^2,3^

Identifying the characteristics, costs, and volume of OR procedures can guide health care improvement efforts. Such information can also provide baseline data for assessing the potential impact of advances in medical practice and technology and changes in health care provider arrangements.

This Healthcare Cost and Utilization Project (HCUP) Statistical Brief updates previous HCUP reports focused on OR procedures in the inpatient setting,^4,5,6,7^ presenting data from U.S. hospitals in 2014, the last full year that procedures were coded using ICD-9-CM. In this Statistical Brief, OR procedures are defined using diagnosis-related group (DRG) algorithms, which were based on reviews by clinical panels. The percentage of all inpatient stays involving operating room (OR) procedures and the percentage of aggregate costs attributed to inpatient stays involving OR procedures are presented. Patient characteristics, resource use, and outcomes are provided for inpatient stays with OR procedures. The most frequent and most costly OR procedures are also presented. Differences in estimates of 10 percent or greater are noted in the text.

## Findings

Highlights

■ In 2014, 10.1 million inpatient hospital stays involved operating room (OR) procedures with a total of 14.2 million OR procedures. Aggregate hospital costs for stays with OR procedures were $187.1 billion.
■ Although just over one-quarter (28.6 percent) of all hospital stays involved OR procedures, these stays accounted for nearly half (48.4 percent) of aggregate hospital costs.
■ Compared with stays without OR procedures, stays involving OR procedures were longer on average (5.1 vs. 4.4 days) and had higher average costs ($18,500 vs. $7,900).
■ In 2014, 36.7 percent of stays that were privately insured involved OR procedures compared with 23–25 percent of stays among other types of payers.
■ Cesarean section, knee arthroplasty, hip replacement, and percutaneous coronary angioplasty (PTCA) were among the five most common OR procedures (along with circumcision) and the five OR procedures with the highest aggregate hospital costs (along with spinal fusion).
■ Three musculoskeletal procedures—hip replacement, knee arthroplasty, and spinal fusion—accounted for 12.2 percent of all OR procedures and 19.6 percent of aggregate costs for all inpatient stays with a first-listed OR procedure.

### Characteristics of inpatient stays involving operating room procedures, 2014

Figure 1 shows the percentage of all inpatient stays with operating room (OR) procedures and the percentage of aggregate hospital costs attributed to stays involving OR procedures.

Figure 1 Percentage of inpatient stays and aggregate costs for inpatient stays with and without operating room (OR) procedures, 2014

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP) National Inpatient Sample (NIS), 2014

Bar chart that shows the percentage of inpatient stays and aggregate costs for inpatient stays with and without OR procedures in 2014. Number of inpatient stays: 28.6% with OR procedures; 71.4% without OR procedures. Aggregate costs: 48.4% with OR procedures; 51.6% without OR procedures.

■ Inpatient stays with OR procedures accounted for more than one-fourth of all hospitalizations and almost half of all aggregate hospital costs in 2014.
  In 2014, 28.6 percent of all inpatient stays involved at least one OR procedure, but costs for stays with OR procedures constituted 48.4 percent of all aggregate hospital costs.

Table 1 presents select utilization characteristics and outcomes for inpatient stays with and without OR procedures in 2014. The unit of analysis is the inpatient stay; stays that listed an OR procedure in any procedure field are compared with those that did not involve any OR procedures.

Table 1 Utilization and outcomes for inpatient hospital stays with and without operating room (OR) procedures, 2014

Characteristic or outcome | Stays with one or more OR procedures | Stays without any OR procedures
Number of stays | 10,115,800 | 25,243,000
All hospital stays, % | 28.6 | 71.4
Rate of stays per 100,000 population | 3,172.5 | 7,916.7
Aggregate costs, $ billions | 187.1 | 199.1
Aggregate costs, % | 48.4 | 51.6
Mean cost per stay, $ | 18,500 | 7,900
Mean length of stay, days | 5.1 | 4.4
Mean cost per day, $ | 4,800 | 2,100
Admitted from emergency department, % | 27.7 | 58.7
Discharge status, %
Discharged to self-care (routine discharge) or home health care | 83.0 | 80.3
Transferred to short-term hospital | 0.8 | 2.5
Transferred to other type of facility, including long-term care | 14.8 | 13.5
Died in hospital | 1.2 | 2.2
Other^a^ | 0.2 | 1.5

Notes: Number of stays, mean cost per stay, and mean cost per day are rounded to the nearest hundred.

a Other discharges include alive/destination unknown, against medical advice, and missing.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP) National Inpatient Sample (NIS), 2014

■ On average, inpatient stays involving OR procedures were longer and more than twice as expensive as stays without OR procedures.
  In 2014, inpatient stays involving OR procedures averaged 5.1 days in length with an average cost of $18,500, compared with 4.4 days and $7,900 for stays without OR procedures.
■ Compared with inpatient stays without OR procedures, a lower percentage of stays involving OR procedures began in the emergency department or ended with in-hospital death.
  In 2014, only 27.7 percent of inpatient stays involving OR procedures were admitted from the emergency department, compared with nearly 60 percent of stays without OR procedures.
  The percentage of stays that resulted in in-hospital death was lower among stays that involved OR procedures than stays without OR procedures (1.2 vs. 2.2 percent). Similarly, the percentage of stays transferred to a short-term hospital was lower among stays that involved OR procedures than those that did not (0.8 vs. 2.5 percent).

Table 2 presents select patient characteristics for inpatient stays with and without OR procedures in 2014.

Table 2 Distribution of inpatient stays with and without operating room (OR) procedures, by patient characteristic, 2014

Characteristic | Stays with one or more OR procedures | | Stays without any OR procedures
Characteristic | Number | % | Number | %
All stays | 10,115,800 | 100.0 | 25,243,000 | 100.0
Sex
Male | 4,776,200 | 47.2 | 10,319,500 | 40.9
Female | 5,337,900 | 52.8 | 14,917,700 | 59.1
Age, years
<1^a^ | 1,136,400 | 11.2 | 3,111,400 | 12.3
1–17 | 272,100 | 2.7 | 1,075,200 | 4.3
18–44 | 2,568,100 | 25.4 | 6,146,800 | 24.4
45–64 | 2,844,000 | 28.1 | 5,865,300 | 23.2
65–84 | 2,851,200 | 28.2 | 6,638,900 | 26.3
85+ | 441,100 | 4.4 | 2,396,600 | 9.5
Expected primary payer
Medicare | 3,505,400 | 34.7 | 10,289,700 | 40.8
Medicaid | 1,903,500 | 18.8 | 6,090,000 | 24.1
Private insurance | 3,970,900 | 39.3 | 6,862,100 | 27.2
Uninsured | 375,200 | 3.7 | 1,275,200 | 5.1
Community-level income
Low (lowest quartile) | 2,610,300 | 25.8 | 7,634,300 | 30.2
Not low (upper 3 quartiles) | 7,505,500 | 74.2 | 17,608,600 | 69.8
Location of patient residence
Large central metropolitan | 2,861,800 | 28.3 | 7,839,700 | 31.1
Large fringe metropolitan (suburbs) | 2,501,800 | 24.7 | 5,914,200 | 23.4
Medium and small metropolitan | 3,045,100 | 30.1 | 7,344,100 | 29.1
Micropolitan and noncore (rural) | 1,670,300 | 16.5 | 4,014,400 | 15.9

Notes: Number of stays is rounded to the nearest hundred. Percentage is based on unrounded data values. Unspecified, missing, and “other” categories are not reported.

a The vast majority of inpatient stays with OR procedures among infants involved male circumcision.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP) National Inpatient Sample (NIS), 2014

■ Females accounted for more than half of inpatient stays with and without OR procedures.
  In 2014, 52.8 percent of hospital stays involving OR procedures were among females, and 47.2 percent of OR-related stays were among males. Females constituted an even larger proportion of inpatient stays that did not involve an OR procedure—59.1 percent.
■ In 2014, the youngest and the oldest age groups accounted for the fewest hospital stays involving OR procedures.
  Although age distributions were similar among stays with and without OR procedures, the youngest and oldest age groups accounted for a smaller proportion of stays with OR procedures than stays without OR procedures (11.2 vs. 12.3 percent for patients younger than 1 year, 2.7 vs. 4.3 percent for patients aged 1–17 years, and 4.4 vs. 9.5 percent for patients aged 85 years and older). Conversely, patients aged 45–64 years accounted for a larger proportion of stays with OR procedures (28.1 percent) than stays without OR procedures (23.2 percent).
■ Private insurance and Medicare were the most common expected primary payers for inpatient stays with OR procedures in 2014.
  Among inpatient stays involving OR procedures, the most common payers were private insurance (39.3 percent of stays with OR procedures) and Medicare (34.7 percent). For stays that did not involve OR procedures, Medicare was the most common payer (40.8 percent of stays) and privately insured stays made up only 27.2 percent.

Figure 2 shows the percentage of inpatient stays that involved OR procedures for select patient subgroups in 2014. Whereas Table 2 shows the distribution of all stays with OR procedures, this figure simply reports the percentage of each patient subgroup that underwent one or more OR procedures.

Figure 2 Percentage of inpatient stays that involved operating room (OR) procedures, by patient characteristic, 2014

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP) National Inpatient Sample (NIS), 2014

Bar chart that shows the percentage of inpatient stays with OR procedures in 2014 by patient characteristics. Sex: male, 31.6%; female, 26.4%. Age: <1 year, 26.8%; 1–17 years, 20.2%; 18–44 years, 29.5%; 45–64 years, 32.7%; 65–84 years, 30.0%; 85+ years, 15.5%. Expected primary payer: Medicare, 25.4%; Medicaid, 23.8%; private insurance, 36.7%; uninsured, 22.7%. Community-level income: low, 25.5%; not low, 29.9%. Location of patient residence: large central metropolitan, 26.7%; large fringe metropolitan, 29.7%; medium and small metropolitan, 29.3%; micropolitan and noncore, 29.4%.

■ OR procedures were more common during inpatient stays among males than during stays among females.
  In 2014, 31.6 percent of inpatient stays among males and 26.4 percent of stays among females involved OR procedures.
■ In 2014, nearly one-third of inpatient stays for patients aged 18–84 years involved OR procedures.
  OR procedures were involved in 29.5 percent of stays for patients aged 18–44 years, 32.7 percent of stays for patients aged 45–64 years, and 30.0 percent of stays for patients aged 65–84 years.
  OR procedures were less common among the youngest and oldest age groups. Only 26.8 percent of inpatient stays for patients younger than 1 year and 20.2 percent of stays for patients aged 1–17 years involved OR procedures. Among inpatients aged 85 years and older, only 15.5 percent of stays involved OR procedures.
■ OR procedures were more common among inpatient stays covered by private insurance than among stays covered by other payers.
  More than one-third (36.7 percent) of inpatient stays covered by private insurance involved OR procedures, compared with only 25.4 percent of stays for Medicare patients, 23.8 percent of stays for Medicaid patients, and 22.7 percent of stays for uninsured patients.
■ OR procedures were less common among inpatient stays for patients in the lowest income quartile and for patients living in large central metropolitan areas.
  OR procedures were involved in 25.5 percent of hospital stays for patients in the lowest income quartile compared with 29.9 percent of stays for patients in the upper three income quartiles.
  Approximately 27 percent of inpatient stays for patients living in large central metropolitan areas involved OR procedures, compared with 29 to 30 percent of stays for patients living in less populated areas.

### Most frequent and costly types of operating room procedures, 2014

Table 3 presents the number and rate of inpatient stays for the 20 most common all-listed operating room procedures in 2014. Only one occurrence of a procedure type is counted per hospitalization because multiple codes may be used for related procedures performed during a single operation. For example, multiple codes for spinal fusion may appear on the record when multiple vertebrae were fused, but only one procedure is counted in the spinal fusion procedure category total. The unit of analysis for Table 3 is the number of procedures (unlike Table 1, which shows the number of inpatient stays with one or more procedures).

Table 3 Most frequent all-listed operating room (OR) procedures, 2014

Rank | All-listed OR procedure type | Number of OR procedures | Percent of all OR procedures | Rate per 100,000 population
All-listed OR procedures | | 14,198,900 | 100.0 | 4,453.1
1 | Cesarean section | 1,242,800 | 8.8 | 389.8
2 | Circumcision | 1,075,100 | 7.6 | 337.2
3 | Arthroplasty of knee | 752,900 | 5.3 | 236.1
4 | Hip replacement, total and partial | 522,800 | 3.7 | 164.0
5 | Percutaneous coronary angioplasty (PTCA) | 465,400 | 3.3 | 146.0
6 | Spinal fusion | 463,200 | 3.3 | 145.3
7 | Laminectomy, excision of intervertebral disc | 438,200 | 3.1 | 137.4
8 | Cholecystectomy and common duct exploration | 372,600 | 2.6 | 116.9
9 | Colorectal resection | 302,400 | 2.5 | 94.8
10 | Treatment, fracture or dislocation of hip and femur | 289,800 | 2.0 | 90.9
11 | Ligation of fallopian tubes | 254,500 | 1.8 | 79.8
12 | Appendectomy | 238,800 | 1.7 | 74.9
13 | Hysterectomy, abdominal and vaginal | 237,500 | 1.7 | 74.5
14 | Coronary artery bypass graft (CABG) | 201,600 | 1.4 | 63.2
15 | Oophorectomy, unilateral and bilateral | 182,400 | 1.3 | 57.2
16 | Treatment, fracture or dislocation of lower extremity (other than hip or femur) | 181,900 | 1.3 | 57.0
17 | Debridement of wound, infection or burn | 160,400 | 1.1 | 50.3
18 | Amputation of lower extremity | 146,500 | 1.0 | 46.0
19 | Heart valve procedures | 143,600 | 1.0 | 45.0
20 | Incision and excision of central nervous system (CNS) | 120,800 | 0.9 | 37.9
Top 20 OR procedures | | 7,793,400 | 54.9 | 2,444.2

Notes: Number of procedures is rounded to the nearest hundred. Percentage is based on unrounded data values. Procedures are grouped using the Agency for Healthcare Research and Quality (AHRQ) Clinical Classifications Software (CCS). CCS categories identified as “Other” and procedure categories that are nonspecific or likely to be adjuncts to other procedures were not reported. Procedure totals include only one occurrence of a CCS category per hospitalization because multiple codes may be used for related procedures performed during a single operation. The overall number of procedures represents the sum of all CCS category totals. Although some procedures are specific to male or female populations (e.g., Cesarean section and circumcision), the population denominator used to calculate rate includes both sexes.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), HCUPnet (www.hcupnet.ahrq.gov/)

■ More than 14 million OR procedures were performed during inpatient hospital stays in 2014—a rate of 4,453.1 OR procedures per 100,000 population.
  Overall, the highest rates were for one of two childbirth- and infant-related procedures—Cesarean section (389.8 per 100,000 population) and male circumcision (337.2 per 100,000 population).
■ The 20 most common OR procedures accounted for more than half of all OR procedures.
  Six musculoskeletal procedures—knee arthroplasty, hip replacement, spinal fusion, treatment of hip and femur fracture or dislocation, treatment of fracture or dislocation of other lower extremity, and amputation of lower extremity—constituted 16.6 percent of all OR procedures.
  Four obstetric/gynecologic procedures—Cesarean section, ligation of fallopian tubes, hysterectomy, and oophorectomy—together made up 13.5 percent of all OR procedures, whereas male circumcision alone constituted 7.6 percent of all OR procedures.
  Three digestive procedures—cholecystectomy, colorectal resection, and appendectomy—together accounted for 6.4 percent of all OR procedures. Three cardiovascular procedures—percutaneous coronary angioplasty, coronary artery bypass graft, and heart valve procedures—accounted for 5.7 percent.

Table 4 presents the five most common operating room procedures by age group in 2014.

Table 4 Top five most frequent all-listed operating room (OR) procedures by age group, 2014

Rank | OR Procedure | Number of OR procedures | Percent of OR procedures in this age group
Age <1 year | | 1,186,700 | 100.0
1 | Circumcision | 1,071,200 | 90.3
2 | Inguinal and femoral hernia repair | 4,600 | 0.4
3 | Insertion, replacement, or removal of extracranial ventricular shunt | 3,400 | 0.3
4 | Colorectal resection | 3,000 | 0.3
5 | Small bowel resection | 2,800 | 0.2
Ages 1–17 years | | 384,100 | 100.0
1 | Appendectomy | 54,400 | 14.2
2 | Cesarean section | 13,000 | 3.4
3 | Spinal fusion | 12,500 | 3.2
4 | Treatment, fracture or dislocation of hip and femur | 12,400 | 3.2
5 | Tonsillectomy and/or adenoidectomy | 10,500 | 2.7
Ages 18–44 years | | 3,585,700 | 100.0
1 | Cesarean section | 1,225,500 | 34.2
2 | Ligation of fallopian tubes | 253,600 | 7.1
3 | Cholecystectomy and common duct exploration | 122,800 | 3.4
4 | Hysterectomy, abdominal and vaginal | 89,700 | 2.5
5 | Appendectomy | 88,800 | 2.5
Ages 45–64 years | | 4,382,700 | 100.0
1 | Arthroplasty of knee | 314,800 | 7.2
2 | Spinal fusion | 216,500 | 4.9
3 | Percutaneous coronary angioplasty (PTCA) | 207,500 | 4.7
4 | Laminectomy, excision of intervertebral disc | 199,200 | 4.5
5 | Hip replacement, total and partial | 188,000 | 4.3
Ages 65–84 years | | 4,094,500 | 100.0
1 | Arthroplasty of knee | 402,500 | 9.8
2 | Hip replacement, total and partial | 253,700 | 6.2
3 | Percutaneous coronary angioplasty (PTCA) | 205,200 | 5.0
4 | Spinal fusion | 155,900 | 3.8
5 | Laminectomy, excision of intervertebral disc | 149,000 | 3.6
Age 85+ years | | 561,700 | 100.0
1 | Treatment, fracture or dislocation of hip and femur | 85,800 | 15.3
2 | Hip replacement, total and partial | 61,700 | 11.0
3 | Percutaneous coronary angioplasty (PTCA) | 26,700 | 4.8
4 | Colorectal resection | 18,700 | 3.3
5 | Arthroplasty of knee | 18,200 | 3.2

Notes: The number of procedures is rounded to the nearest hundred. Percentage is based on unrounded data values. Procedures are grouped using the Agency for Healthcare Research and Quality (AHRQ) Clinical Classifications Software (CCS). CCS categories identified as “Other” and procedure categories that are nonspecific or likely to be adjuncts to other procedures were not reported. Procedure totals include only one occurrence of a CCS category per hospitalization because multiple codes may be used for related procedures performed during a single operation. The overall number of procedures for each age group represents the sum of all CCS category totals for that age group.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), HCUPnet (www.hcupnet.ahrq.gov/)

■ Childbirth- and delivery-related procedures and appendectomies were the most common OR procedures among younger patients in 2014.
  Of all OR procedures performed on patients younger than 1 year, 90.3 percent were male circumcisions. Other procedures among infants demonstrate how infrequently this age group undergoes surgery.
  Appendectomy was the most common OR procedure among patients aged 1–17 years, accounting for 14.2 percent of OR procedures for this age group. Orthopedic procedures and tonsillectomy were also in the top five procedures for children and adolescents. Cesarean section accounted for about 13,000 procedures among adolescents (teen pregnancy).
■ Among the top five procedures for 18–44-year-olds, three are performed only on females.
  Cesarean section was the most common procedure among 18–44-year-olds, accounting for more than one-third of OR procedures in this age group. Two gynecologic procedures were also among the top five OR procedures for this age group. Among all patients aged 18–44 years, fallopian tube ligation accounted for 7.1 percent and hysterectomy accounted for 2.5 percent of all OR procedures. Cholecystectomy and appendectomy are the only top five procedures in this age group that are performed for both males and females.
■ Musculoskeletal and cardiovascular procedures were most common among older patients in 2014.
  Knee arthroplasty was the most common OR procedure among older patients, accounting for 7.2 percent of OR procedures among patients aged 45–64 years, 9.8 percent of procedures among patients aged 65–84 years, and 3.2 percent of procedures among patients aged 85 years and older.
  Hip replacement was also one of the top five OR procedures among these three older age groups, accounting for 4–11 percent of OR procedures for patients aged 45 years and older.
  Percutaneous coronary angioplasty was the third most common OR procedure among the three oldest age groups, accounting for approximately 5 percent of OR procedures for patients aged 45 years and older.

Table 5 presents the 20 OR procedures with the highest aggregate costs for the entire hospital stay during which the procedure was the first-listed procedure on the record. Procedures are ranked by aggregate hospital costs. Rankings are based on first-listed procedure to avoid double-counting costs of inpatient stays involving more than one type of OR procedure. (The unit of analysis is the inpatient stay. Numbers of stays vary from all-listed analyses presented earlier because of the focus on first-listed procedures.) Aggregate costs, mean cost per stay, and number of stays are provided.

Table 5 Most costly inpatient stays by first-listed operating room (OR) procedure, 2014

Rank | First-listed OR procedure type | Aggregate costs for stays with a first-listed OR procedure, $ billions | Percent of aggregate costs for all stays with a first-listed OR procedure | Mean cost per stay, $ thousands | Number of inpatient stays
First-listed OR procedures | | 163.8 | 100.0 | 17.8 | 9,204,100
1 | Spinal fusion | 12.0 | 7.3 | 28.9 | 413,200
2 | Arthroplasty of knee | 11.8 | 7.2 | 16.3 | 723,100
3 | Hip replacement, total and partial | 8.3 | 5.1 | 17.1 | 487,600
4 | Percutaneous coronary angioplasty (PTCA) | 8.1 | 4.9 | 21.5 | 377,500
5 | Cesarean section | 7.0 | 4.3 | 6.1 | 1,142,700
6 | Coronary artery bypass graft (CABG) | 6.7 | 4.1 | 41.9 | 160,200
7 | Heart valve procedures | 5.8 | 3.5 | 52.0 | 111,100
8 | Colorectal resection | 5.6 | 3.4 | 23.7 | 234,700
9 | Treatment, fracture or dislocation of hip and femur | 4.3 | 2.6 | 17.3 | 246,100
10 | Cholecystectomy and common duct exploration | 4.0 | 2.4 | 13.3 | 300,200
11 | Incision and excision of central nervous system (CNS) | 3.5 | 2.1 | 34.6 | 100,400
12 | Insertion, revision, replacement, removal of cardiac pacemaker or cardioverter/defibrillator | 2.8 | 1.7 | 35.0 | 79,000
13 | Amputation of lower extremity | 2.5 | 1.5 | 20.8 | 119,200
14 | Treatment, fracture or dislocation of lower extremity (other than hip or femur) | 2.4 | 1.4 | 16.5 | 142,400
15 | Laminectomy, excision of intervertebral disc | 2.3 | 1.4 | 14.9 | 151,700
16 | Hysterectomy, abdominal and vaginal | 1.9 | 1.2 | 10.3 | 185,000
17 | Appendectomy | 1.9 | 1.2 | 10.7 | 177,600
18 | Circumcision | 1.8 | 1.1 | 2.0 | 887,600
19 | Debridement of wound, infection or burn | 1.7 | 1.1 | 17.5 | 98,400
20 | Small bowel resection | 1.7 | 1.1 | 34.3 | 50,300
20 most costly first-listed OR procedures | | 96.0 | 58.6 | — | 6,188,000

Notes: Number of stays is rounded to the nearest hundred. Percentage is based on unrounded data values. Procedures are grouped using the Agency for Healthcare Research and Quality (AHRQ) Clinical Classifications Software (CCS). CCS categories identified as “Other” are not reported.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), HCUPnet (www.hcupnet.ahrq.gov/)

■ Inpatient stays for the 20 most costly OR procedures accounted for nearly 60 percent of aggregate costs for all inpatient stays with a first-listed OR procedure.
  In 2014, there were 9,204,100 inpatient stays with a first-listed OR procedure. The aggregate costs for these stays totaled $163.8 billion. Stays for the 20 most costly OR procedures accounted for 58.6 percent of this total, or $96.0 billion.
■ Inpatient stays for six musculoskeletal procedures accounted for one-quarter of aggregate costs for all stays with a first-listed OR procedure.
  Six musculoskeletal procedures combined accounted for $41.2 billion in hospital costs, or 25 percent of aggregate costs for stays with a first-listed OR procedure: spinal fusion (7.3 percent of aggregate costs), knee arthroplasty (7.2 percent), hip replacement (5.1 percent), treatment of hip and femur fracture or dislocation (2.6 percent), amputation of lower extremity (1.5 percent), and treatment of fracture or dislocation of other lower extremity (1.4 percent).
  Costs associated with four cardiovascular procedures— percutaneous coronary angioplasty, coronary artery bypass graft, heart valve procedures, and procedures related to pacemakers/defibrillators—constituted about 14 percent of aggregate costs for inpatient stays with a first-listed OR procedure, or $23.4 billion in aggregate hospital costs.
  Four digestive procedures—colorectal resection, cholecystectomy, appendectomy, and small bowel resection—together accounted for roughly 8 percent of aggregate costs associated with a first-listed OR procedure, or $13.2 billion in aggregate costs.
■ Although they were not among the 20 most common all-listed OR procedures, procedures related to pacemakers/defibrillators and small bowel resection were among the 20 most expensive OR procedures in 2014.
  Procedures related to pacemakers/defibrillators and small bowel resection were less common than other costly procedures. Still, these procedures were associated with high aggregate costs because of their relatively high mean costs per stay—$35,000 for procedures related to pacemakers/defibrillators and $34,300 for small bowel resection. Among the 20 most expensive OR procedures overall, the only procedures with higher or equivalent average hospital costs were heart valve procedures (mean cost, $52,000), coronary artery bypass graft ($41,900), and incision and excision of the central nervous system ($34,600).

## Data Source

The estimates in this Statistical Brief are based upon data from the Healthcare Cost and Utilization Project (HCUP) 2014 National Inpatient Sample (NIS). Some of the statistics were generated from HCUPnet, a free, online query system that provides users with immediate access to the largest set of publicly available, all-payer national, regional, and State-level hospital care databases from HCUP.^8^ Supplemental sources included population denominator data for use with HCUP databases, derived from information available from the U.S. Census Bureau.^9^

## Definitions

### Procedures, ICD-9-CM, Clinical Classifications Software (CCS), diagnosis-related groups (DRGs)

All-listed procedures include all procedures performed during the hospital stay, whether for definitive treatment or for diagnostic or exploratory purposes. The first-listed procedure is the procedure that is listed first on the discharge record. Inpatient data define this as the principal procedure—the procedure that is performed for definitive treatment rather than for diagnostic or exploratory purposes (i.e., the procedure that was necessary to take care of a complication).

ICD-9-CM is the International Classification of Diseases, Ninth Revision, Clinical Modification, which assigns numeric codes to procedures. There are approximately 4,000 ICD-9-CM procedure codes.

CCS categorizes ICD-9-CM procedure codes into a manageable number of clinically meaningful categories.^10^ This clinical grouper makes it easier to quickly understand patterns of procedure use. CCS categories identified as Other typically are not reported; these categories include miscellaneous, otherwise unclassifiable procedures that may be difficult to interpret as a group. In this report, procedure categories that are nonspecific or likely to be adjuncts to other procedures (e.g., excision, lysis peritoneal adhesions; partial bone excision; intraoperative cholangiogram) are not included in the listings of specific procedure rankings. Only one occurrence of a CCS category is counted per hospitalization because multiple codes may be used for related procedures performed during a single operation. For example, multiple codes for spinal fusion may appear on the record when multiple vertebrae were fused, but only one code is counted in the spinal fusion CCS category total.

Major operating room (OR) procedures were defined using procedure classes, which categorize each ICD-9-CM procedure code as either major therapeutic, major diagnostic, minor therapeutic, or minor diagnostic.^11^ If at least one major diagnostic or major therapeutic procedure was on a hospital record, the hospital stay was classified as involving a major OR procedure. Major OR procedures are considered to be valid OR procedures based on diagnosis-related groups (DRGs). This classification scheme relies upon physician panels that classify ICD-9-CM procedure codes according to whether the procedure would be performed in a hospital operating room in most hospitals.

### Types of hospitals included in the HCUP National (Nationwide) Inpatient Sample

The National (Nationwide) Inpatient Sample (NIS) is based on data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). The NIS includes obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded are long-term care facilities such as rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. Beginning in 2012, long-term acute care hospitals are also excluded. However, if a patient received long-term care, rehabilitation, or treatment for a psychiatric or chemical dependency condition in a community hospital, the discharge record for that stay will be included in the NIS.

### Unit of analysis

The unit of analysis is the hospital discharge (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the hospital multiple times in 1 year will be counted each time as a separate discharge from the hospital.

### Costs and charges

Total hospital charges were converted to costs using HCUP Cost-to-Charge Ratios based on hospital accounting reports from the Centers for Medicare & Medicaid Services (CMS).^12^ Costs reflect the actual expenses incurred in the production of hospital services, such as wages, supplies, and utility costs; charges represent the amount a hospital billed for the case. For each hospital, a hospital-wide cost-to-charge ratio is used. Hospital charges reflect the amount the hospital billed for the entire hospital stay and do not include professional (physician) fees. For the purposes of this Statistical Brief, costs are reported to the nearest hundred.

As reported in this Statistical Brief, mean cost per day represents the weighted average of cost per day at the discharge level, which is calculated as total cost of stay divided by length of stay. When length of stay was 0 days (same-day discharge), cost per day was set equal to total cost of stay.

### How HCUP estimates of costs differ from National Health Expenditure Accounts

There are a number of differences between the costs cited in this Statistical Brief and spending as measured in the National Health Expenditure Accounts (NHEA), which are produced annually by CMS.^13^ The largest source of difference comes from the HCUP coverage of inpatient treatment only in contrast to the NHEA inclusion of outpatient costs associated with emergency departments and other hospital-based outpatient clinics and departments as well. The outpatient portion of hospitals' activities has been growing steadily and may exceed half of all hospital revenue in recent years. On the basis of the American Hospital Association Annual Survey, 2012 outpatient gross revenues (or charges) were about 44 percent of total hospital gross revenues.^14^

Smaller sources of differences come from the inclusion in the NHEA of hospitals that are excluded from HCUP. These include Federal hospitals (Department of Defense, Veterans Administration, Indian Health Services, and Department of Justice [prison] hospitals) as well as psychiatric, substance abuse, and long-term care hospitals. A third source of difference lies in the HCUP reliance on billed charges from hospitals to payers, adjusted to provide estimates of costs using hospital-wide cost-to-charge ratios, in contrast to the NHEA measurement of spending or revenue. HCUP costs estimate the amount of money required to produce hospital services, including expenses for wages, salaries, and benefits paid to staff as well as utilities, maintenance, and other similar expenses required to run a hospital. NHEA spending or revenue measures the amount of income received by the hospital for treatment and other services provided, including payments by insurers, patients, or government programs. The difference between revenues and costs include profit for for-profit hospitals or surpluses for nonprofit hospitals.

### Location of patients' residence

Place of residence is based on the urban-rural classification scheme for U.S. counties developed by the National Center for Health Statistics (NCHS):

- Large Central Metropolitan: includes metropolitan areas with 1 million or more residents
- Large Fringe Metropolitan: includes counties of metropolitan areas with 1 million or more residents
- Medium and Small Metropolitan: includes areas with 50,000 to 999,999 residents
- Micropolitan and Noncore: includes nonmetropolitan counties (i.e., counties with no town greater than 50,000 residents).

### Community-level income

Community-level income is based on the median household income of the patient's ZIP Code of residence. Quartiles are defined so that the total U.S. population is evenly distributed. Cut-offs for the quartiles are determined annually using ZIP Code demographic data obtained from Claritas, a vendor that adds value to data from the U.S. Census Bureau.^15^ The value ranges for the income quartiles vary by year. Patients in the first quartile are designated as having low income, and patients in the upper three quartiles are designated as having not low income. The income quartile is missing for patients who are homeless or foreign.

### Payer

Payer is the expected payer for the hospital stay. To make coding uniform across all HCUP data sources, payer combines detailed categories into general groups:

- Medicare: includes patients covered by fee-for-service and managed care Medicare
- Medicaid: includes patients covered by fee-for-service and managed care Medicaid
- Private Insurance: includes Blue Cross, commercial carriers, and private health maintenance organizations (HMOs) and preferred provider organizations (PPOs)
- Uninsured: includes an insurance status of self-pay and no charge
- Other: includes Workers' Compensation, TRICARE/CHAMPUS, CHAMPVA, Title V, and other government programs

Hospital stays billed to the State Children's Health Insurance Program (SCHIP) may be classified as Medicaid, Private Insurance, or Other, depending on the structure of the State program. Because most State data do not identify patients in SCHIP specifically, it is not possible to present this information separately.

For this Statistical Brief, when more than one payer is listed for a hospital discharge, the first-listed payer is used.

### Admission source or point of origin

Admission source (now known as the patient's point of origin) indicates where the patient was located prior to admission to the hospital. Emergency admission indicates that the patient was admitted to the hospital through the emergency department.

### Discharge status

Discharge status reflects the disposition of the patient at discharge from the hospital and includes the following five categories: discharged to self-care (routine discharge to home) or home health care; transferred to a short-term hospital; transferred to other type of facility (including skilled nursing facility, intermediate care, and another type of facility such as a nursing home); died in hospital, and other (including alive/destination unknown, against medical advice (AMA), and missing).

## For More Information

For other information on procedures and treatments, refer to the HCUP Statistical Briefs located at www.hcup-us.ahrq.gov/reports/statbriefs/sb_procedures.jsp.

For additional HCUP statistics, visit:

- HCUP Fast Stats at www.hcup-us.ahrq.gov/faststats/landing.jsp for easy access to the latest HCUP-based statistics for health information topics
- HCUPnet, HCUP's interactive query system, at www.hcupnet.ahrq.gov/

For more information about HCUP, visit www.hcup-us.ahrq.gov/.

For a detailed description of HCUP and more information on the design of the National (Nationwide) Inpatient Sample (NIS), please refer to the following database documentation:

Agency for Healthcare Research and Quality. Overview of the National (Nationwide) Inpatient Sample (NIS). Healthcare Cost and Utilization Project (HCUP). Rockville, MD: Agency for Healthcare Research and Quality. Updated December 2016. www.hcup-us.ahrq.gov/nisoverview.jsp. Accessed January 31, 2017 .

1 Pfuntner A, Wier LM, Stocks C. Most Frequent Procedures Performed in U.S. Hospitals, 2011. HCUP Statistical Brief #165. October 2013. Agency for Healthcare Research and Quality, Rockville, MD. www.hcup-us.ahrq.gov/reports/statbriefs/sb165.pdf. Accessed October 9, 2017 .

2 Elixhauser A, Andrews RM. Profile of inpatient operating room procedures in US hospitals in 2007. Archives of Surgery. 2010;145(12):1201–1208 21173295 .

3 Weiss AJ, Elixhauser A, Andrews RM. Characteristics of Operating Room Procedures in U.S. Hospitals, 2011. HCUP Statistical Brief #170. February 2014. Agency for Healthcare Research and Quality, Rockville, MD. www.hcup-us.ahrq.gov/reports/statbriefs/sb170-Operating-Room-Procedures-United-States-2011.pdf. Accessed October 10, 2017 .

4 Fingar KR, Stocks CA, Weiss AJ, Steiner CA. Most Frequent Operating Room Procedures Performed in U.S. Hospitals, 2003–2012. HCUP Statistical Brief #186. December 2014. Agency for Healthcare Research and Quality, Rockville, MD. www.hcup-us.ahrq.gov/reports/statbriefs/sb186-Operating-Room-Procedures-United-States-2012.pdf. Accessed October 10, 2017 .

5 Weiss AJ, Elixhauser A. Trends in Operating Room Procedures in U.S. Hospitals, 2001–2011. HCUP Statistical Brief #171. March 2014. Agency for Healthcare Research and Quality, Rockville, MD. www.hcup-us.ahrq.gov/reports/statbriefs/sb171-Operating-Room-Procedure-Trends.pdf. Accessed October 10, 2017 .

6 Elixhauser, Andrews, 2010. Op. cit.

7 Weiss, Elixhauser, Andrews, 2014. Op cit.

8 Agency for Healthcare Research and Quality. HCUPnet Web site. www.hcupnet.ahrq.gov/. Accessed January 31, 2017 .

9 Barrett M, McCarty J, Coffey R, Levit K. Population Denominator Data for Use with the HCUP Databases (Updated with 2015 Population Data). HCUP Methods Series Report #2016-04. September 29, 2016. U.S. Agency for Healthcare Research and Quality. www.hcup-us.ahrq.gov/reports/methods/2016-04.pdf. Accessed January 31, 2017 .

10 Agency for Healthcare Research and Quality. HCUP Clinical Classifications Software (CCS) for ICD-9-CM. Healthcare Cost and Utilization Project (HCUP). Rockville, MD: Agency for Healthcare Research and Quality. Updated October 2016. www.hcup-us.ahrq.gov/toolssoftware/ccs/ccs.jsp. Accessed January 31, 2017 .

11 HCUP Procedure Classes. Healthcare Cost and Utilization Project (HCUP). U.S. Agency for Healthcare Research and Quality. Rockville, MD. Updated September 2015. www.hcup-us.ahrq.gov/toolssoftware/procedure/procedure.jsp. Accessed September 26, 2017 .

12 Agency for Healthcare Research and Quality. HCUP Cost-to-Charge Ratio (CCR) Files. Healthcare Cost and Utilization Project (HCUP). 2001–2014. Rockville, MD: Agency for Healthcare Research and Quality. Updated November 2016. www.hcup-us.ahrq.gov/db/state/costtocharge.jsp. Accessed January 31, 2017 .

13 For additional information about the NHEA, see Centers for Medicare & Medicaid Services (CMS). National Health Expenditure Data. CMS Web site May 2014. www.cms.gov/Research-Statistics-Data-and-Systems/Statistics-Trends-and-Reports/NationalHealthExpendData/index.html?redirect=/NationalHealthExpendData/. Accessed January 31, 2017 .

14 American Hospital Association. TrendWatch Chartbook, 2014. Table 4.2. Distribution of Inpatient vs. Outpatient Revenues, 1992–2012. www.aha.org/research/reports/tw/chartbook/2014/table4-2.pdf. Accessed January 31, 2017 .

15 Claritas. Claritas Demographic Profile. www.claritas.com. Accessed June 23, 2017 .