# Statistical Brief #230 A Comparison of All-Cause 7-Day and 30-Day Readmissions, 2014

## Introduction

There have been increasing efforts among health care policy makers, payers, and providers to measure and reduce hospital readmissions. Various time frames are used for identifying readmissions: 48 hours,^1^ 7 days,^2^ 15 days,^3,4^ and 30 days after discharge of an initial stay.^5,6,7^ The likelihood of readmission and associated contributing factors vary by the length of postdischarge time.^8,9^ Thus, it is important to understand how readmission rates and the conditions associated with the highest readmission rates vary by different postdischarge time frames.

This Healthcare Cost and Utilization Project (HCUP) Statistical Brief presents data on rates of all-cause 7-day readmissions compared with all-cause 30-day readmissions in 2014. For diagnoses with the highest 7-day readmission rates, the percentage of 30-day readmissions that occurred within 7 days is also presented. Finally, 7-day and 30-day readmission rates are reported by expected payer.

Readmissions include stays for all causes, including planned and unplanned stays. Readmission rates reported by diagnoses reflect the principal diagnosis at the index (i.e., initial) inpatient stay, grouped into broad clinical categories. Condition-specific readmission rates for index stays related to nonspecific clinical categories (e.g., other respiratory diseases), cancer, and pregnancy are not reported. However, these stays contribute to the total readmission rate. All differences between estimates noted in the text are greater than 10 percent.

## Findings

Highlights

■ In 2014, 14 percent of inpatient stays were readmitted within 30 days. More than one-third of these readmissions occurred within 7 days, reflecting a 7-day readmission rate of 5 percent.
■ Diagnoses at index stays with the highest 7-day and 30-day readmission rates were similar. Schizophrenia, alcohol-related disorders, and congestive heart failure were among the leading diagnoses with both the highest 7-day and 30-day readmission rates.
■ However, there were several differences in diagnoses associated with the two types of rates. Index stays with intestinal obstruction without hernia and acute myocardial infarction ranked in the top 20 diagnoses with the highest 7-day, but not 30-day, readmission rates.
■ For both 7-day and 30-day readmissions, the rate of readmission was highest among patients with Medicare, followed by patients with Medicaid, no insurance, and private insurance.
■ Among Medicaid patients who were discharged with congestive heart failure or schizophrenia at the index stay, nearly 1 in 10 stays resulted in readmission within 7 days.
■ Among patients readmitted within 30 days of an index stay for septicemia or schizophrenia, uninsured patients were more likely than patients with insurance to return within 7 days.

### Diagnoses with the highest readmission rates, 2014

Table 1 presents all-cause 7-day readmission rates following index stays overall and for the top 20 principal diagnoses at the index stay. The top 20 diagnoses with the highest 30-day readmission rates also are shown for comparison. The diagnoses are sorted by the 7-day readmission rate.

Table 1 Top 20 principal diagnoses with the highest 7-day and 30-day readmission rates, 2014

Principal diagnosis at the index stay | Index stays, N | 7-day readmissions | | 30-day readmissions
Principal diagnosis at the index stay | Index stays, N | Rank | Rate^a^ | Rank | Rate^a^
Total inpatient stays | 27,698,101 | — | 5.0 | — | 13.9
Schizophrenia and other psychotic disorders | 374,097 | 1 | 9.0 | 2 | 22.9
Alcohol-related disorders | 340,076 | 2 | 7.5 | 4 | 21.5
Congestive heart failure; nonhypertensive | 795,709 | 3 | 7.4 | 1 | 23.2
Heart valve disorders | 117,788 | 4 | 7.3 | 14 | 18.4
Hypertension with complications, secondary hypertension | 223,396 | 5 | 7.2 | 6 | 20.9
Respiratory failure; insufficiency; arrest (adult) | 311,005 | 6 | 7.2 | 3 | 21.6
Aspiration pneumonitis; food/vomitus | 128,019 | 7 | 7.1 | 11 | 19.5
Acute and unspecified renal failure | 436,833 | 8 | 7.0 | 8 | 20.1
Diabetes mellitus with complications | 487,947 | 9 | 6.9 | 7 | 20.5
Complication of device; implant or graft | 572,761 | 10 | 6.7 | 10 | 19.7
Septicemia | 1,202,893 | 11 | 6.7 | 13 | 18.5
Deficiency and other anemia | 171,160 | 12 | 6.6 | 5 | 21.2
Intestinal obstruction without hernia | 313,596 | 13 | 6.6 | 25 | 15.2
Fluid and electrolyte disorders | 338,954 | 14 | 6.5 | 12 | 18.8
Abdominal pain | 113,331 | 15 | 6.5 | 18 | 17.2
Complications of surgical procedures or medical care | 417,261 | 16 | 6.5 | 15 | 17.9
Gastrointestinal hemorrhage | 331,739 | 17 | 6.5 | 20 | 16.9
Pancreatic disorders (not diabetes) | 276,534 | 18 | 6.2 | 17 | 17.2
Chronic obstructive pulmonary disease and bronchiectasis | 521,955 | 19 | 6.1 | 9 | 20.1
Acute myocardial infarction | 480,338 | 20 | 6.1 | 29 | 14.2
Intestinal infection | 195,644 | 24 | 5.7 | 16 | 17.5
Peripheral and visceral atherosclerosis | 127,624 | 22 | 5.8 | 19 | 16.9

Notes: Diagnoses are grouped using the Clinical Classification Software (CCS). Only CCS with at least 100,000 index stays are shown; “other” CCS that group a nonspecific set of diagnoses, as well as diagnoses related to cancer and pregnancy, are excluded. Highlighting indicates diagnoses that were not ranked in the top 20 for either 7-day or 30-day readmissions.

a Rate per 100 index inpatient stays

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Readmissions Database (NRD), 2014

■ In 2014, the 30-day readmission rate was over 2 times higher than the 7-day readmission rate.
  In 2014, the 30-day readmission rate was 13.9 per 100 index stays—more than twice as high as the 7-day readmission rate, which was 5.0 per 100 index stays.
■ The leading diagnoses with the highest 7-day readmission rates were largely the same as the leading diagnoses with the highest 30-day readmission rates.
  Although the rank differed, the leading diagnoses with the highest 7-day readmission rates were largely the same as those with the highest 30-day readmission rates. Index stays with a principal diagnosis of schizophrenia and other psychotic disorders had the highest rate of readmission within 7 days (9.0 per 100 index stays) and the second highest rate of readmission within 30 days (22.9 per 100 index stays). Alcohol-related disorders and congestive heart failure (CHF) were also among the diagnoses with the highest 7-day and 30-day readmission rates.
  There were a few differences between diagnoses with the highest 7-day versus 30-day readmission rates. Whereas index stays with intestinal obstruction without hernia (7-day readmission rate of 6.6 per 100 index stays) and acute myocardial infarction (7-day readmission rate of 6.1 per 100 index stays) ranked in the top 20 diagnoses with the highest 7-day readmission rates, these diagnoses did not rank in the top 20 diagnoses with the highest 30-day readmission rates. Intestinal infection and peripheral visceral atherosclerosis were among the top 20 diagnoses with the highest 30-day readmission rates but did not rank in the top 20 for 7-day readmissions.

### Timing of readmissions, 2014

Figure 1 displays the percentage of 30-day readmissions that occurred within 7 days following discharge, overall and for the top 20 principal diagnoses with the highest 7-day readmission rates. The 7-day readmission rate is listed on the y-axis for reference.

Figure 1 The percentage of 30-day readmissions that occurred within 7 days, overall and for the top 20 diagnoses with the highest 7-day readmission rates, 2014

Notes: Readmission rates are per 100 index inpatient stays. The principal diagnosis is grouped using the Clinical Classification Software (CCS). Only CCS with at least 100,000 index stays are shown; “other” CCS that group a nonspecific set of diagnoses, as well as diagnoses related to cancer and pregnancy, are excluded.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Readmissions Database (NRD), 2014

Bar chart shows percentage of 30-day readmissions that occurred within 7 days by principal diagnosis with highest 7-day readmission rate in 2014. Total inpatient stays (7-day readmission rate=5.0): 36.1%. Intestinal obstruction without hernia (7-day readmission rate=6.6): 43.6%. Acute myocardial infarction (7-day readmission rate=6.1): 43.0%. Heart valve disorders (7-day readmission rate=7.3): 39.6%. Schizophrenia and other psychotic disorders (7-day readmission rate=9.0): 39.4%. Gastrointestinal hemorrhage (7-day readmission rate=6.5): 38.5%. Abdominal pain (7-day readmission rate=6.5): 38.0%. Complications of surgical procedures/medical care (7-day readmission rate=6.5): 36.6%. Aspiration pneumonitis; food/vomitus (7-day readmission rate=7.1): 36.4%. Pancreatic disorders (not diabetes) (7-day readmission rate=6.2): 36.1%. Septicemia (7-day readmission rate=6.7): 36.0%. Alcohol-related disorders (7-day readmission rate=7.5): 34.9%. Fluid and electrolyte disorders (7-day readmission rate=6.5): 34.8%. Acute and unspecified renal failure (7-day readmission rate=7.0): 34.8%. Hypertension with complications (7-day readmission rate=7.2): 34.5%. Complication of device; implant or graft (7-day readmission rate=6.7): 33.9%. Diabetes mellitus with complications (7-day readmission rate=6.9): 33.7%. Respiratory failure; insufficiency; arrest (adult) (7-day readmission rate=7.2): 33.3. Congestive heart failure; nonhypertensive (7-day readmission rate=7.4): 31.7%. Deficiency and other anemia (7-day readmission rate=6.6): 31.3%. Chronic obstructive pulmonary disease (7-day readmission rate=6.1): 30.5%.

■ Over one-third of 30-day readmissions occurred within the first 7 days following discharge. This varied by the principal diagnosis at the index stay.
  Overall, 36.1 percent of all 30-day readmissions occurred within 7 days. This ranged from 30.5 percent to 43.6 percent among index diagnoses with the highest 7-day readmission rates. For instance, a larger proportion of patients with intestinal obstruction without hernia at the index stay were readmitted within 7 days than were patients with other diagnoses: 43.6 percent of all 30-day readmissions following index stays with this diagnosis occurred within 7 days. Similarly, among patients with an index stay for acute myocardial infarction, 43.0 percent of all 30-day readmissions occurred within 1 week of discharge.
  In comparison, only 30.5 percent of patients readmitted within 30 days for chronic obstructive pulmonary disease returned to the hospital within 7 days following discharge.

### Readmission patterns by expected payer, 2014

Figure 2 displays all-cause 7-day and 30-day readmission rates following index stays by expected payer.

Figure 2 All-cause 7-day and 30-day readmission rates, by expected payer, 2014

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Readmissions Database (NRD), 2014

Bar chart that shows readmission rate per 100 index inpatient stays by expected payer in 2014. Medicare: total readmission rate within 30 days: 17.3; readmission rate within 7 days: 6.1. Medicaid: total readmission rate within 30 days: 13.7; readmission rate within 7 days: 5.0. Private: total readmission rate within 30 days: 8.9; readmission rate within 7 days: 3.3. Uninsured: total readmission rate within 30 days: 11.5; readmission rate within 7 days: 4.5.

■ Patterns of 7-day readmissions across expected payers were consistent with the pattern of 30-day readmissions.
  For both 7-day and 30-day readmissions, the rate of readmission was highest among patients covered by Medicare (6.1 and 17.3 per 100 index stays, respectively), followed by patients with Medicaid (5.0 and 13.7), no insurance (4.5 and 11.5), and private insurance (3.3 and 8.9).
  Across each expected payer, slightly more than one-third of 30-day readmissions occurred within 7 days. The percentage of 7-day readmissions, out of total 30-day readmissions, was similar across payers, ranging from 35.2 among patients with Medicare (6.1 out of 17.3) to 38.7 among those without insurance (4.5 out of 11.5).

Table 2 focuses on expected payer and presents the all-cause 7-day rate of readmission following index stays for the top five principal diagnoses at the index stay. The top five diagnoses with the highest 30-day readmission rates also are shown for comparison. The conditions are sorted by the 7-day readmission rate.

Table 2 Top five principal diagnoses with the highest 7-day and 30-day readmission rates, by expected payer, 2014

Principal diagnosis | Index stays, N | 7-day readmissions | | 30-day readmissions
Principal diagnosis | Index stays, N | Rank | Rate^a^ | Rank | Rate^a^
Medicare
Schizophrenia and other psychotic disorders | 150,743 | 1 | 9.3 | 3 | 23.9
Pleurisy; pneumothorax; pulmonary collapse | 50,119 | 2 | 8.9 | 1 | 24.5
Alcohol-related disorders | 67,838 | 3 | 8.3 | 2 | 24.4
Heart valve disorders | 85,682 | 4 | 7.9 | 14 | 19.9
Hypertension with complications, secondary hypertension | 141,206 | 5 | 7.7 | 8 | 22.6
Deficiency and other anemia | 103,430 | 13 | 7.1 | 4 | 23.3
Congestive heart failure; nonhypertensive | 613,829 | 9 | 7.4 | 5 | 23.3
Medicaid
Schizophrenia and other psychotic disorders | 151,794 | 1 | 9.9 | 6 | 24.9
Sickle cell anemia | 50,187 | 2 | 9.8 | 1 | 34.4
Alcohol-related disorders | 123,583 | 3 | 9.3 | 3 | 26.1
Congestive heart failure; nonhypertensive | 78,938 | 4 | 9.0 | 2 | 28.5
Hypertension with complications, secondary hypertension | 33,068 | 5 | 8.9 | 4 | 25.0
Complication of device; implant or graft | 71,974 | 6 | 8.5 | 5 | 25.0
Private
Acute and unspecified renal failure | 54,314 | 1 | 6.4 | 3 | 17.2
Regional enteritis and ulcerative colitis | 42,829 | 2 | 6.4 | 4 | 16.2
Schizophrenia and other psychotic disorders | 35,493 | 3 | 6.2 | 5 | 15.8
Congestive heart failure; nonhypertensive | 67,683 | 4 | 6.0 | 1 | 18.7
Deficiency and other anemia | 29,565 | 5 | 6.0 | 2 | 17.6
Uninsured
Schizophrenia and other psychotic disorders | 23,574 | 1 | 7.4 | 4 | 17.3
Abdominal pain | 9,104 | 2 | 6.8 | 8 | 16.2
Alcohol-related disorders | 56,753 | 3 | 6.5 | 1 | 18.2
Mood disorders | 82,318 | 4 | 6.5 | 11 | 15.3
Complications of surgical procedures or medical care | 11,261 | 5 | 6.3 | 7 | 16.8
Regional enteritis and ulcerative colitis | 6,630 | ^—b^ | ^—b^ | 2 | 18.1
Complication of device; implant or graft | 8,777 | 7 | 6.1 | 3 | 18.1
Congestive heart failure; nonhypertensive | 21,986 | 12 | 5.2 | 5 | 17.0

a Rate per 100 index inpatient stays

b Data are suppressed because cell contains fewer than 11 readmissions.

Note: Diagnoses are grouped using the Clinical Classification Software (CCS). Only CCS with at least 50,000 Medicare index stays, 20,000 Medicaid index stays, 25,000 privately insured index stays, and 5,000 uninsured index stays are shown. “Other” CCS that group a nonspecific set of diagnoses, as well as diagnoses related to cancer and pregnancy, are excluded. Highlighting indicates diagnoses that were not ranked in the top five for either 7-day or 30-day readmissions.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Readmissions Database (NRD), 2014

■ A principal diagnosis of schizophrenia and other psychotic disorders at the index stay was among the top five diagnoses with the highest 7-day readmission rates across all payers.
  Index stays with schizophrenia and other psychotic disorders had the highest rate of readmission within 7 days for patients with Medicare (9.3 per 100 index stays), Medicaid (9.9), and those who were uninsured (7.4). For patients with private insurance, index stays with schizophrenia had the third highest 7-day readmission rate (6.2 per 100 index stays).
  Schizophrenia also ranked in the top five diagnoses with the highest 30-day readmission rates for all payers, except for patients with Medicaid, for whom it ranked ninth for 30-day readmissions (24.9 per 100 index stays).
■ The diagnoses with the highest 7-day readmission rates differed from those with the highest 30-day readmission rates for all payers, except for those with private insurance.
  Although rankings differed, the top five diagnoses with the highest 7-day readmission rates were the same as those with the highest 30-day readmission rates for patients with private insurance: acute and unspecified renal failure, regional enteritis and ulcerative colitis, schizophrenia and other psychotic disorders, CHF, and deficiency and other anemia.
  For patients with Medicare, heart valve disorders and hypertension with complications were among the top five diagnoses with the highest 7-day readmission rates, but these diagnoses did not rank in the top five for 30-day readmissions. Instead, deficiency and other anemia and CHF ranked among the top five diagnoses with the highest 30-day readmission rates.
  For patients with Medicaid, schizophrenia was among the top five diagnoses with the highest 7-day readmission rates, but this diagnosis did not rank in the top five for 30-day readmissions. Instead, complication of device, implant or graft ranked among the top five diagnoses with the highest 30-day readmission rates.
  For patients without insurance, three of the five diagnoses with the highest 7-day readmission rates were related to mental health: schizophrenia, alcohol-related disorders, and mood disorders. In comparison, mood disorders did not rank in the top five diagnoses with the highest 30-day readmission rates. With respect to diagnoses that were unrelated to mental health, abdominal pain and complications of surgical procedures or medical care ranked in the top five diagnoses with the highest 7-day readmission rates, but these diagnoses did not rank in the top five for 30-day readmissions. Instead, regional enteritis and ulcerative colitis; complication of device, implant or graft; and CHF ranked among the top five diagnoses with the highest 30-day readmission rates for patients who were uninsured.

Figure 3 displays all-cause 7-day and 30-day readmission rates following index stays for select conditions by expected payer. The conditions shown are septicemia, CHF, and schizophrenia. These conditions were chosen as examples because they constitute a high volume of index stays and are among the conditions with the highest readmission rates. For instance, as shown in Table 1, septicemia constitutes a high volume of nonmaternal and nonneonatal stays and ranks among the top 20 diagnoses with the highest 7-day and 30-day readmission rates. Schizophrenia and CHF are both chronic conditions and among the top three diagnoses with the highest 7-day and 30-day readmission rates, with one being a mental illness and the other a physical condition. Schizophrenia also is among the top five diagnoses with the highest 7-day readmission rates for each payer category.

Figure 3 All-cause 7-day and 30-day readmission rates following index stays for three select conditions, by expected payer, 2014

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Readmissions Database (NRD), 2014

Bar chart that shows 7- and 30-day readmission rates following index stays for septicemia (N=1,202,893), congestive heart failure (N=795,709), and schizophrenia and other psychotic disorders (N=374,097), by expected payer in 2014. Septicemia: Medicare: readmission rate within 7 days: 7.0; total readmission rate within 30 days: 19.8. Medicaid: readmission rate within 7 days: 7.5; total readmission rate within 30 days: 20.1. Private: readmission rate within 7 days: 5.1; total readmission rate within 30 days: 14.0. Uninsured: readmission rate within 7 days: 4.6; total readmission rate within 30 days: 11.0. Congestive heart failure: Medicare: readmission rate within 7 days: 7.4; total readmission rate within 30 days: 23.3. Medicaid: readmission rate within 7 days: 9.0; total readmission rate within 30 days: 28.5. Private: readmission rate within 7 days: 6.0; total readmission rate within 30 days: 18.7. Uninsured: readmission rate within 7 days: 5.2; total readmission rate within 30 days: 17.0. Schizophrenia and other psychotic disorders: Medicare: readmission rate within 7 days: 9.3; total readmission rate within 30 days: 23.9. Medicaid: readmission rate within 7 days: 9.9; total readmission rate within 30 days: 24.9. Private: readmission rate within 7 days: 6.2; total readmission rate within 30 days: 15.8. Uninsured: readmission rate within 7 days: 7.4; total readmission rate within 30 days: 17.3.

■ For septicemia, CHF, and schizophrenia, the pattern of 7-day readmissions across categories of expected payer was consistent with the pattern of 30-day readmissions.
  For both 7-day and 30-day readmissions, the rate of readmission for septicemia, CHF, and schizophrenia was highest for patients with Medicare and Medicaid and lowest for patients with private insurance and those who were uninsured.
■ For all three conditions, 7-day and 30-day readmission rates were particularly high among patients with Medicare or Medicaid.
  Among patients with Medicare or Medicaid who were discharged with one of these three conditions at the index stay, between 1 in 4 and 1 in 5 stays resulted in readmission within 30 days. The 7-day readmission rate was also highest for patients with Medicare or Medicaid. In particular, nearly 1 in 10 stays paid by Medicaid for patients with CHF or schizophrenia resulted in readmission within 7 days.

In addition to the rate of readmission per 100 index stays as shown in Figure 3, readmissions within 7 days are shown as a percentage of all 30-day readmissions in Table 3 for these same conditions (septicemia, CHF, and schizophrenia).

Table 3 All-cause 7-day readmissions as a percentage of 30-day readmissions following index stays for three select conditions, by expected payer, 2014

Expected payer | Septicemia | | Congestive heart failure | | Schizophrenia and other psychotic disorders
Expected payer | Number of 30-day readmissions | 30-day readmissions within 7 days, % | Number of 30-day readmissions | 30-day readmissions within 7 days, % | Number of 30-day readmissions | 30-day readmissions within 7 days, %
Medicare | 155,652 | 35.5 | 142,967 | 31.7 | 36,015 | 38.8
Medicaid | 32,408 | 37.1 | 22,464 | 31.8 | 37,762 | 39.7
Private | 25,848 | 36.3 | 12,685 | 32.3 | 5,625 | 39.2
Uninsured | 5,102 | 41.4 | 3,738 | 30.5 | 4,087 | 42.7

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Readmissions Database (NRD), 2014

■ The percentage of 30-day readmissions that occurred within 7 days was higher for index stays with septicemia or schizophrenia than for those with CHF.
  Across payers, the percentage of 30-day readmissions that occurred within 1 week of initial discharge ranged from 36 to 41 percent for index stays with septicemia and 39 to 43 percent for those with schizophrenia and other psychotic disorders. In comparison, 31–32 percent of 30-day readmissions for CHF occurred within 7 days across payers.
■ Among patients who were readmitted within 30 days of an index stay for septicemia or schizophrenia, those who were uninsured were readmitted earlier than patients with any type of health insurance coverage.
  The percentage of 30-day readmissions related to septicemia and schizophrenia that occurred within 7 days was highest for uninsured patients (41.4 and 42.7 percent, respectively) and lowest for patients with Medicare (35.5 and 38.8 percent, respectively).

## Data Source

The estimates in this Statistical Brief are based upon data from the Healthcare Cost and Utilization Project (HCUP) 2014 Nationwide Readmissions Database (NRD).

## Definitions

### Diagnoses and Clinical Classifications Software (CCS)

The principal diagnosis is that condition established after study to be chiefly responsible for the patient's admission to the hospital.

CCS categorizes ICD-9-CM diagnosis codes into a manageable number of clinically meaningful categories.^10^ This clinical grouper makes it easier to quickly understand patterns of diagnoses use. CCS categories identified as Other typically are not reported; these categories include miscellaneous, otherwise unclassifiable diagnoses that may be difficult to interpret as a group.

### Readmissions

The 30-day readmission rate is defined as the number of admissions for each condition for which there was at least one subsequent hospital admission within 7 or 30 days, divided by the total number of admissions from January through November of the same year. That is, when patients are discharged from the hospital, they are followed for 7 or 30 days in the data. If any readmission to the same or different hospital occurs during the specified time period, the admission is counted as having a readmission. No more than one readmission is counted within the 7- or 30-day period, because the outcome measure assessed is “percentage of admissions that are readmitted.” If a patient was transferred to a different hospital on the same day or was transferred within the same hospital, the two events were combined as a single stay and the second event was not counted as a readmission; that is, transfers were not considered a readmission.

Every qualifying inpatient stay is counted as a separate initial (starting point) admission, called an index stay. Thus, a single patient can be counted multiple times during the course of the January through November observation period. In addition, index stays do not require a prior “clean period” with no hospitalizations; that is, a hospital stay may be a readmission for a prior stay and the initial admission for a subsequent readmission. Admissions were disqualified from the analysis as index stays if they could not be followed for 7 or 30 days for one of the following reasons: (1) the patient died in the hospital, (2) information on length of stay was missing, or (3) the patient was discharged in December.

### Types of hospitals included in the HCUP Nationwide Readmissions Database

The Nationwide Readmissions Database (NRD) is based on data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). The NRD includes obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded are long-term care facilities such as rehabilitation, long-term acute care, psychiatric, and alcoholism and chemical dependency hospitals. However, if a patient received long-term care, rehabilitation, or treatment for a psychiatric or chemical dependency condition in a community hospital, the discharge record for that stay will be included in the NRD.

### Unit of analysis

The unit of analysis is the hospital discharge (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the hospital multiple times in 1 year will be counted each time as a separate discharge from the hospital.

### Payer

Payer is the expected payer for the hospital stay. To make coding uniform across all HCUP data sources, payer combines detailed categories into general groups:

- Medicare: includes patients covered by fee-for-service and managed care Medicare
- Medicaid: includes patients covered by fee-for-service and managed care Medicaid
- Private Insurance: includes Blue Cross, commercial carriers, and private health maintenance organizations (HMOs) and preferred provider organizations (PPOs)
- Uninsured: includes an insurance status of self-pay and no charge
- Other: includes Workers' Compensation, TRICARE/CHAMPUS, CHAMPVA, Title V, and other government programs

Hospital stays billed to the State Children's Health Insurance Program (SCHIP) may be classified as Medicaid, Private Insurance, or Other, depending on the structure of the State program. Because most State data do not identify patients in SCHIP specifically, it is not possible to present this information separately.

For this Statistical Brief, a hierarchy was used to assign the payer category based on the primary and secondary expected payer:^11^

- If the primary or secondary expected payer indicates Medicare, then the payer category is assigned to Medicare. This categorization includes patients who are dually eligible for Medicare and Medicaid under Medicare.
- If not Medicare and the primary or secondary expected payer indicates Medicaid, then the payer category is Medicaid.
- If not Medicare or Medicaid and the primary or secondary expected payer indicates private insurance, then the payer category is private.
- If not Medicare, Medicaid, or private and the primary expected payer indicates self-pay or no charge, then the payer category is uninsured.
- Stays for other types of payers are not reported in this Statistical Brief because this is a small group of mixed payers such as State and local programs.

Categorization of readmission counts by expected payer was based on the index stay. The concordance between the expected payer coded at the index stay and the expected payer coded at readmission varies by payer: 98 percent for Medicare, 95 percent for Medicaid, 93 percent for private, and 80 percent for uninsured (percentages based on the 2013 NRD).

## For More Information

For other information on readmissions and revisits, refer to the HCUP Statistical Briefs located at www.hcup-us.ahrq.gov/reports/statbriefs/sb_readmission.jsp. For additional HCUP statistics, visit:

- HCUP Fast Stats at www.hcup-us.ahrq.gov/faststats/landing.jsp for easy access to the latest HCUP-based statistics for health information topics
- HCUPnet, HCUP's interactive query system, at www.hcupnet.ahrq.gov/

For more information about HCUP, visit www.hcup-us.ahrq.gov/.

For a detailed description of HCUP and more information on the design of the Nationwide Readmissions Database (NRD), please refer to the following database documentation:

Agency for Healthcare Research and Quality. Overview of the Nationwide Readmissions Database (NRD). Healthcare Cost and Utilization Project (HCUP). Rockville, MD: Agency for Healthcare Research and Quality. Updated December 2016. www.hcup-us.ahrq.gov/nrdoverview.jsp. Accessed January 31, 2017 .

1 Colorado Medical Association. Inpatient/Outpatient Billing Manual. February 2014. www.colorado.gov/pacific/sites/default/files/IP%20and%20OP%20Hospital%20Billing%20Manual%20(February%202014).pdf. Accessed September 15, 2017 .

2 Chin DL, Bang H, Manickam RN, Romano PS. Rethinking Thirty-Day Hospital Readmissions: Shorter Intervals Might Be Better Indicators of Quality of Care. Health Affairs (Millwood). 2016;35(10):1867–75 .

3 Michigan Department of Health and Human Services. Medicaid Provider Manual. July 2017. www.mdch.state.mi.us/dch-medicaid/manuals/MedicaidProviderManual.pdf. Accessed September 15, 2017 .

4 Texas External Quality Review Organization. Potentially Preventable Readmissions in Texas Medicaid and CHIP Programs. December 2014. hhs.texas.gov/sites/default/files/documents/about-hhs/process-improvement/medicaid-chip-qei/PPR-Statewide-Report-FY2013.pdf. Accessed September 15, 2017 .

5 Ibid.

6 Centers for Medicare & Medicaid Services. Hospital Readmissions Reduction Program (HRRP). April 2016. www.cms.gov/Medicare/Medicare-Fee-for-Service-Payment/AcuteInpatientPPS/Readmissions-Reduction-Program.html. Accessed June 6, 2017 .

7 Washington State Health Care Authority. Potentially Preventable Readmissions (PPR) Policy. Frequently Asked Questions (FAQ) – CY 2016. February 2016. www.wsha.org/wp-content/uploads/WA-PPR-FAQ-Final.pdf. Accessed September 15, 2017 .

8 Chin et al., 2016. Op. cit.

9 Herrin J, St Andre J, Kenward K, Joshi MS, Audet AM, Hines SC. Community factors and hospital readmission rates. Health Services Research. 2015;50(1):20–39 24712374 .

10 Agency for Healthcare Research and Quality. HCUP Clinical Classifications Software (CCS) for ICD-9-CM. Healthcare Cost and Utilization Project (HCUP). Rockville, MD: Agency for Healthcare Research and Quality. Updated October 2016. www.hcup-us.ahrq.gov/toolssoftware/ccs/ccs.jsp. Accessed January 31, 2017 .

11 The 2013 NRD available for purchase through the HCUP Central Distributor includes the data element for the primary expected payer but not the data element for the secondary expected payer.