# Statistical Brief #229 Characteristics of Homeless Individuals Using Emergency Department Services in 2014

## Introduction

Homeless people are more likely than members of the general public to use emergency department (ED) services. Compared with the general population, homeless individuals are 3 times more likely to use an ED at least once in a year.^1^ Nearly three out of four inpatient stays by homeless individuals began in the ED, compared with half of stays for nonhomeless patients.^2^ Various factors may contribute to this outcome. Prior research has shown that homeless individuals experience acute physical disorders at 3 to 6 times the rates experienced by nonhomeless individuals.^3^ It has also been shown that homeless individuals have high rates of mental illness^2,4,5,6^ and high rates of hospitalization.^7^ Because of barriers to access to care—such as lack of insurance and transportation—as well as poor continuity of care, homeless people frequently use EDs as their primary or only source of health care.^8,9^ When they do seek medical care, it is usually at teaching hospitals.^10^

This Healthcare Cost and Utilization Project (HCUP) Statistical Brief presents patient characteristics, insurance coverage, and a clinical profile of ED visits among homeless individuals during 2014 in eight States (Arizona, Florida, Georgia, Maryland, Massachusetts, Missouri, New York, and Wisconsin). Homelessness is directly reported by the hospitals; there is an indicator for each discharge from inpatient hospitals or hospital-affiliated EDs regarding a patient’s homelessness status. Data used for this analysis include ED visits that resulted in admission to inpatient care at the same hospital, as well as treat-and-release ED visits that resulted in discharge from the ED, which includes patients who were routinely discharged, who were transferred to another type of healthcare facility, who were discharged against medical advice, or who died in the ED. Homeless individuals’ demographic information, expected primary payer, and prevalence of a mental or substance use disorder are summarized for Black, Hispanic, and White individuals by hospital teaching status.

## Findings

Highlights

■ More than three-fourths of all ED visits by homeless individuals were to teaching hospitals.
■ In teaching hospitals, Medicaid was the most common payer for ED visits by homeless individuals (47.1 percent of treat-and-release ED visits and 72.1 percent of ED visits resulting in hospital admission).
■ In nonteaching hospitals, more than 40 percent of ED visits by homeless individuals were uninsured.
■ Among treat-and-release ED visits, alcohol-related disorders, screening and history of mental disorders and substance abuse, and mood disorders were the three most common conditions by homeless individuals with a mental or substance use disorder.
■ Among ED visits resulting in hospital admission, schizophrenia and other psychotic disorders, mood disorders, and alcohol-related disorders were the three most common conditions by homeless individuals with a mental or substance use disorder.
■ More than half of ED visits resulting in hospital admission for Black homeless individuals with a mental or substance use disorder were attributable to schizophrenia.
■ More than one-third of ED visits resulting in admission to nonteaching hospitals for White and Hispanic homeless individuals with a mental or substance use disordr were attributable to mood disorders.

### Patient characteristics of ED visits among homeless individuals in teaching and nonteaching hospitals, 2014

Table 1 shows variations among ED visits in homeless individuals’ age, sex, race/ethnicity, and expected primary payer by type of ED visit and hospital type.

Table 1 Demographic profile of ED visits by homeless individuals, 2014

Patient characteristic | Treat-and-release ED visits | | ED visits resulting in hospital admission
Patient characteristic | Teaching hospital | Nonteaching hospital | Teaching hospital | Nonteaching hospital
Total number of ED visits^a^ | 73,600 | 25,600 | 110,200 | 4,900
Age, %
Under 18 | 2.0 | 4.4 | 8.0 | 0.3
18–29 | 17.5 | 22.3 | 18.4 | 13.8
30–44 | 28.6 | 27.0 | 22.9 | 23.0
45–64 | 47.7 | 41.9 | 33.1 | 53.8
65 and older | 4.2 | 4.4 | 17.6 | 9.1
Sex, %
Male | 73.0 | 69.5 | 49.3 | 75.1
Race/ethnicity, %
White | 56.0 | 72.1 | 18.1 | 74.5
Black | 24.7 | 12.2 | 35.5 | 14.0
Hispanic | 13.1 | 8.8 | 29.7 | 8.9
Expected primary payer, %
Medicare | 15.6 | 11.7 | 21.7 | 21.7
Medicaid | 47.1 | 28.8 | 72.1 | 28.4
Private | 3.9 | 6.7 | 1.7 | 5.6
Uninsured | 28.1 | 49.2 | 3.8 | 41.0
Other | 5.2 | 3.5 | 0.7 | 3.3

Abbreviation: ED, emergency department

a Total numbers of ED visits are rounded to the nearest hundred

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), 2014 State Inpatient Databases (SID) and 2014 State Emergency Department Databases (SEDD) from eight States (Arizona, Florida, Georgia, Maryland, Massachusetts, Missouri, New York, and Wisconsin)

■ In 2014, the majority—86 percent—of ED visits by homeless individuals were made to teaching hospitals.
  There were 99,200 total treat-and-release ED visits by homeless individuals from eight States (73,600 visits at teaching hospitals plus 25,600 visits at nonteaching hospitals).
  There were 115,100 total ED visits resulting in hospital admission by homeless individuals in eight States (110,200 visits admitted to teaching hospitals plus 4,900 visits admitted to nonteaching hospitals).
■ The proportion of ED visits by homeless individuals differed between teaching and nonteaching hospitals across age cohorts.
  In 2014, the largest proportion of ED visits by homeless patients was among individuals aged 45–64 years.
  In 2014, among ED visits by homeless patients that resulted in admission to a teaching hospital, 8.0 percent were made by homeless individuals aged less than 18 years old, compared with 0.3 percent admitted to a nonteaching hospital.
■ In 2014, the majority of ED visits by homeless patients were made by male individuals.
  Males accounted for 73.0 and 69.5 percent of treat-and-release ED visits by homeless individuals in teaching and nonteaching hospitals, respectively.
  Male individuals made 49.3 percent of ED visits by homeless patients that resulted in admission to a teaching hospital and 75.1 percent of ED visits by homeless patients that resulted in admission to a nonteaching hospital.
■ The proportion of ED visits by homeless individuals differed between teaching and nonteaching hospitals across racial/ethnic cohorts.
  In 2014, the majority of treat-and-release ED visits by homeless patients were made by White individuals in both teaching and nonteaching hospitals.
  In 2014, about 72 percent of ED visits by homeless patients that resulted in admission to a teaching hospital were by non-White individuals.
■ In 2014, among homeless individuals, Medicaid was the most common expected primary source of payment for ED visits at teaching hospitals but no insurance coverage was most common among ED visits at nonteaching hospitals.
  Among ED visits by homeless individuals at teaching hospitals, Medicaid provided coverage for 47.1 percent of treat-and-release ED visits and 72.1 percent of ED visits that resulted in a hospital admission.
  Among ED visits by homeless individuals at nonteaching hospitals, there was no insurance coverage for 49.2 percent of treat-and-release ED visits and for 41.0 percent of ED visits resulting in a hospital admission.

### Mental and substance use diagnoses among ED visits by homeless individuals, 2014

Table 2 presents the clinical profile of ED visits by homeless individuals with a mental or substance use disorder.

Table 2 Clinical profile of emergency department visits by homeless individuals with a mental or substance use disorder, 2014

Patient Clinical characteristics | Treat-and-release ED visits | | ED visits resulting in hospital admission
Patient Clinical characteristics | Teaching hospital | Nonteaching hospital | Teaching hospital | Nonteaching hospital
Total number of ED visits with a mental or substance use disorder | 44,700 | 14,900 | 26,100 | 2,100
Subcategories of mental and substance use disorders,^a^ %
Adjustment disorders | 0.6 | 0.4 | 1.2 | 1.4
Anxiety disorders | 12.4 | 13.8 | 0.8 | 1.4
Attention deficit, conduct, and disruptive behavior disorders | 1.6 | 1.3 | 0.8 | —^b^
Delirium, dementia, and amnestic and other cognitive disorders | 0.4 | 0.6 | 1.1 | 0.8
Developmental disorders | 1.0 | 0.6 | 0.0 | —^b^
Disorders usually diagnosed in infancy, childhood, or adolescence | 0.2 | 0.1 | 0.2 | —^b^
Impulse control disorders | 0.1 | —^b^ | 0.7 | —^b^
Mood disorders | 25.1 | 22.3 | 25.9 | 38.9
Personality disorders | 0.8 | 0.6 | 0.3 | —^b^
Schizophrenia and other psychotic disorders | 10.1 | 7.0 | 38.4 | 25.7
Alcohol-related disorders | 46.0 | 34.0 | 19.5 | 24.7
Substance-related disorders | 21.9 | 16.8 | 10.3 | 6.1
Suicide and intentional self-inflicted injury | 8.0 | 9.1 | 0.0 | 0.2
Screening and history of mental health and substance abuse | 37.4 | 57.4 | —^b^ | —^b^
Miscellaneous disorders | 0.4 | 0.4 | 0.7 | —^b^

Abbreviation: ED, emergency department

Notes: Total numbers of ED visits with a mental or substance use disorder are rounded to the nearest hundred.

a Disease categories are based on the Clinical Classification Software (CCS)—a diagnosis and procedure categorization scheme based on the International Classification of Diseases, 9th Revision, Clinical Modification (ICD-9-CM). Percentages in the table are based on principal diagnosis codes at inpatient facilities. The HCUP SEDD do not differentiate between the principal diagnosis codes and other diagnosis codes. Therefore, we used all diagnosis codes reported for each treat-and-release ED visit when creating broader CCS disease categories.

b Statistics are not reported whenever there are fewer than 11 observations in a particular cell.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), 2014 State Inpatient Databases (SID) and 2014 State Emergency Department Databases (SEDD) from eight States (Arizona, Florida, Georgia, Maryland, Massachusetts, Missouri, New York and Wisconsin)

■ In 2014, the majority of treat-and-release ED visits among homeless individuals involved a mental or substance use disorder.
  For ED treat-and-release visits among homeless individuals, nearly 60 percent of ED visits at both teaching (44,700 out of 73,600, or 60.7 percent) and nonteaching hospitals (14,900 out of 25,600, or 58.2 percent) involved a mental or substance use disorder.
■ In 2014, alcohol-related disorders, mood disorders, and screening and history of mental and substance abuse were the three most common conditions among treat-and-release ED visits by homeless individuals with a mental or substance use disorder.
  In teaching hospitals, alcohol-related disorders were the most prevalent conditions (46.0 percent) followed by screening and history of mental health and substance abuse (37.4 percent) and mood disorders (25.1 percent) among treat-and-release ED visits by homeless individuals with a mental or substance use disorder.
  In nonteaching hospitals, screening and history of mental health and substance abuse was the most prevalent condition (57.4 percent) followed by alcohol-related disorders (34.0 percent) and mood disorders (22.3 percent) among treat-and-release ED visits by homeless individuals with a mental or substance use disorder.
■ In 2014, alcohol-related disorders, mood disorders, and schizophrenia and other psychotic disorders were the three most common conditions among ED visits resulting in hospital admission by homeless individuals with a mental or substance use disorder.
  Schizophrenia and other psychotic disorders (38.4 percent), mood disorders (25.9 percent), and alcohol-related disorders (19.5 percent) were the most common mental and substance use disorders among ED visits by homeless individuals resulting in admission to teaching hospitals. These disorders also ranked in the top three at nonteaching hospitals, but the leading diagnosis was mood disorders (38.9 percent).

Figure 1 shows racial/ethnic differences in the distribution of the three most common mental and substance use disorders among treat-and-release ED visits by homeless individuals.

Figure 1 Common mental and substance use disorders among treat-and-release ED visits by homeless individuals, 2014

Note: Disease categories are based on the Clinical Classification Software (CCS)—a diagnosis and procedure categorization scheme based on the International Classification of Diseases, 9th Revision, Clinical Modification. The first-listed diagnosis for treat-and-release ED records may not reflect the principal reason for the visit, as it does for inpatient stays. Therefore, we used all diagnosis codes reported for each treat-and-release ED visit when creating broader CCS disease categories. Thus, the percentages can add to more than 100 percent because a record may have more than one mental health and substance use disorder listed.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), 2014 State Inpatient Databases (SID) and 2014 State Emergency Department Databases (SEDD) from eight States (Arizona, Florida, Georgia, Maryland, Massachusetts, Missouri, New York, and Wisconsin)

Figure 1. Common mental and substance use disorders among treat-and-release ED visits by homeless individuals, 2014. Bar chart that shows percentage of common mental and substance use disorders among treat-and-release ED visits by homeless individuals in 2014 by race and hospital teaching status. Teaching hospitals: White: alcohol-related disorders 48.3; screening and history of mental health and substance abuse 38.2; mood disorders 26.1; Black: alcohol-related disorders 37.6; screening and history of mental health and substance abuse 37.3; mood disorders 23.9; Hispanic: alcohol-related disorders 44.7; screening and history of mental health and substance abuse 35.0; mood disorders 24.7. Nonteaching hospitals: White: alcohol-related disorders 35.4; screening and history of mental health and substance abuse 59.5; mood disorders 22.6; Black: alcohol-related disorders 17.7; screening and history of mental health and substance abuse 57.5; mood disorders 24.2; Hispanic: alcohol-related disorders 43.1; screening and history of mental health and substance abuse 33.6; mood disorders 21.1.

■ The proportions of treat-and-release ED visits by homeless individuals with a mental or substance use disorder that were for mood disorders, screening and history of mental health and substance use, and alcohol-related disorders differed between teaching and nonteaching hospitals across racial/ethnic cohorts.
  In teaching hospitals, alcohol-related disorders were the most common conditions across all racial/ethnic cohorts among treat-and-release ED visits by homeless individuals with a mental or substance use disorder (48.3, 37.6 and 44.7 percent respectively for White, Black, and Hispanic homeless individuals).
  In nonteaching hospitals, screening and history of mental health and substance abuse was the most common condition among treat-and-release ED visits by White and Black homeless individuals with a mental or substance use disorder (59.5 and 57.5 percent, respectively). In comparison, alcohol-related disorders were the most common conditions for Hispanics (43.1 percent).

Figure 2 shows racial/ethnic differences in the distribution of the three most common mental and substance use disorders among ED visits by homeless individuals that resulted in hospital admission.

Figure 2 Common mental and substance use disorders among ED visits resulting in hospital admission by homeless individuals, 2014

Note: Disease categories are based on the Clinical Classification Software—a diagnosis and procedure categorization scheme based on the International Classification of Diseases, 9th Revision, Clinical Modification. The percentages are based on principal diagnosis codes on the inpatient record.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), 2014 State Inpatient Databases (SID) and 2014 State Emergency Department Databases (SEDD) from eight States (Arizona, Florida, Georgia, Maryland, Massachusetts, Missouri, New York, and Wisconsin).

Figure 2. Common mental and substance use disorders among ED visits resulting in hospital admission by homeless individuals, 2014. Bar chart that shows percentage of common mental and substance use disorders among ED visits resulting in hospital admission by homeless individuals in 2014 by race and hospital teaching status. Teaching hospitals: White: alcohol-related disorders 30.0; screening and history of mental health and substance abuse 29.9; mood disorders 20.8; Black: alcohol-related disorders 10.5; screening and history of mental health and substance abuse 21.4; mood disorders 54.5; Hispanic: alcohol-related disorders 21.4; screening and history of mental health and substance abuse 28.0; mood disorders 33.8. Nonteaching hospitals: White: alcohol-related disorders 30.1; screening and history of mental health and substance abuse 41.1; mood disorders 17.5; Black: alcohol-related disorders 5.5; screening and history of mental health and substance abuse 31.5; mood disorders 55.3; Hispanic: alcohol-related disorders 20.0; screening and history of mental health and substance abuse 41.5; mood disorders 28.2.

■ In 2014, more than half of ED visits resulting in hospital admission for Black homeless individuals with a mental or substance use disorder were attributable to schizophrenia.
  Among ED visits by Black homeless individuals with a mental or substance use disorder, 54.5 and 55.3 percent of visits were for schizophrenia and other psychotic disorders for those admitted to teaching and nonteaching hospitals, respectively.
■ In 2014, more than one-third of ED visits resulting in admission to nonteaching hospitals by White and Hispanic homeless individuals with a mental or substance use disorder were attributable to mood disorders.
  In nonteaching hospitals, mood disorders were the most common conditions among ED visits resulting in hospital admission for White and Hispanic homeless individuals with a mental or substance use disorder (41.1 and 41.5 percent, respectively).

## Data Source

The estimates in this Statistical Brief are based upon data from the Healthcare Cost and Utilization Project (HCUP) State Inpatient Databases (SID) and State Emergency Department Databases (SEDD) for 2014. Eight States were included in the analysis: Arizona, Florida, Georgia, Maryland, Massachusetts, Missouri, New York, and Wisconsin.

## Definitions

### Diagnoses, ICD-9-CM, and Clinical Classifications Software (CCS)

The principal diagnosis is that condition established after study to be chiefly responsible for the patient’s admission to the hospital. Secondary diagnoses are concomitant conditions that coexist at the time of admission or develop during the stay. All-listed diagnoses include the principal diagnosis plus these additional secondary conditions.

ICD-9-CM is the International Classification of Diseases, Ninth Revision, Clinical Modification, which assigns numeric codes to diagnoses. There are approximately 14,000 ICD-9-CM diagnosis codes.

CCS categorizes ICD-9-CM diagnosis codes into a manageable number of clinically meaningful categories.^11^ This clinical grouper makes it easier to quickly understand patterns of diagnoses. CCS categories identified as Other typically are not reported; these categories include miscellaneous, otherwise unclassifiable diagnoses that may be difficult to interpret as a group.

In this analysis, mental and substance use conditions are based on clinical classification of the principal diagnosis for visits that resulted in inpatient stays and are based on all-listed diagnoses for records where the patient was discharged from the emergency department.

### Case definition

Homelessness is directly reported by the hospitals. There is an indicator for each discharge from inpatient hospitals or hospital-affiliated emergency departments regarding the patient’s homelessness status.

### Types of hospitals included in HCUP State Inpatient Databases

This analysis used State Inpatient Databases (SID) limited to data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). Community hospitals include obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded for this analysis are long-term care facilities such as rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. However, if a patient received long-term care, rehabilitation, or treatment for a psychiatric or chemical dependency condition in a community hospital, the discharge record for that stay was included in the analysis.

### Types of hospitals included in HCUP State Emergency Department Databases

This analysis used State Emergency Department Databases (SEDD) limited to data from community hospitals with a hospital-based emergency department. Community hospitals are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). Community hospitals include specialty, pediatric, public, and academic medical hospitals. Excluded for this analysis are long-term care facilities such as rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals.

### Unit of analysis

The unit of analysis for inpatient data is the hospital discharge (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the hospital multiple times in 1 year will be counted each time as a separate discharge from the hospital. Inpatient stays include those admitted through the emergency department (ED).

The unit of analysis for ED data is the ED visit, not a person or patient. This means that a person who is seen in the ED multiple times in 1 year will be counted each time as a separate visit in the ED. ED visits exclude those for patients admitted to the hospital, including patients transferred to other hospitals.

### Payer

Payer is the expected payer for the hospital stay. To make coding uniform across all HCUP data sources, payer combines detailed categories into general groups:

- Medicare: Includes patients covered by fee-for-service and managed care Medicare
- Medicaid: Includes patients covered by fee-for-service and managed care Medicaid
- Private Insurance: Includes Blue Cross, commercial carriers, and private health maintenance organizations (HMOs) and preferred provider organizations (PPOs)
- Uninsured: Includes an insurance status of self-pay and no charge
- Other: Includes Worker’s Compensation, TRICARE/CHAMPUS, CHAMPVA, Title V, and other government programs.

When more than one payer is listed for a hospital discharge, the first-listed payer is used.

### Teaching hospitals

Teaching hospital status was based on variables provided by American Hospital Association (AHA) Annual Survey, 2014. A hospital is defined as a teaching hospital if one of the following conditions holds:

- The hospital is a member of the Council of Teaching Hospital of the Association of American Medical Colleges (COTH).
- The participating site is recognized for one or more programs accredited by the Accreditation Council for Graduate Medical Education.
- The ratio of interns and residents to beds is 0.25 or higher.

### Reporting of race and ethnicity

Data on Hispanic ethnicity are collected differently among the States and also can differ from the census methodology of collecting information on race (White, Black, Asian/Pacific Islander, American Indian/Alaska Native, Other [including mixed race]) separately from ethnicity (Hispanic, non-Hispanic). State data organizations often collect Hispanic ethnicity as one of several categories that include race. Therefore, for multistate analyses, HCUP creates the combined categorization of race and ethnicity for data from States that report ethnicity separately. This Statistical Brief reports race/ethnicity only for the following categories: non-Hispanic White, non-Hispanic Black, and Hispanic.

## For More Information

For more information on hospital utilization among individuals with low income, including homeless individuals, refer to the HCUP Statistical Briefs located at www.hcup-us.ahrq.gov/reports/statbriefs/sb_lowincome.jsp.

For additional HCUP statistics, visit:

- HCUP Fast Stats at www.hcup-us.ahrq.gov/faststats/landing.jsp for easy access to the latest HCUP-based statistics for health information topics
- HCUPnet, HCUP’s interactive query system, at hcupnet.ahrq.gov/

For more information about HCUP, visit www.hcup-us.ahrq.gov/.

For a detailed description of HCUP and more information on the design of the State Inpatient Databases (SID) or State Emergency Department Databases (SEDD), please refer to the following database documentation:

Agency for Healthcare Research and Quality. Overview of the State Inpatient Databases (SID). Healthcare Cost and Utilization Project (HCUP). Rockville, MD: Agency for Healthcare Research and Quality. Updated June 2016. www.hcup-us.ahrq.gov/sidoverview.jsp. Accessed January 31, 2017.

Agency for Healthcare Research and Quality. Overview of the State Emergency Department Databases (SEDD). Healthcare Cost and Utilization Project (HCUP). Rockville, MD: Agency for Healthcare Research and Quality. Updated June 2016. www.hcup-us.ahrq.gov/seddoverview.jsp. Accessed January 31, 2017.

1 Kushel MB, Vittinghoff E, Haas JS. Factors associated with the health care utilization of homeless persons. Journal of the American Medical Association. 2001;285(2):200–6.11176814

2 Karaca Z (AHRQ), Wong H (AHRQ), Mutter R (AHRQ). Characteristics of Homeless and Non-Homeless Individuals Using Inpatient and Emergency Department Services, 2008. Statistical Brief #152. March 2013. Agency for Healthcare Research and Quality, Rockville, MD. www.hcup-us.ahrq.gov/reports/statbriefs/sb152.pdf. Accessed August 8, 2017.

3 Wright JD. Poor people, poor health: the health status of the homeless. Journal of Social Issues. 1990;46(4):49–64.

4 Wright NM, Tompkins CN. How can health services effectively meet the health needs of homeless people? British Journal of General Practice. 2006;56(525):286–93.

5 Bassuk EL, Buckner JC, Perloff JN, Bassuk SS. Prevalence of mental health and substance use disorders among homeless and low-income housed mothers. American Journal of Psychiatry. 1998;155(11):1561–4.9812118

6 Sadowski LS, Kee RA, VanderWeele TJ, Buchanan D. Effect of a housing and case management program on emergency department visits and hospitalizations among chronically ill homeless adults: a randomized trial. Journal of the American Medical Association. 2009;301(17):1771–8.19417194

7 Martell JV, Seitz RS, Harada JK, Kobayashi J, Sasaki VK, Wong C. Hospitalization in an urban homeless population: the Honolulu Urban Homeless Project. Annals of Internal Medicine. 1992;116(4):299–303.1733384

8 Kushel MB, Perry S, Bangsberg D, Clark R, Moss AR. Emergency department use among the homeless and marginally housed: results from a community-based study. American Journal of Public Health. 2002 May;92(5):778–84.11988447

9 Morris DM, Gordon JA. The role of the emergency department in the care of homeless and disadvantaged populations. Emergency Medicine Clinics of North America. 2006;24(4):839–48.16982342

10 Bowdler JE, Barrell LM. Health needs of homeless persons. Public Health Nursing. 1987;4(3):135–40.3684889

11 Agency for Healthcare Research and Quality. HCUP Clinical Classifications Software (CCS) for ICD-9-CM. Healthcare Cost and Utilization Project (HCUP). Rockville, MD: Agency for Healthcare Research and Quality. Updated October 2016. www.hcup-us.ahrq.gov/toolssoftware/ccs/ccs.jsp. Accessed January 31, 2017