# Statistical Brief #226 Patient Residence Characteristics of Opioid-Related Inpatient Stays and Emergency Department Visits Nationally and by State, 2014

## Introduction

Data from the Healthcare Cost and Utilization Project (HCUP) have been used to document dramatic increases in inpatient hospitalizations and emergency department (ED) visits related to opioid use.^1^ The Agency for Healthcare Research and Quality (AHRQ) is publishing a series of Statistical Briefs that provide descriptive information on opioid-related hospital use by State and select patient subgroups. A recent report showed that females and patients aged 65 years and older had the greatest increases in the rate of opioid-related inpatient stays between 2005 and 2014.^2^

This HCUP Statistical Brief presents data from HCUP Fast Stats on the rates of opioid-related hospital inpatient stays and ED visits by patient location (urban/rural) and community-level income from 2005 to 2014.^3^ The location and income groups with the highest opioid-related inpatient rates are presented for each of 44 States and the District of Columbia that provided inpatient data in 2014. The location and income groups with the highest opioid-related ED visit rates are presented for each of 30 States that provided ED visit data in 2014. States are ranked overall on the rates of opioid-related inpatient stays and ED visits by location and income group in 2014. Identification of opioid-related stays and visits is based on all-listed diagnoses and includes events associated with prescription opioids or illicit opioids such as heroin. Rates are calculated using the population denominator specific to each location or income group.

## Findings

Highlights

■ From 2005 to 2014 in the United States, large central metropolitan areas had the highest rate of opioid-related inpatient stays. However, the rate of opioid hospitalizations increased the most in small metropolitan areas—a 122 percent increase versus a 28 percent increase in large central metropolitan areas.
■ The rate of opioid-related emergency department (ED) visits increased less in large metropolitan areas than in medium metropolitan, small metropolitan, and rural areas.
■ In 2014, the rates of opioid-related inpatient stays and ED visits were highest in urban areas for some States and in rural areas for other States.
  ■ Among States with the highest rates in large central metropolitan areas, opioid-related inpatient stays and ED visits averaged 446.5 and 377.1 per 100,000 population, respectively.
  ■ Among States with the highest rates in rural areas, opioid-related inpatient stays and ED visits averaged 215.4 and 177.3 per 100,000 population, respectively.
■ For most States in 2014, the highest rates of opioid-related inpatient stays and ED visits were among patients residing in the communities with the lowest income.

### National rate of opioid-related inpatient stays and ED visits by patient location, 2005–2014

Figure 1 presents 10-year trends in the national rate of opioid-related inpatient stays and ED visits by location of patients’ residence, from 2005 to 2014.

Figure 1 National rate of opioid-related inpatient stays and ED visits by patient location, 2005–2014

Abbreviation: ED, emergency department

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), HCUP Fast Stats, Opioid-Related Hospital Use (www.hcup-us.ahrq.gov/faststats/landing.jsp) based on the HCUP National (Nationwide) Inpatient Sample (NIS) and the Nationwide Emergency Department Sample (NEDS)

Figure 1. National rate of opioid-related inpatient stays and ED visits by patient location, 2005–2014. Two line graphs that show the rate of inpatient stays and emergency department visits per 100,000 population from 2005 to 2014 by patient location. Inpatient stays: Large central metropolitan: Increased from 195.8 in 2005 to 257.8 in 2006, decreased to 192.0 in 2008, steady increase to 266.0 in 2011, steady decrease to 243.9 in 2013, increase to 250.5 in 2014—28.0% cumulative increase. Large fringe metropolitan: Increased from 111.5 in 2005 to 142.8 in 2006, small fluctuations between 132.4 in 2007 and 143.5 in 2009, increased steadily to 213.6 in 2014—91.6% cumulative increase. Medium metropolitan: Increased from 126.0 in 2005 in to 126.2 in 2006, decreased to 114.7 in 2007, increased steadily to 160.9 in 2010, decreased to 150.5 in 2011, increased steadily to 210.4 in 2014—67.0% cumulative increase. Small metropolitan: Increased from 89.6 in 2005 to 129.2 in 2007, decreased to 113.8 in 2008, increased steadily to 198.5 in 2014—121.6% cumulative increase. Rural: Increased steadily from 102.5 in 2005 to 204.0 in 2014—99.1% cumulative increase. Emergency department visits: Large central metropolitan: Decreased from 91.9 in 2005 to 83.7 in 2006, increased steadily to 186.5 in 2013, decreased to 176.7 in 2014—92.3% cumulative increase. Large fringe metropolitan: Increased from 96.6 in 2005 to 106.2 in 2006, decreased to 77.6 in 2007, increased steadily to 173.3 in 2014—79.4% cumulative increase. Medium metropolitan: Increased from 93.0 in 2005 to 100.5 in 2006, decreased to 89.5 in 2007, increased steadily to 203.6 in 2014—cumulative increase 118.9%. Small metropolitan: Small fluctuations between 70.1 in 2005 and 71.9 in 2007, increased steadily to 155.0 in 2014—121.2% cumulative increase. Rural: Increased steadily from 71.9 in 2005 to 146.5 in 2014—103.8% cumulative increase.

■ From 2005 to 2014, the rate of opioid-related inpatient stays increased the most in small metropolitan areas and the least in large central metropolitan areas.
  The rate of opioid-related inpatient stays was consistently highest among those residing in large central metropolitan areas from 2005 to 2014. However, over this time period, the rate increased the least in large central metropolitan areas (28 percent) and increased the most in small metropolitan areas–a 122 percent increase, more than doubling in 10 years.
■ The rate of opioid-related ED visits increased the most in small and medium metropolitan areas and the least in large fringe metropolitan areas.
  The rate of opioid-related ED visits from 2005 to 2014 was generally highest among patients residing in large and medium metropolitan areas and lowest among patients residing in small metropolitan and rural areas. However, similar to the trend in inpatient stays, the ED visit rate increased the most in small and medium metropolitan areas (121 and 119 percent, respectively), followed by rural areas (104 percent). The rate increased the least in large fringe metropolitan areas (suburbs, 79 percent), followed by large central metropolitan areas (92 percent).
  Opioid-related ED visits increased at a faster rate than did opioid-related inpatient stays in large central and medium metropolitan areas but increased at a slower rate in large fringe metropolitan areas. Opioid-related inpatient and ED visit rates increased at a similar pace in small metropolitan and rural areas.

### Patient location with the highest rate of opioid-related inpatient stays and ED visits, by State, 2014

Figures 2 and 3 show the patient location within each State with the highest population rate of opioid-related inpatient stays (Figure 2) and ED visits (Figure 3) in 2014. The location with the highest rate overall is reported for each State. States where the difference between the highest and second highest rates was 10 percent or greater are noted with an asterisk. Figure 2 reports the patient location with the highest population rate of opioid-related inpatient stays for each of 44 States and the District of Columbia that provided data in 2014. Details on inpatient rates specific to patient location are shown in Appendix A.

Figure 2 Patient location with the highest rate^a^ a Opioid-related inpatient rates are per 100,000 population. State-level inpatient rates by patient location are provided in Appendix A. of opioid-related inpatient stays, by State, 2014

Note: Asterisks denote States where the difference between the highest and second highest rates in the State was at least 10 percent.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), HCUP Fast Stats, Opioid-Related Hospital Use (www.hcup-us.ahrq.gov/faststats/landing.jsp) based on the HCUP State Inpatient Databases (SID)

Figure 2. Patient location with the highest rate of opioid-related inpatient stays, by State, 2014. Map of the United States that shows for each state the patient location with the highest rate of opioid-related inpatient stays in 2014. Large central metropolitan: Oregon, Texas, Missouri, Illinois, Wisconsin, Indiana, Michigan, Ohio, Pennsylvania, New York, Rhode Island, Connecticut, Maryland, District of Columbia. Large fringe metropolitan: Washington, Utah, Kentucky. Medium metropolitan: Arizona, New Mexico, Nebraska, Kansas, Oklahoma, Louisiana, Arkansas, Iowa, Minnesota, West Virginia, Virginia, North Carolina, New Jersey. Small metropolitan: Nevada, Montana, Wyoming, Colorado, Tennessee, Georgia, Massachusetts, Maine, Hawaii. Rural: California, North Dakota, South Dakota, South Carolina, Florida.

Figure 3 Patient location with the highest rate^a^ a Opioid-related ED visit rates are per 100,000 population. State-level ED visit rates by patient location are provided in Appendix B. of opioid-related ED visits, by State, 2014

Abbreviation: ED, emergency department

Note: Asterisks denote States where the difference between the highest and second highest rates in the State was at least 10 percent.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), HCUP Fast Stats, Opioid-Related Hospital Use (www.hcup-us.ahrq.gov/faststats/landing.jsp) based on the HCUP State Emergency Department Databases (SEDD)

Figure 3. Patient location with the highest rate of opioid-related emergency department visits, by State, 2014. Map of the United States that shows for each state the patient location with the highest rate of opioid-related emergency department visits stays in 2014. Large central metropolitan: Wisconsin, Illinois, Indiana, Ohio, Massachusetts, Rhode Island, New Jersey, Maryland. Large fringe metropolitan: Utah, Missouri, Kentucky, Tennessee, Florida. Medium metropolitan: Arizona, Kansas, Minnesota, Iowa, New York, North Carolina. Small metropolitan: Nevada, South Dakota, Georgia, Vermont. Rural: California, North Dakota, Nebraska, Arkansas, South Carolina, Connecticut, Hawaii.

Appendix A State-level rates^a^ of opioid-related inpatient stays, by patient location and community-level income, 2014

State | Patient location | | | | | Income quartile
State | Large central metro | Large fringe metro | Medium metro | Small metro | Rural | 1 (lowest) | 2 | 3 | 4 (highest)
Arizona | 236.0 | 185.4 | 341.0 | 219.8 | 205.8 | 295.0 | 246.7 | 195.7 | 144.1
Arkansas | n/a | n/a | 149.7 | 136.0 | 130.6 | 148.2 | 132.8 | 113.7 | 111.2
California | 153.7 | 156.2 | 162.8 | 282.7 | 347.8 | 194.7 | 180.5 | 156.8 | 134.8
Colorado | 246.2 | 178.9 | 150.4 | 346.6 | 149.9 | 271.6 | 205.3 | 172.9 | 130.3
Connecticut | 387.4 | 337.0 | 322.8 | n/a | 265.3 | 713.8 | 489.5 | 380.4 | 211.6
District of Columbia | 317.8 | n/a | n/a | n/a | n/a | 562.8 | n/a | 426.6 | 267.5
Florida | 219.0 | 238.3 | 231.4 | 226.7 | 263.8 | 263.7 | 227.0 | 189.1 | 154.0
Georgia | 91.3 | 104.3 | 132.6 | 154.2 | 134.9 | 136.2 | 124.3 | 106.4 | 82.5
Hawaii | n/a | n/a | 125.0 | 209.8 | 151.6 | 172.4 | 195.0 | 149.0 | 112.3
Illinois | 518.1 | 161.5 | 201.3 | 145.4 | 141.3 | 758.8 | 233.0 | 208.1 | 148.9
Indiana | 269.1 | 184.7 | 167.5 | 181.8 | 195.9 | 267.3 | 194.4 | 158.5 | 112.8
Iowa | n/a | n/a | 77.5 | 66.7 | 70.4 | 105.9 | 76.3 | 68.6 | 55.9
Kansas | n/a | 91.4 | 129.4 | 100.3 | 90.4 | 148.5 | 96.2 | 107.8 | 65.4
Kentucky | 236.6 | 375.6 | 251.7 | 88.5 | 321.1 | 353.7 | 225.5 | 205.4 | 158.1
Louisiana | 130.1 | 170.5 | 182.0 | 128.9 | 127.0 | 139.0 | 148.5 | 176.2 | 181.7
Maine | n/a | n/a | 284.6 | 329.8 | 289.7 | 318.4 | 325.4 | 265.2 | 202.2
Maryland | 1,541.2 | 250.2 | 400.5 | 380.1 | 299.3 | 1,701.8 | 672.5 | 453.2 | 194.4
Massachusetts | 436.7 | 348.4 | 398.2 | 682.0 | 513.5 | 582.2 | 609.3 | 432.2 | 263.8
Michigan | 318.0 | 196.0 | 215.6 | 235.2 | 172.9 | 351.8 | 213.2 | 150.0 | 133.4
Minnesota | 319.5 | 247.6 | 345.7 | 140.9 | 179.4 | 556.2 | 254.9 | 239.1 | 191.5
Missouri | 345.3 | 261.8 | 303.1 | 167.9 | 233.9 | 362.2 | 225.0 | 224.2 | 154.4
Montana | n/a | n/a | n/a | 263.8 | 180.0 | 277.7 | 167.6 | 194.4 | 187.5
Nebraska | n/a | n/a | 81.7 | 52.2 | 75.6 | 109.1 | 87.8 | 68.3 | 58.2
Nevada | 156.2 | n/a | 187.0 | 410.7 | 211.5 | 228.8 | 166.7 | 135.1 | 117.9
New Jersey | 295.9 | 259.6 | 445.8 | 413.1 | n/a | 528.1 | 366.9 | 348.2 | 206.8
New Mexico | n/a | n/a | 265.3 | 161.6 | 185.5 | 256.9 | 188.0 | 158.1 | 126.6
New York | 377.2 | 292.4 | 286.2 | 258.1 | 303.1 | 495.5 | 244.7 | 260.9 | 258.0
North Carolina | 106.4 | 245.1 | 259.8 | 201.3 | 251.9 | 279.1 | 224.5 | 143.8 | 92.4
North Dakota | n/a | n/a | n/a | 151.6 | 165.1 | 253.1 | 167.1 | 158.5 | 117.3
Ohio | 349.8 | 263.6 | 289.6 | 349.2 | 227.1 | 431.6 | 269.8 | 224.7 | 150.5
Oklahoma | 140.6 | 111.6 | 203.9 | 109.9 | 146.8 | 178.0 | 144.0 | 136.2 | 101.7
Oregon | 501.1 | 256.1 | 320.2 | 245.2 | 207.4 | 359.4 | 313.7 | 268.6 | 203.4
Pennsylvania | 431.9 | 245.3 | 261.1 | 213.3 | 219.6 | 469.4 | 300.7 | 226.2 | 167.2
Rhode Island | 414.7 | 308.7 | n/a | n/a | n/a | 631.9 | 448.2 | 359.8 | 210.7
South Carolina | n/a | 103.9 | 132.8 | 166.7 | 176.3 | 163.2 | 147.1 | 95.7 | 63.5
South Dakota | n/a | n/a | n/a | 122.3 | 133.1 | 134.1 | 130.2 | 132.8 | 75.2
Tennessee | 178.5 | 253.7 | 257.4 | 335.9 | 288.6 | 288.3 | 267.3 | 185.4 | 102.2
Texas | 108.6 | 76.9 | 91.6 | 102.5 | 98.1 | 114.9 | 108.4 | 86.4 | 73.1
Utah | 237.3 | 249.1 | 195.7 | 162.5 | 145.9 | 260.1 | 221.0 | 200.3 | 155.8
Vermont | n/a | n/a | n/a | 190.2 | 206.5 | 158.4 | 257.3 | 198.4 | 120.1
Virginia | 153.5 | 141.8 | 243.0 | 215.0 | 201.8 | 303.6 | 216.6 | 178.2 | 105.8
Washington | 331.6 | 350.1 | 260.5 | 294.4 | 269.4 | 445.7 | 330.1 | 312.3 | 234.0
West Virginia | n/a | 265.9 | 387.2 | 346.7 | 337.1 | 349.2 | 330.8 | 286.7 | 194.0
Wisconsin | 370.7 | 179.0 | 165.8 | 188.2 | 185.4 | 301.4 | 229.6 | 174.3 | 159.6
Wyoming | n/a | n/a | n/a | 120.9 | 83.2 | n/a | 100.9 | 78.7 | 93.0

Abbreviations: metro, metropolitan; n/a, not available (the sample size was too small to calculate the rate)

a Opioid-related inpatient rates are per 100,000 population.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), HCUP Fast Stats, Opioid-Related Hospital Use (www.hcup-us.ahrq.gov/faststats/landing.jsp) based on the HCUP State Inpatient Databases (SID)

■ Across States, there was substantial variation in the patient location that had the highest opioid-related inpatient rate in 2014.
  In 2014, the highest rate of opioid-related inpatient stays was in urban areas in some States and in rural areas in other States. The highest rate was seen in—
  - Large central metropolitan areas for 13 States and the District of Columbia (with an average across these States of 446.5 per 100,000 population, data not shown)
  - Large fringe metropolitan areas for three States (average 324.9 per 100,000)
  - Medium metropolitan areas for 13 States (average 239.4 per 100,000)
  - Small metropolitan areas for nine States (average 317.1 per 100,000)
  - Rural areas for six States (average 215.4 per 100,000)

Figure 3 reports the patient location with the highest population rate of opioid-related ED visits for each of 30 States that provided data in 2014. Details on ED visit rates specific to patient location are shown in Appendix B.

Appendix B State-level rates^a^ of opioid-related ED visits, by patient location and community-level income, 2014

State | Patient location | | | | | Income quartile
State | Large central metro | Large fringe metro | Medium metro | Small metro | Rural | 1 (lowest) | 2 | 3 | 4 (highest)
Arizona | 189.7 | 124.3 | 358.4 | 203.6 | 168.6 | 263.0 | 221.0 | 154.6 | 111.2
Arkansas | n/a | n/a | 73.9 | 50.6 | 75.3 | 81.0 | 65.7 | 48.1 | 54.9
California | 130.9 | 133.7 | 189.4 | 282.5 | 341.0 | 178.5 | 171.4 | 152.3 | 114.0
Connecticut | 268.9 | 234.6 | 243.0 | n/a | 347.8 | 438.3 | 606.2 | 252.3 | 164.0
Florida | 97.4 | 111.7 | 111.6 | 101.1 | 107.6 | 123.3 | 104.6 | 83.3 | 72.7
Georgia | 80.2 | 96.4 | 87.8 | 100.9 | 99.9 | 95.0 | 96.2 | 96.8 | 84.9
Hawaii | n/a | n/a | 92.0 | 92.2 | 188.7 | 209.6 | 213.8 | 107.8 | 74.6
Illinois | 235.3 | 110.0 | 153.8 | 145.4 | 119.4 | 345.3 | 155.6 | 125.8 | 97.0
Indiana | 204.4 | 149.6 | 131.1 | 124.7 | 154.8 | 200.4 | 153.2 | 127.1 | 82.7
Iowa | n/a | n/a | 50.1 | 37.0 | 43.9 | 60.0 | 51.2 | 38.4 | 35.5
Kansas | n/a | 72.8 | 100.2 | 82.6 | 70.2 | 110.0 | 84.7 | 84.7 | 45.2
Kentucky | 278.3 | 494.7 | 202.8 | 58.7 | 141.9 | 234.3 | 195.0 | 212.3 | 203.0
Maryland | 993.1 | 195.1 | 453.7 | 281.1 | 256.9 | 1177.6 | 511.0 | 321.0 | 159.7
Massachusetts | 551.0 | 444.0 | 390.8 | 367.9 | 335.4 | 656.4 | 640.8 | 493.9 | 311.6
Minnesota | 167.4 | 116.8 | 292.1 | 62.9 | 115.1 | 400.6 | 154.2 | 113.9 | 87.6
Missouri | 257.0 | 176.3 | 157.2 | 123.0 | 125.5 | 242.8 | 141.0 | 141.1 | 96.8
Nebraska | n/a | n/a | 48.2 | 28.2 | 61.7 | 75.9 | 60.6 | 46.3 | 34.2
Nevada | 169.9 | n/a | 201.8 | 337.3 | 182.8 | 229.7 | 187.7 | 131.2 | 137.5
New Jersey | 298.5 | 173.0 | 285.4 | 280.7 | n/a | 544.9 | 251.2 | 241.3 | 135.8
New York | 176.7 | 175.7 | 226.1 | 179.5 | 171.5 | 291.9 | 161.0 | 149.4 | 150.9
North Carolina | 101.3 | 183.1 | 211.8 | 175.8 | 190.4 | 216.2 | 176.5 | 129.1 | 99.8
North Dakota | n/a | n/a | n/a | 82.6 | 109.3 | 116.5 | 92.7 | 108.5 | 84.6
Ohio | 316.7 | 290.3 | 303.1 | 300.5 | 219.8 | 405.5 | 271.6 | 234.5 | 153.8
Rhode Island | 305.0 | 267.9 | n/a | n/a | n/a | 400.0 | 348.9 | 293.4 | 205.8
South Carolina | n/a | 71.1 | 106.5 | 86.5 | 127.3 | 124.1 | 107.1 | 70.5 | 50.5
South Dakota | n/a | n/a | n/a | 68.2 | 55.3 | 84.0 | 69.4 | 51.6 | 49.6
Tennessee | 140.2 | 149.6 | 140.1 | 107.7 | 167.7 | 161.6 | 146.7 | 138.2 | 60.8
Utah | 236.8 | 252.8 | 131.0 | 141.1 | 119.1 | 233.0 | 194.5 | 165.6 | 120.9
Vermont | n/a | n/a | n/a | 245.9 | 204.0 | n/a | 310.8 | 184.9 | 142.9
Wisconsin | 232.6 | 215.0 | 118.2 | 129.9 | 122.6 | 232.9 | 160.9 | 129.5 | 120.7

Abbreviations: ED, emergency department; metro, metropolitan; n/a, not available (the sample size was too small to calculate the rate)

a Opioid-related ED visit rates are per 100,000 population.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), HCUP Fast Stats, Opioid-Related Hospital Use (www.hcup-us.ahrq.gov/faststats/landing.jsp) based on the HCUP State Emergency Department Databases (SEDD)

■ Across States, there was substantial variation in the patient location that had the highest opioid-related ED visit rate in 2014.
  In 2014, the highest rate of opioid-related ED visits was in urban areas in some States and in rural areas in other States. The highest rate was seen in—
  - Large central metropolitan areas for nine States (with an average across these States of 377.1 per 100,000 population, data not shown)
  - Large fringe metropolitan areas for three States (average 286.4 per 100,000)
  - Medium metropolitan areas for six States (average 206.4 per 100,000)
  - Small metropolitan areas for four States (average 188.0 per 100,000)
  - Rural areas for eight States (average 177.3 per 100,000)

### National rate of opioid-related inpatient stays and ED visits by community-level income, 2005–2014

Figure 4 presents 10-year trends in the national rate of opioid-related inpatient stays and ED visits by median community-level income group, from 2005 to 2014.

Figure 4 National rate of opioid-related inpatient stays and ED visits by community-level income, 2005–2014

Abbreviation: ED, emergency department

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), HCUP Fast Stats, Opioid-Related Hospital Use (www.hcup-us.ahrq.gov/faststats/landing.jsp) based on the HCUP National (Nationwide) Inpatient Sample (NIS) and the Nationwide Emergency Department Sample (NEDS)

Figure 4. National rate of opioid-related inpatient stays and ED visits by community-level income, 2005–2014. Two line graphs that show the rate of inpatient stays and emergency department visits per 100,000 population from 2005 to 2014 by community-level income. Inpatient stays: Income quartile 1(lowest): increased from 179.6 in 2005 to 223.8 in 2007, decreased to 198.4 in 2007, then increased steadily to 296.8 in 2014—65.2% cumulative increase. Income quartile 2: Increased from 125.5 in 2005 to 150.8 in 2006, decreased to 147.6 in 2007, increased steadily to 207.7 in 2011, small fluctuations between 201.4 in 2012 and 218.2 in 2014—73.8% cumulative increase. Income quartile 3: Increased steadily from 117.2 in 2005 to 192.8 in 2014—64.5% cumulative increase. Income quartile 4 (highest): Increased from 98.1 in 2005 to 119.0 in 2006, decreased to 113.8 in 2007, small fluctuations between 131.6 in 2008 and 132.2 in 2010, small fluctuations between 156.3 in 2011 and 157.8 in 2014—60.9% cumulative increase. Emergency department visits: income quartile 1 (lowest): Small fluctuations between 104.9 in 2005 and 109.0 in 2008, increased steadily from 130.1 in 2009 to 231.9 in 2014—121.1% cumulative increase. Income quartile 2: Increased from 90.2 in 2005 to 96.8 in 2006, decreased to 82.8 in 2007, increased steadily to 176.5 in 2014—95.6% cumulative increase. Income quartile 3: decreased steadily from 83.2 in 2005 to 73.7 in 2007, increased steadily to 149.9 in 2014—79.6% cumulative increase. Income quartile 4 (highest): Small fluctuations between 65.5 in 2005 and 56.5 in 2007, increased steadily from 67.4 in 2008 to 132.1 in 2014—101.8% cumulative increase.

■ There was a consistent relationship between community-level income and the rates of opioid-related inpatient stays and ED visits from 2005 to 2014: the higher the income level, the lower the rate of opioid-related utilization.
  For each year over the 10-year period examined, the rates of opioid-related inpatient stays and ED visits were highest in the lowest income group and lowest in the highest income group (e.g., in 2014, inpatient stays: 296.8 vs. 157.8 per 100,000 population, respectively; ED visits: 231.9 vs. 132.1 per 100,000, respectively).
■ The increase in the rate of opioid-related inpatient stays was similar across different levels of community income over the 10-year time period from 2005 to 2014.
  The rate of opioid-related inpatient stays increased between 61 and 74 percent across community-level income.
■ From 2005 to 2014, the rate of opioid-related ED visits increased the most in communities with the lowest income.
  The rate of opioid-related ED visits increased the most among patients in communities with the lowest income (a 121 percent increase from 2005 to 2014).
  For all levels of community income, the rate of opioid-related ED visits increased faster than the rate of opioid-related inpatient stays over the 10-year period.

### Community-level income with the highest rate of opioid-related inpatient stays and ED visits, by State, 2014

Figures 5 and 6 show the community-level income quartile with the highest population rate of opioid-related inpatient stays (Figure 5) and ED visits (Figure 6) within each State in 2014. The income quartile with the highest rate overall is reported for each State. States where the difference between the highest and second highest rates was 10 percent or greater are noted with an asterisk. Figure 5 reports the community-level income quartile with the highest population rate of opioid-related inpatient stays for each of 44 States and the District of Columbia that provided data in 2014. Details on the income-specific inpatient rates are shown in Appendix A.

Figure 5 Community-level income with the highest rate^a^ a Opioid-related inpatient rates are per 100,000 population. State-level inpatient rates by community-level income are provided in Appendix A. of opioid-related inpatient stays, by State, 2014

Note: Asterisks denote States where the difference between the highest and second highest rates in the State was at least 10 percent.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), HCUP Fast Stats, Opioid-Related Hospital Use (www.hcup-us.ahrq.gov/faststats/landing.jsp) based on the HCUP State Inpatient Databases (SID)

Figure 5. Community-level income with the highest rate of opioid-related inpatient stays, by State, 2014. Map of the United States that shows for each state the community-level income with the highest rate of opioid-related inpatient stays in 2014. Income quartile 1 (lowest): Washington, Oregon, California, Nevada, Montana, Utah, Arizona, Colorado, New Mexico, Texas, Oklahoma, Kansas, Nebraska, South Dakota, North Dakota, Minnesota, Iowa, Missouri, Arkansas, Wisconsin, Illinois, Michigan, Indiana, Kentucky, Tennessee, Ohio, West Virginia, Florida, Georgia, South Carolina, North Carolina, Virginia, District of Columbia, Maryland, Pennsylvania, New Jersey, New York, Connecticut, Rhode Island. Income quartile 2: Wyoming, Maine, Vermont, Massachusetts, Hawaii. Income quartile 3: none. Income quartile 4: Louisiana.

Figure 6 Community-level income with the highest rate^a^ a Opioid-related ED visit rates are per 100,000 population. State-level ED visit rates by community-level income are provided in Appendix B. of opioid-related ED visits, by State, 2014

Abbreviation: ED, emergency department

Note: Asterisks denote States where the difference between the highest and second highest rates in the State was at least 10 percent.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), HCUP Fast Stats, Opioid-Related Hospital Use (www.hcup-us.ahrq.gov/faststats/landing.jsp) based on the HCUP State Emergency Department Databases (SEDD)

Figure 6. Community-level income with the highest rate of opioid-related ED visits, by State, 2014. Map of the United States that shows for each state the community-level income with the highest rate of opioid-related emergency department visits stays in 2014. Income quartile 1 (lowest): California, Nevada, Utah, Arizona, North Dakota, South Dakota, Nebraska, Kansas, Minnesota, Iowa, Missouri, Arkansas, Wisconsin, Illinois, Indiana, Ohio, Kentucky, Tennessee, Florida, South Carolina, North Carolina, Maryland, New Jersey, New York, Rhode Island, Massachusetts. Income quartile 2: Vermont, Connecticut, Hawaii. Income quartile 3: Georgia. Income quartile 4 (highest): none.

■ For the vast majority of States, the 2014 opioid-related inpatient rate was highest among communities with the lowest income.
  In 2014, the rate of opioid-related inpatient stays was highest among patients residing in communities that were in the—
  - Lowest income quartile (quartile 1) for most States (38 States and the District of Columbia, with an average across these States of 360.3 per 100,000 population, data not shown)
  - Next lowest income quartile (quartile 2) for five States (average 297.6 per 100,000)
  - Highest income quartile (quartile 4) for one State–Louisiana (181.7 per 100,000)

Figure 6 reports the community-level income quartile with the highest population rate of opioid-related ED visits for each of 30 States that provided data in 2014. Details on the income-specific ED visit rates are shown in Appendix B.

■ For most States, the 2014 opioid-related ED visit rate was highest among the lowest income communities.
  In 2014, the rate of opioid-related ED visits was highest among patients residing in communities that were in the—
  - Lowest income quartile (quartile 1) for the majority of States (26 of 30 States, with an average across these States of 276.5 per 100,000 population, data not shown)
  - Next lowest income quartile (quartile 2) for three States (average 376.9 per 100,000)
  - Second highest income quartile (quartile 3) for one State–Georgia (96.8 per 100,000)

### State rankings in rate of opioid-related inpatient stays and ED visits by patient location and community-level income, 2014

Tables 1 and 2 present the relative State rankings in the rate of opioid-related inpatient stays (Table 1) and ED visits (Table 2) by patient location and community-level income in 2014. State rankings in each patient subgroup are reported based on four quartiles:

- Lowest rates, corresponding to the bottom 25 percent, noted with a partially filled circle (⊙)
- Highest rates, corresponding to the top 25 percent, noted with a solid circle (●)
- Neither the lowest nor highest rates, corresponding to the middle 50 percent, noted with a dash

Table 1 Ranking^a^ in State rates^b^ of opioid-related inpatient stays, by patient location and community-level income, 2014

State | Patient location | | | | | Income quartile
State | Large central metro | Large fringe metro | Medium metro | Small metro | Rural | 1 (lowest) | 2 | 3 | 4 (highest)
Arizona | – | – | ● | – | – | – | – | – | –
Arkansas | n/a | n/a | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | –
California | ⊙ | ⊙ | – | – | ● | – | – | – | –
Colorado | – | – | ⊙ | ● | – | – | – | – | –
Connecticut | ● | ● | ● | n/a | ● | ● | ● | ● | ●
District of Columbia | – | n/a | n/a | n/a | n/a | ● | n/a | ● | ●
Florida | – | – | – | – | – | – | – | – | –
Georgia | ⊙ | ⊙ | ⊙ | – | ⊙ | ⊙ | ⊙ | ⊙ | ⊙
Hawaii | n/a | n/a | ⊙ | – | – | ⊙ | – | – | –
Illinois | ● | ⊙ | – | – | ⊙ | ● | – | – | –
Indiana | – | – | – | – | – | – | – | – | –
Iowa | n/a | n/a | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | ⊙
Kansas | n/a | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | ⊙
Kentucky | – | ● | – | ⊙ | ● | – | – | – | –
Louisiana | ⊙ | – | – | ⊙ | ⊙ | ⊙ | ⊙ | – | –
Maine | n/a | n/a | – | ● | ● | – | ● | ● | ●
Maryland | ● | – | ● | ● | ● | ● | ● | ● | ●
Massachusetts | ● | ● | ● | ● | ● | ● | ● | ● | ●
Michigan | – | – | – | – | – | – | – | – | –
Minnesota | – | – | ● | – | – | ● | – | – | –
Missouri | – | – | ● | – | – | – | – | – | –
Montana | n/a | n/a | n/a | – | – | – | – | – | –
Nebraska | n/a | n/a | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | ⊙
Nevada | ⊙ | n/a | – | ● | – | – | – | ⊙ | –
New Jersey | – | – | ● | ● | n/a | ● | ● | ● | ●
New Mexico | n/a | n/a | – | – | – | – | – | – | –
New York | ● | ● | – | – | ● | ● | – | ● | ●
North Carolina | ⊙ | – | – | – | – | – | – | – | ⊙
North Dakota | n/a | n/a | n/a | – | – | – | – | – | –
Ohio | – | ● | – | ● | – | – | ● | – | –
Oklahoma | ⊙ | ⊙ | – | ⊙ | – | – | ⊙ | ⊙ | ⊙
Oregon | ● | – | ● | – | – | – | ● | ● | ●
Pennsylvania | ● | – | – | – | – | ● | ● | – | –
Rhode Island | ● | ● | n/a | n/a | n/a | ● | ● | ● | ●
South Carolina | n/a | ⊙ | ⊙ | – | – | ⊙ | ⊙ | ⊙ | ⊙
South Dakota | n/a | n/a | n/a | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | ⊙
Tennessee | – | – | – | ● | ● | – | – | – | ⊙
Texas | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | ⊙
Utah | – | – | – | – | – | – | – | – | –
Vermont | n/a | n/a | n/a | – | – | ⊙ | – | – | –
Virginia | ⊙ | ⊙ | – | – | – | – | – | – | –
Washington | – | ● | – | ● | ● | ● | ● | ● | ●
West Virginia | n/a | ● | ● | ● | ● | – | ● | ● | ●
Wisconsin | – | – | – | – | – | – | – | – | –
Wyoming | n/a | n/a | n/a | ⊙ | ⊙ | n/a | ⊙ | ⊙ | ⊙

Key:

● States with the highest opioid-related inpatient rates (top 25 percent) in the patient subgroup

– States with opioid-related inpatient rates in the middle 50 percent in the patient subgroup

⊙ States with the lowest opioid-related inpatient rates (bottom 25 percent) in the patient subgroup

Abbreviations: metro, metropolitan; n/a, not available (the sample size was too small to calculate the rate)

a The number of States represented in the top and bottom 25 percent of a specific patient subgroup were calculated on the basis of the total number of States with a rate available for that subgroup (i.e., excluding States for which a rate was not available).

b Opioid-related inpatient rates are per 100,000 population. The actual inpatient rates for each patient location and income quartile by State are provided in Appendix A.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), HCUP Fast Stats, Opioid-Related Hospital Use (www.hcup-us.ahrq.gov/faststats/landing.jsp) based on the HCUP State Inpatient Databases (SID)

Table 2 Ranking^a^ in State rates^b^ of opioid-related ED visits, by patient location and community-level income, 2014

State | Patient location | | | | | Income quartile
State | Large central metro | Large fringe metro | Medium metro | Small metro | Rural | 1 (lowest) | 2 | 3 | 4 (highest)
Arizona | – | – | ● | – | – | – | – | – | –
Arkansas | n/a | n/a | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | ⊙
California | ⊙ | – | – | ● | ● | – | – | – | –
Connecticut | – | – | – | n/a | ● | ● | ● | ● | ●
Florida | ⊙ | ⊙ | – | – | ⊙ | – | – | ⊙ | –
Georgia | ⊙ | ⊙ | ⊙ | – | ⊙ | ⊙ | ⊙ | – | –
Hawaii | n/a | n/a | ⊙ | – | – | – | – | – | –
Illinois | – | ⊙ | – | – | – | – | – | – | –
Indiana | – | – | – | – | – | – | – | – | –
Iowa | n/a | n/a | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | ⊙
Kansas | n/a | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | ⊙
Kentucky | – | ● | – | ⊙ | – | – | – | ● | ●
Maryland | ● | – | ● | ● | ● | ● | ● | ● | ●
Massachusetts | ● | ● | ● | ● | ● | ● | ● | ● | ●
Minnesota | – | – | ● | ⊙ | – | ● | – | – | –
Missouri | – | – | – | – | – | – | – | – | –
Nebraska | n/a | n/a | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | ⊙
Nevada | – | n/a | – | ● | – | – | – | – | –
New Jersey | ● | – | ● | ● | n/a | ● | ● | ● | –
New York | – | – | – | – | – | – | – | – | ●
North Carolina | ⊙ | – | – | – | ● | – | – | – | –
North Dakota | n/a | n/a | n/a | – | – | ⊙ | ⊙ | – | –
Ohio | ● | ● | ● | ● | ● | ● | ● | ● | ●
Rhode Island | ● | ● | n/a | n/a | n/a | ● | ● | ● | ●
South Carolina | n/a | ⊙ | – | – | – | – | – | ⊙ | ⊙
South Dakota | n/a | n/a | n/a | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | ⊙
Tennessee | ⊙ | – | – | – | – | – | – | – | ⊙
Utah | – | ● | – | – | – | – | – | – | –
Vermont | n/a | n/a | n/a | ● | ● | n/a | ● | – | –
Wisconsin | – | – | – | – | – | – | – | – | –

Key:

● States with the highest opioid-related ED visit rates (top 25 percent) in the patient subgroup

– States with opioid-related ED visit rates in the middle 50 percent in the patient subgroup

⊙ States with the lowest opioid-related ED visit rates (bottom 25 percent) in the patient subgroup

Abbreviations: ED, emergency department; metro, metropolitan; n/a, not available (the sample size was too small to calculate the rate)

a The number of States represented in the top and bottom 25 percent of a specific patient subgroup were calculated on the basis of the total number of States with a rate available for that subgroup (i.e., excluding States for which a rate was not available).

b Opioid-related ED visit rates are per 100,000 population. The actual ED visit rates for each patient location and income quartile by State are provided in Appendix B.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), HCUP Fast Stats, Opioid-Related Hospital Use (www.hcup-us.ahrq.gov/faststats/landing.jsp) based on the HCUP State Emergency Department Databases (SEDD)

Table 1 reports the relative rankings in rates of opioid-related inpatient stays for each of 44 States and the District of Columbia that provided data in 2014.

■ Some States consistently ranked lowest or highest in rates of opioid-related inpatient stays in all patient location and income groups in 2014.
  Six States were consistently ranked as having among the lowest rates of opioid-related inpatient stays across all patient location and income groups: Iowa, Kansas, Nebraska, South Dakota, Texas, and Wyoming. Similarly, Arkansas and Georgia ranked among the States with the lowest rates in all but one location or income group.
  Three States consistently ranked as having among the highest rates of opioid-related inpatient stays across all patient location and income groups: Connecticut, Massachusetts, and Rhode Island. The District of Columbia, Maryland, and West Virginia ranked among the States with the highest rates in all but one location or income group.
■ Some States ranked lowest for opioid-related inpatient stays for some patient location and income groups but highest for other patient location and income groups.
  Many States ranked highest or lowest for rates of opioid-related inpatient stays for select patient location and income groups, with some States having a mix of both the highest and lowest rates, depending on the group. For instance, California had among the lowest rates of opioid-related inpatient stays for patients living in large central and large fringe metropolitan areas but had among the highest rates for patients living in rural areas.

Table 2 reports the relative rankings in rates of opioid-related ED visits for each of 30 States that provided data in 2014.

■ Some States consistently ranked lowest or highest in rates of opioid-related ED visits in all patient location and income groups in 2014.
  Five States were consistently ranked as having among the lowest rates of opioid-related ED visits across all patient location and income groups: Arkansas, Iowa, Kansas, Nebraska, and South Dakota.
  Three States consistently ranked as having among the highest rates of opioid-related ED visits across all patient location and income groups: Massachusetts, Ohio, and Rhode Island. Maryland ranked among the States with the highest rates in all but one location or income group.
■ Some States ranked lowest in rates of opioid-related ED visits for some patient location and income groups but highest for other patient location and income groups.
  Many States ranked highest or lowest for rates of opioid-related ED visits for select patient location and income groups, with some States having a mix of both the highest and lowest rates, depending on the group. For instance, North Carolina had among the lowest rates of opioid-related ED visits for patients living in large central metropolitan areas but had among the highest rates for patients living in rural areas.

## Data Source

The estimates in this Statistical Brief are based upon data from the Healthcare Cost and Utilization Project (HCUP) 2005–2014 National (Nationwide) Inpatient Sample (NIS), 2005–2014 Nationwide Emergency Department Sample (NEDS), 2014 State Inpatient Databases (SID), and 2014 State Emergency Department Databases (SEDD). The statistics were generated from HCUP Fast Stats, a free, online tool that provides users with easy access to the latest HCUP-based statistics for health information topics, including opioid-related hospital use.^4^

Inpatient statistics from HCUP Fast Stats were available for the following 44 individual States and the District of Columbia in 2014: Arizona, Arkansas, California, Colorado, Connecticut, District of Columbia, Florida, Georgia, Hawaii, Illinois, Indiana, Iowa, Kansas, Kentucky, Louisiana, Maine, Maryland, Massachusetts, Michigan, Minnesota, Missouri, Montana, Nebraska, Nevada, New Jersey, New Mexico, New York, North Carolina, North Dakota, Ohio, Oklahoma, Oregon, Pennsylvania, Rhode Island, South Carolina, South Dakota, Tennessee, Texas, Utah, Vermont, Virginia, Washington, West Virginia, Wisconsin, and Wyoming.

Emergency department (ED) statistics from HCUP Fast Stats were available for the following 30 individual States in 2014: Arizona, Arkansas, California, Connecticut, Florida, Georgia, Hawaii, Illinois, Indiana, Iowa, Kansas, Kentucky, Maryland, Massachusetts, Minnesota, Missouri, Nebraska, Nevada, New Jersey, New York, North Carolina, North Dakota, Ohio, Rhode Island, South Carolina, South Dakota, Tennessee, Utah, Vermont, and Wisconsin.

Rates are presented in HCUP Fast Stats using population data obtained from Claritas, a vendor that compiles and adds value to data from the U.S. Census Bureau.^5^

## Definitions

### Diagnoses and ICD-9-CM

The principal diagnosis is that condition established after study to be chiefly responsible for the patient’s admission to the hospital. Secondary diagnoses are concomitant conditions that coexist at the time of admission or develop during the stay. All-listed diagnoses include the principal diagnosis plus these additional secondary conditions.

ICD-9-CM is the International Classification of Diseases, Ninth Revision, Clinical Modification, which assigns numeric codes to diagnoses. There are approximately 14,000 ICD-9-CM diagnosis codes.

### Case definition

Opioid-related hospital use was identified using the following all-listed ICD-9-CM diagnosis codes:

- 304.00–304.02: Opioid type dependence (unspecified; continuous; episodic)
- 304.70–304.72: Combinations of opioid type drug with any other drug dependence (unspecified; continuous; episodic)
- 305.50–305.52: Opioid abuse (unspecified; continuous; episodic)
- 965.00–965.02; 965.09: Poisoning by opium (alkaloids), unspecified; heroin; methadone; other opiates and related narcotics
- 970.1: Poisoning by opiate antagonists
- E850.0–E850.2: Accidental poisoning by heroin; methadone; other opiates and related narcotics
- E935.0–E935.2: Heroin, methadone, other opiates and related narcotics causing adverse effects in therapeutic use
- E940.1: Opiate antagonists causing adverse effects in therapeutic use

It should be noted that ICD-9-CM diagnosis codes related to opioid dependence or abuse “in remission” were not used to identify opioid-related hospital use because remission does not indicate active use of opioids. Potential changes in the use of ICD-9-CM codes identifying opioid use cannot be isolated in these analyses.

These codes include opioid-related use stemming from illicit opioids such as heroin, illegal use of prescription opioids, and the use of opioids as prescribed. Each type of opioid use is important for understanding and addressing the opioid epidemic in the United States.^6^ While there may be interest in examining how much each type of opioid use contributes to the overall opioid problem, many of the opioid-related codes under the ICD-9-CM clinical coding system do not allow heroin-related cases to be explicitly identified (e.g., in the 304.0x series, heroin is not distinguished from other opioids). In addition, the codes do not distinguish between illegal use of prescription drugs and their use as prescribed.

### Types of hospitals included in the HCUP National (Nationwide) Inpatient Sample

The National (Nationwide) Inpatient Sample (NIS) is based on data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). The NIS includes obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded are long-term care facilities such as rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. Beginning in 2012, long-term acute care hospitals are also excluded. However, if a patient received long-term care, rehabilitation, or treatment for a psychiatric or chemical dependency condition in a community hospital, the discharge record for that stay will be included in the NIS.

### Types of hospitals included in the HCUP Nationwide Emergency Department Sample

The Nationwide Emergency Department Sample (NEDS) is based on data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). The NEDS includes specialty, pediatric, public, and academic medical hospitals. Excluded are long-term care facilities such as rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. Hospitals included in the NEDS have hospital-owned emergency departments (EDs) and no more than 90 percent of their ED visits resulting in admission.

### Types of hospitals included in HCUP State Inpatient Databases

This analysis used State Inpatient Databases (SID) limited to data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). Community hospitals include obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded for this analysis are long-term care facilities such as rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. However, if a patient received long-term care, rehabilitation, or treatment for a psychiatric or chemical dependency condition in a community hospital, the discharge record for that stay was included in the analysis.

### Types of hospitals included in HCUP State Emergency Department Databases

This analysis used State Emergency Department Databases (SEDD) limited to data from community hospitals with a hospital-owned emergency department. Community hospitals are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). Community hospitals include specialty, pediatric, public, and academic medical hospitals. Excluded for this analysis are long-term care facilities such as rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals.

### Unit of analysis

The unit of analysis for inpatient data is the hospital discharge (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the hospital multiple times in 1 year will be counted each time as a separate discharge from the hospital. Inpatient stays include those for patients admitted through the emergency department (ED). Patients transferred between inpatient hospitals are counted only once.

The unit of analysis for ED data is the ED visit, not a person or patient. This means that a person who is seen in the ED multiple times in 1 year will be counted each time as a separate visit in the ED. ED visits exclude those for patients admitted to the same hospital and also exclude patients transferred to another hospital.

### Location of patients’ residence

Place of residence is based on the urban-rural classification scheme for U.S. counties developed by the National Center for Health Statistics (NCHS):

- Large Central Metropolitan: Central counties of metropolitan areas with 1 million or more residents
- Large Fringe Metropolitan: Fringe counties of metropolitan areas with 1 million or more residents
- Medium Metropolitan: Counties in metropolitan areas of 250,000–999,999 residents
- Small Metropolitan: Counties in metropolitan areas of 50,000–249,999 residents
- Micropolitan: Nonmetropolitan counties areas of 10,000 or more residents
- Noncore: Nonmetropolitan and nonmicropolitan counties

For this Statistical Brief, we collapsed the NCHS categories of Micropolitan and Noncore into a single Rural category.

### Community-level income

Community-level income is based on the median household income of the patient’s ZIP Code of residence. Quartiles are defined so that the total U.S. population is evenly distributed. Cut-offs for the quartiles are determined annually using ZIP Code demographic data obtained from Claritas, a vendor that adds value to data from the U.S. Census Bureau.^7^ The value ranges for the income quartiles vary by year. The income quartile is missing for patients who are homeless or foreign.

## For More Information

For other information on mental health and substance abuse, including opioids, refer to the HCUP Statistical Briefs located at www.hcup-us.ahrq.gov/reports/statbriefs/sb_mhsa.jsp.

For additional HCUP statistics, visit:

- HCUP Fast Stats at www.hcup-us.ahrq.gov/faststats/landing.jsp for easy access to the latest HCUP-based statistics for health information topics
- HCUPnet, HCUP’s interactive query system, at www.hcupnet.ahrq.gov/

For more information about HCUP, visit www.hcup-us.ahrq.gov/.

For a detailed description of HCUP and more information on the design of the National (Nationwide) Inpatient Sample (NIS), Nationwide Emergency Department Sample (NEDS), State Inpatient Databases (SID), or State Emergency Department Databases (SEDD), please refer to the following database documentation:

Agency for Healthcare Research and Quality. Overview of the National (Nationwide) Inpatient Sample (NIS). Healthcare Cost and Utilization Project (HCUP). Rockville, MD: Agency for Healthcare Research and Quality. Updated December 2016. www.hcup-us.ahrq.gov/nisoverview.jsp. Accessed January 31, 2017.

Agency for Healthcare Research and Quality. Overview of the Nationwide Emergency Department Sample (NEDS). Healthcare Cost and Utilization Project (HCUP). Rockville, MD: Agency for Healthcare Research and Quality. Updated December 2016. www.hcup-us.ahrq.gov/nedsoverview.jsp. Accessed January 31, 2017.

Agency for Healthcare Research and Quality. Overview of the State Inpatient Databases (SID). Healthcare Cost and Utilization Project (HCUP). Rockville, MD: Agency for Healthcare Research and Quality. Updated June 2016. www.hcup-us.ahrq.gov/sidoverview.jsp. Accessed January 31, 2017.

Agency for Healthcare Research and Quality. Overview of the State Emergency Department Databases (SEDD). Healthcare Cost and Utilization Project (HCUP). Rockville, MD: Agency for Healthcare Research and Quality. Updated June 2016. www.hcup-us.ahrq.gov/seddoverview.jsp. Accessed January 31, 2017.

1 Weiss AJ, Elixhauser A, Barrett ML, Steiner CA, Bailey MK, O’Malley L. Opioid-Related Inpatient Stays and Emergency Department Visits by State, 2009–2014. HCUP Statistical Brief #219. December 2016. Agency for Healthcare Research and Quality, Rockville, MD. www.hcup-us.ahrq.gov/reports/statbriefs/sb219-Opioid-Hospital-Stays-ED-Visits-by-State.pdf. Accessed February 9, 2017.

2 Weiss AJ, Bailey MK, O’Malley L, Barrett ML, Elixhauser A, Steiner CA. Patient Characteristics of Opioid-Related Inpatient Stays and Emergency Department Visits Nationally and by State, 2014. HCUP Statistical Brief #224. June 2017. Agency for Healthcare Research and Quality, Rockville, MD. www.hcup-us.ahrq.gov/reports/statbriefs/sb224-Patient-Characteristics-Opioid-Hospital-Stays-ED-Visits-by-State.pdf. Accessed June 23, 2017.

3 Agency for Healthcare Research and Quality. HCUP Fast Stats Web site, Opioid-Related Hospital Use path. www.hcup-us.ahrq.gov/faststats/landing.jsp. Accessed March 6, 2017.

4 Agency for Healthcare Research and Quality. HCUP Fast Stats Web site, Opioid-Related Hospital Use path. www.hcup-us.ahrq.gov/faststats/landing.jsp. Accessed January 26, 2017.

5 Claritas. Claritas Demographic Profile. www.claritas.com. Accessed June 23, 2017.

6 Compton WM, Jones CM, Baldwin GT. Relationship between nonmedical prescription-opioid use and heroin use. The New England Journal of Medicine. 2016;374:154–63.26760086

7 Claritas. Claritas Demographic Profile. www.claritas.com. Accessed June 23, 2017.