# Statistical Brief #224 Patient Characteristics of Opioid-Related Inpatient Stays and Emergency Department Visits Nationally and by State, 2014

## Introduction

Between 2005 and 2014 there was a dramatic increase nationally in hospitalizations involving opioids: the rate of opioid-related inpatient stays increased 64 percent, and the rate of opioid-related emergency department (ED) visits nearly doubled.^1^ In a series of Statistical Briefs, the Agency for Healthcare Research and Quality (AHRQ) is providing descriptive information on opioid-related hospitalizations nationally and at the State level, based on data from the Healthcare Cost and Utilization Project (HCUP) Fast Stats online tool.^2^ In a previous Statistical Brief, AHRQ reported that across States in 2014 the rate of opioid-related inpatient stays varied more than five-fold and the rate of opioid-related ED visits varied more than ten-fold.^3^ Rates were reported for each State at the overall State level.

This HCUP Statistical Brief extends the previous report by presenting data from HCUP Fast Stats on the rate of opioid-related hospital inpatient stays and ED visits by patient sex and age group from 2005 to 2014. The patient sex and age groups with the highest opioid-related inpatient stay rates are presented for each of 44 States and the District of Columbia that provided inpatient data in 2014. Similarly, the patient sex and age groups with the highest opioid-related ED visit rates are presented for each of 30 States that provided ED visit data in 2014. Finally, States are ranked overall on the rates of opioid-related inpatient stays and ED visits by patient sex and age group in 2014. Identification of opioid-related stays and visits is based on all-listed diagnoses and includes events associated with prescription opioids or illicit opioids such as heroin. The population denominator specific to each sex or age group was used to calculate rates.

## Findings

Highlights

■ Between 2005 and 2014, opioid-related inpatient stays and ED visits increased for both sexes and all age groups.
■ During this timeframe, the national rate of opioid-related inpatient stays increased more for females than for males. Although the rate for males was higher in 2005, by 2014 the rate was the same for both sexes. In contrast, the increase in the rate of opioid-related ED visits was similar for males and females, with males always having the higher rate.
■ In most States in 2014, females had a higher rate of opioid-related inpatient stays than males but males had a higher rate of opioid-related ED visits than females.
■ From 2005 to 2014, the highest rates of opioid-related inpatient stays nationally were among patients aged 25–44 and 45–64 years. The highest rate of opioid-related ED visits was among those aged 25–44 years.
■ In 2014, there was substantial State-to-State variation in the age group with the highest rate of opioid-related inpatient stays, but patients aged 25–44 years had the highest opioid-related ED visit rate in all States.
■ Across all patient sex and age groups in 2014:
  ■ Opioid-related inpatient stays were lowest in Iowa, Nebraska, Texas, and Wyoming and highest in Massachusetts.
  ■ Opioid-related ED visits were lowest in Arkansas and Iowa and highest in Maryland.

### National rate of opioid-related inpatient stays and ED visits by patient sex, 2005–2014

Figure 1 presents the 10-year trends in the national rate of opioid-related inpatient stays and ED visits by patient sex, from 2005 to 2014.

Figure 1 National rate of opioid-related inpatient stays and ED visits by patient sex, 2005–2014

Abbreviation: ED, emergency department

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), HCUP Fast Stats, Opioid-Related Hospital Use (www.hcup-us.ahrq.gov/faststats/landing.jsp) based on the HCUP National (Nationwide) Inpatient Sample (NIS) and the Nationwide Emergency Department Sample (NEDS)

Figure 1. National rate of opioid-related inpatient stays and ED visits by patient sex, 2005–2014. Two line graphs that show the national rate of opioid-related inpatient stays and ED visits per 100,000 population from 2005 to 2014 by patient sex. Inpatient stays: male: Increased from 145.6 in 2005 to 178.2 in 2006, decreased to 167.5 in 2007, and then increased steadily to 225.0 in 2014; cumulative increase, 54.5%. Female: Increased from 127.8 in 2005 to 150.5 in 2006, decreased to 150.2 in 2007, and then increased steadily to 224.1 in 2014; cumulative increase, 75.3%. ED visits: male: Increased from 99.9 in 2005 to 102.9 in 2006, decreased to 91.9 in 2007, and then increased steadily to 202.8 in 2014; cumulative increase, 103.1%. Female: Increased from 78.6 in 2005 to 81.0 in 2006, decreased to 73.6 in 2007, and then increased steadily to 153.2 in 2014; cumulative increase, 94.8%.

■ From 2005 to 2014, the rate of opioid-related inpatient stays increased faster for females than for males. By 2014, the rate was virtually the same for both sexes.
  In 2005, males had a higher rate of opioid-related inpatient stays than did females (145.6 vs. 127.8 per 100,000 population). Between 2005 and 2014, the rate of opioid-related inpatient stays increased 55 percent for males and 75 percent for females. By 2014, the rates of opioid-related inpatient stays for males and for females converged and were virtually identical (225.0 vs. 224.1 per 100,000 population).
■ The increase in the opioid-related ED visit rate was similar for both sexes, with males consistently experiencing a higher ED visit rate than females.
  In 2005, males had a higher rate of opioid-related ED visits than did females (99.9 vs. 78.6 per 100,000 population). Between 2005 and 2014, the rate of opioid-related ED visits approximately doubled for both sexes (males: 103 percent increase; females: 95 percent increase). In 2014, males still had a higher rate of opioid-related ED visits than did females (202.8 vs. 153.2 per 100,000 population).
■ For both sexes, the opioid-related ED visit rate increased faster over the 10 years than the opioid-related inpatient stay rate.
  Between 2005 and 2014, the rate of opioid-related ED visits increased faster than the rate of opioid-related inpatient stays for both males (103 vs. 55 percent increase) and females (95 vs. 75 percent increase).

### Patient sex with the higher rate of opioid-related inpatient stays and ED visits, by State, 2014

Figures 2 and 3 identify the patient sex with the higher rate of opioid-related inpatient stays (Figure 2) and ED visits (Figure 3) in each State in 2014. The sex with the higher rate overall is reported for each State. States where the difference between the male and female rates was 10 percent or greater are noted with an asterisk.

Figure 2 Patient sex with the higher rate^a^ a Opioid-related inpatient rates are per 100,000 population. State-level inpatient rates by sex are provided in Appendix A. of opioid-related inpatient stays, by State, 2014

Note: Asterisks denote States where the difference between the higher and lower of the male and female rates was at least 10 percent.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), HCUP Fast Stats, Opioid-Related Hospital Use (www.hcup-us.ahrq.gov/faststats/landing.jsp) based on the HCUP State Inpatient Databases (SID)

Figure 2. Patient sex with the higher rate of opioid-related inpatient stays, by State, 2014. U.S. map that depicts for participating States which sex had the higher rate of opioid-related inpatient stays in 2014. Higher male rate of opioid-related inpatient stays: California, Louisiana, Illinois, New York, Massachusetts, Rhode Island, Connecticut, Pennsylvania, New Jersey, Maryland, District of Columbia, Hawaii. Higher female rate of opioid-related inpatient stays: Washington, Oregon, Nevada, Utah, Arizona, New Mexico, Colorado, Wyoming, Montana, North Dakota, South Dakota, Nebraska, Kansas, Oklahoma, Texas, Arkansas, Missouri, Iowa, Minnesota, Wisconsin, Michigan, Indiana, Ohio, Kentucky, Tennessee, West Virginia, Virginia, North Carolina, South Carolina, Georgia, Florida, Vermont, Maine.

Figure 3 Patient sex with the higher rate^a^ a Opioid-related ED visit rates are per 100,000 population. State-level ED visit rates by sex are provided in Appendix B. of opioid-related ED visits, by State, 2014

Abbreviation: ED, emergency department

Note: Asterisks denote States where the difference between the higher and lower of the male and female rates was at least 10 percent.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), HCUP Fast Stats, Opioid-Related Hospital Use (www.hcup-us.ahrq.gov/faststats/landing.jsp) based on the HCUP State Emergency Department Databases (SEDD)

Figure 3. Patient sex with the higher rate of opioid-related ED visits, by State, 2014. U.S. map that depicts for participating States which sex had the higher rate of opioid-related ED visits in 2014. Higher male rate of opioid-related ED visits: California, Nevada, Utah, Arizona, Minnesota, Missouri, Wisconsin, Illinois, Indiana, Kentucky, Ohio, Florida, Georgia, South Carolina, North Carolina, Maryland, New Jersey, New York, Connecticut, Rhode Island, Massachusetts, Vermont, Hawaii. Higher female rate of opioid-related ED visits: North Dakota, South Dakota, Nebraska, Kansas, Iowa, Arkansas, Tennessee.

Figure 2 reports the patient sex with the higher population rate of opioid-related inpatient stays for each of 44 States and the District of Columbia that provided inpatient data in 2014. Details on the sex-specific inpatient rates are shown in Appendix A.

Appendix A State-level rates^a^ of opioid-related inpatient stays, by patient sex and age group, 2014

State | Males | Females | Ages 1–24 years | Ages 25–44 years | Ages 45–64 years | Ages 65+ years
Arizona | 229.7 | 264.1 | 65.9 | 275.8 | 399.0 | 371.2
Arkansas | 118.0 | 159.8 | 37.9 | 206.0 | 194.2 | 160.9
California | 168.8 | 167.9 | 40.4 | 159.3 | 286.1 | 303.1
Colorado | 166.0 | 206.4 | 58.5 | 192.4 | 263.6 | 353.7
Connecticut | 377.3 | 299.8 | 78.3 | 490.3 | 515.5 | 297.3
District of Columbia | 472.0 | 312.8 | 62.2 | 186.3 | 1138.8 | 330.8
Florida | 219.8 | 249.3 | 67.1 | 335.9 | 331.7 | 232.6
Georgia | 104.5 | 133.9 | 27.1 | 135.4 | 185.9 | 214.4
Hawaii | 163.6 | 119.3 | 36.7 | 163.1 | 233.4 | 161.8
Illinois | 349.2 | 265.4 | 54.6 | 365.7 | 598.7 | 249.6
Indiana | 176.7 | 216.4 | 63.5 | 320.9 | 240.1 | 226.3
Iowa | 63.0 | 82.3 | 20.1 | 75.8 | 95.3 | 143.8
Kansas | 87.2 | 121.2 | 23.9 | 127.5 | 148.9 | 185.9
Kentucky | 255.8 | 304.2 | 112.4 | 561.4 | 280.3 | 175.1
Louisiana | 155.7 | 155.1 | 52.9 | 287.3 | 176.2 | 132.5
Maine | 273.6 | 326.3 | 115.6 | 620.4 | 254.7 | 274.8
Maryland | 442.7 | 367.2 | 100.8 | 592.2 | 640.7 | 284.7
Massachusetts | 433.4 | 356.3 | 132.3 | 689.0 | 466.8 | 307.6
Michigan | 222.3 | 236.6 | 61.1 | 330.6 | 336.6 | 239.3
Minnesota | 228.2 | 266.0 | 106.1 | 325.4 | 309.1 | 324.2
Missouri | 259.8 | 263.0 | 92.0 | 461.8 | 298.7 | 243.8
Montana | 163.4 | 264.2 | 50.2 | 269.3 | 273.6 | 351.9
Nebraska | 63.4 | 93.5 | 26.6 | 85.6 | 105.4 | 145.7
Nevada | 150.1 | 198.5 | 51.2 | 185.7 | 272.4 | 267.5
New Jersey | 327.3 | 251.9 | 97.7 | 470.3 | 398.5 | 182.6
New Mexico | 205.4 | 225.2 | 83.6 | 340.7 | 266.7 | 219.9
New York | 467.1 | 260.2 | 118.7 | 533.0 | 555.7 | 213.9
North Carolina | 198.8 | 240.0 | 78.4 | 333.6 | 273.1 | 247.8
North Dakota | 133.4 | 190.4 | 55.2 | 231.3 | 184.1 | 244.7
Ohio | 276.6 | 306.7 | 109.8 | 565.4 | 314.6 | 209.9
Oklahoma | 122.9 | 186.7 | 45.9 | 199.4 | 224.2 | 221.2
Oregon | 266.9 | 346.4 | 62.8 | 296.9 | 435.6 | 599.9
Pennsylvania | 299.8 | 271.0 | 94.6 | 506.5 | 339.0 | 237.1
Rhode Island | 421.8 | 335.8 | 86.9 | 623.6 | 540.1 | 281.2
South Carolina | 123.8 | 158.3 | 37.5 | 200.7 | 191.9 | 182.1
South Dakota | 108.6 | 148.2 | 45.5 | 163.8 | 154.8 | 218.4
Tennessee | 222.9 | 279.2 | 83.7 | 372.7 | 336.4 | 261.3
Texas | 90.9 | 106.1 | 29.5 | 115.5 | 147.2 | 178.2
Utah | 189.7 | 219.3 | 69.9 | 325.0 | 288.4 | 270.6
Vermont | 147.6 | 257.4 | 95.3 | 449.0 | 147.4 | 170.4
Virginia | 156.2 | 176.5 | 55.8 | 238.6 | 211.3 | 206.5
Washington | 279.1 | 347.2 | 102.2 | 368.9 | 416.9 | 505.4
West Virginia | 326.7 | 371.2 | 168.5 | 739.9 | 320.9 | 177.6
Wisconsin | 187.1 | 238.2 | 73.8 | 294.0 | 247.1 | 324.5
Wyoming | 74.0 | 118.1 | 24.4 | 142.5 | 125.8 | 133.9

a Opioid-related inpatient rates are per 100,000 population.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), HCUP Fast Stats, Opioid-Related Hospital Use (www.hcup-us.ahrq.gov/faststats/landing.jsp) based on the HCUP State Inpatient Databases (SID)

■ In 2014, females had a higher rate of opioid-related inpatient stays than did males in the majority of States.
  In 2014, the rate of opioid-related inpatient stays was higher among—
  - Females in nearly three-fourths of States (33 of 45 States, with an average across these States of 221.2 per 100,000 population, data not shown)
  - Males in 11 States and the District of Columbia (average 339.9 per 100,000 population)
  The average rate for both sexes was higher in States where males had a higher rate than females.

Figure 3 reports the patient sex with the higher population rate of opioid-related ED visits for each of 30 States that provided ED data in 2014. Details on the sex-specific ED visit rates are shown in Appendix B.

Appendix B State-level rates^a^ of opioid-related ED visits, by patient sex and age group, 2014

State | Males | Females | Ages 1–24 years | Ages 25–44 years | Ages 45–64 years | Ages 65+ years
Arizona | 224.4 | 205.4 | 128.5 | 358.1 | 255.0 | 112.6
Arkansas | 63.3 | 79.6 | 35.3 | 130.1 | 81.6 | 41.5
California | 169.0 | 144.0 | 74.3 | 228.6 | 214.9 | 110.9
Connecticut | 323.7 | 188.9 | 157.2 | 549.1 | 231.1 | 47.2
Florida | 110.5 | 107.8 | 59.7 | 220.3 | 111.7 | 41.2
Georgia | 96.3 | 94.5 | 48.4 | 166.1 | 101.6 | 64.9
Hawaii | 130.9 | 93.5 | 46.8 | 179.1 | 158.4 | 56.9
Illinois | 204.4 | 135.0 | 70.5 | 272.9 | 248.9 | 62.0
Indiana | 159.6 | 145.1 | 95.6 | 316.4 | 124.4 | 61.1
Iowa | 37.0 | 53.1 | 22.4 | 69.2 | 51.4 | 47.9
Kansas | 70.7 | 91.4 | 36.0 | 147.6 | 98.6 | 54.5
Kentucky | 230.3 | 209.4 | 131.8 | 494.1 | 159.8 | 60.4
Maryland | 353.5 | 251.1 | 146.9 | 510.2 | 398.3 | 77.1
Massachusetts | 598.8 | 310.4 | 299.1 | 1071.3 | 284.4 | 41.0
Minnesota | 134.6 | 133.7 | 88.1 | 240.6 | 129.0 | 66.8
Missouri | 187.3 | 152.2 | 94.4 | 362.2 | 148.2 | 61.5
Nebraska | 47.0 | 58.2 | 28.0 | 82.6 | 60.2 | 50.3
Nevada | 186.3 | 179.9 | 99.4 | 294.7 | 219.8 | 101.1
New Jersey | 265.4 | 166.1 | 115.4 | 401.2 | 250.0 | 45.1
New York | 252.0 | 123.5 | 109.6 | 340.8 | 204.8 | 40.2
North Carolina | 187.8 | 169.5 | 109.6 | 351.0 | 157.5 | 73.1
North Dakota | 86.4 | 114.7 | 61.2 | 191.5 | 94.3 | 54.2
Ohio | 319.6 | 257.6 | 178.1 | 686.8 | 202.2 | 54.7
Rhode Island | 383.0 | 218.9 | 166.0 | 625.2 | 294.4 | 64.7
South Carolina | 109.5 | 102.3 | 52.1 | 209.9 | 108.4 | 49.1
South Dakota | 61.2 | 65.0 | 33.8 | 118.5 | 59.5 | 51.0
Tennessee | 140.3 | 150.7 | 72.5 | 272.8 | 152.4 | 78.6
Utah | 179.4 | 166.8 | 91.3 | 330.1 | 169.4 | 95.3
Vermont | 226.7 | 220.8 | 139.5 | 558.1 | 145.3 | 68.9
Wisconsin | 165.0 | 148.8 | 103.7 | 333.6 | 118.7 | 59.9

a Opioid-related ED visit rates are per 100,000 population.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), HCUP Fast Stats, Opioid-Related Hospital Use (www.hcup-us.ahrq.gov/faststats/landing.jsp) based on the HCUP State Emergency Department Databases (SEDD)

■ In contrast to inpatient stays, males had a higher rate of opioid-related ED visits than did females in most States.
  In 2014, the rate of opioid-related ED visits was higher among—
  - Males in three-fourths of States (23 of 30 States, with an average across these States of 226.0 per 100,000 population, data not shown)
  - Females in seven States (average 87.5 per 100,000 population)
  The average rate for both sexes was higher in States where males had a higher rate than females.

### National rate of opioid-related inpatient stays and ED visits by patient age, 2005–2014

Figure 4 presents the 10-year trends in the national rate of opioid-related inpatient stays and ED visits by patient age group, from 2005–2014.

Figure 4 National rate of opioid-related inpatient stays and ED visits by patient age, 2005–2014

Abbreviation: ED, emergency department

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), HCUP Fast Stats, Opioid-Related Hospital Use (www.hcup-us.ahrq.gov/faststats/landing.jsp) based on the HCUP National (Nationwide) Inpatient Sample (NIS) and the Nationwide Emergency Department Sample (NEDS)

Figure 4. National rate of opioid-related inpatient stays and ED visits by patient age, 2005–2014. Two line graphs that show the national rate of opioid-related inpatient stays and ED visits per 100,000 population from 2005 to 2014 by patient age. Inpatient stays: <1 year: 2005, 27.9; 2006, 20.5; 2007, 19.0; 2008, 18.6; 2009, 19.1; 2010, 19.2; 2011, 17.5; 2012, 27.9; 2013, 22.6; 2014, 28.3; cumulative increase, 1.5%. 1–24 years: Increased from 40.6 in 2005 to 57.5 in 2008, decreased to 57.4 in 2009, increased to 69.0 in 2012, and decreased to 67.4 in 2014; cumulative increase, 66.2%. 25–44 years: Increased from 207.7 in 2005 to 256.4 in 2006, decreased to 233.3 in 2008, increased to 286.9 in 2011, decreased to 285.6 in 2012, and increased to 321.0 in 2014; cumulative increase, 54.5%. 45–64 years: increased from 193.6 in 2005 to 241.5 in 2006, decreased to 230.6 in 2007, increased to 306.5 in 2012, decreased to 306.2 in 2013, and increased to 317.4 in 2014; cumulative increase, 64.0%. 65+ years: Increased steadily from 133.9 in 2005 to 238.7 in 2012, decreased to 230.7 in 2013, and then increased to 247.7 in 2014; cumulative increase, 85.0%. ED visits: < 1 year: 2005, 6.4; 2006, 7.1; 2007, 5.1; 2008, 7.0; 2009, 5.9; 2010, 5.3; 2011, 5.5; 2012, 7.1; 2013, 6.5; 2014, 8.6; cumulative increase, 33.5%. 1–24 years: Increased from 52.4 in 2005 to 53.4 in 2006, decreased to 46.9 in 2007, steadily increased to 96.9 in 2013, and then decreased to 96.7 in 2014; cumulative increase, 84.5%. 25–44 years: Increased from 160.8 in 2005 to 164.8 in 2006, decreased to 144.5 in 2007, increased steadily to 336.2 in 2014; cumulative increase, 109.1%. 45–64 years: Increased from 90.3 in 2005 to 95.7 in 2006, decreased to 91.2 in 2007, and then increased steadily to 187.9 in 2014; cumulative increase, 108.1%. 65+ years: Increased from 31.6 in 2005 to 33.0 in 2006, decreased to 31.6 in 2007, and then steadily increased to 67.0 in 2014; cumulative increase, 112.1%.

■ The highest rates of opioid-related inpatient stays were among patients aged 25–44 and 45–64 years, whereas the highest rate of opioid-related ED visits was among patients aged 25–44 years.
  For opioid-related inpatient stays, patients aged 25–44 and 45–64 years had the highest and nearly identical rates throughout 2005 to 2014. Patients aged 65 years and older had the next highest rate of opioid-related inpatient stays over time. For opioid-related ED visits, patients aged 25–44 years had the highest rate, followed by patients aged 45–64 years and those aged 1–24 years.
■ For all age groups, the rate of increase over 10 years was greater for opioid-related ED visits than for opioid-related inpatient stays.
  Between 2005 and 2014 for all age groups, the rate of opioid-related ED visits increased faster than the rate of opioid-related inpatient stays. For example, over the 10-year period for patients aged 25–44 years, the rate of opioid-related ED visits increased 109 percent whereas the rate of opioid-related inpatient stays increased 55 percent.
■ The rate of opioid-related inpatient stays was consistently higher than the rate of opioid-related ED visits among patients younger than 1 year of age, those aged 45–64 years, and those aged 65 years and older, but not among those aged 1–24 and 25–44 years.
  Among patients aged less than 1 year, 45–64 years, and 65 years and older, the rate of opioid-related inpatient stays exceeded the rate of opioid-related ED visits from 2005 to 2014. The reverse was true for patients aged 1–24 years, with a higher opioid-related ED visit rate over this time period. Among those aged 25–44 years, the rate of opioid-related inpatient stays was higher than the rate of opioid-related ED visits from 2005 to 2012, but by 2013 the rate of opioid-related ED visits was higher.

### Patient age group with the highest rate of opioid-related inpatient stays and ED visits, by State, 2014

Figures 5 and 6 identify the patient age group with the highest rate of opioid-related inpatient stays (Figure 5) and ED visits (Figure 6) in each State in 2014. The age group with the highest rate overall is reported for each State. States where the difference between the highest and second highest rates was 10 percent or greater are noted with an asterisk. Figure 5 reports the patient age group with the highest population rate of opioid-related inpatient stays for each of 44 States and the District of Columbia in 2014. Details on the age-specific inpatient rates are shown in Appendix A.

Figure 5 Patient age group with the highest rate^a^ a Opioid-related inpatient rates are per 100,000 population. State-level inpatient rates by age group are provided in Appendix A. of opioid-related inpatient stays, by State, 2014

Note: Asterisks denote States where the difference between the highest and second highest rates in the State was at least 10 percent.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), HCUP Fast Stats, Opioid-Related Hospital Use (www.hcup-us.ahrq.gov/faststats/landing.jsp) based on the HCUP State Inpatient Databases (SID)

Figure 5. Patient age group with the highest rate of opioid-related inpatient stays, by State, 2014. U.S. map that depicts for participating States which age group had the highest rate of opioid-related inpatient stays in 2014. States with the highest rate of opioid-related inpatient stays for ages 25–44 years: Utah, Wyoming, New Mexico, Minnesota, Missouri, Arkansas, Louisiana, Indiana, Ohio, Kentucky, Tennessee, Florida, South Carolina, North Carolina, Virginia, West Virginia, Pennsylvania, New Jersey, Rhode Island, Massachusetts, Vermont, Maine. States with the highest rate of opioid-related inpatient stays for ages 45–64 years: Hawaii, Nevada, Arizona, Oklahoma, Illinois, Michigan, New York, Connecticut, District of Columbia, Maryland. States with highest rate of opioid-related inpatient stays for ages 65+ years: Washington, Oregon, California, Montana, Colorado, North Dakota, South Dakota, Nebraska, Kansas, Texas, Iowa, Wisconsin, Georgia.

Figure 6 Patient age group with the highest rate^a^ a Opioid-related ED visit rates are per 100,000 population. State-level ED visit rates by age group are provided in Appendix B. of opioid-related ED visits, by State, 2014

Abbreviation: ED, emergency department

Note: Asterisks denote States where the difference between the highest and second highest rates in the State was at least 10 percent.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), HCUP Fast Stats, Opioid-Related Hospital Use (www.hcup-us.ahrq.gov/faststats/landing.jsp) based on the HCUP State Emergency Department Databases (SEDD)

Figure 6. Patient age group with the highest rate of opioid-related ED visits, by State, 2014. U.S. map that depicts for participating States which age group had the highest rate of opioid-related ED visits in 2014. States with the highest rate of opioid-related ED visits for ages 25–44 years: California, Nevada, Utah, Arizona, North Dakota, South Dakota, Nebraska, Kansas, Minnesota, Iowa, Missouri, Arkansas, Wisconsin, Illinois, Indiana, Ohio, Kentucky, Tennessee, Florida, Georgia, South Carolina, North Carolina, Maryland, New Jersey, New York, Connecticut, Rhode Island, Massachusetts, Vermont, Hawaii.

■ There was substantial variation in the age group that had the highest rate of opioid-related inpatient stays across States in 2014.
  In 2014, the rate of opioid-related inpatient stays was highest among patients—
  - Aged 25–44 years in approximately half of the States (22 of 45 States, with an average across these States of 414.4 per 100,000 population, data not shown)
  - Aged 45–64 years in 9 States and the District of Columbia (average 491.5 per 100,000 population)
  - Aged 65+ years in 13 States (average 290.0 per 100,000 population)
  There were no States where patients aged 1–24 years had the highest rate.

Figure 6 reports the patient age group with the highest population rate of opioid-related ED visits for each of 30 States that provided data in 2014. Details on the age-specific ED visit rates are shown in Appendix B.

■ Patients aged 25–44 years had the highest opioid-related ED visit rate in all States in 2014.
  In 2014, the rate of opioid-related ED visits was highest among patients aged 25–44 years in all 30 States for which ED visit data were available.

### State rankings in rate of opioid-related inpatient stays and ED visits by patient sex and age group, 2014

Tables 1 and 2 present the relative State rankings in the rate of opioid-related inpatient stays (Table 1) and ED visits (Table 2) by patient sex and age group in 2014. State rankings in each patient subgroup are reported based on four quartiles:

- Lowest rates, corresponding to the bottom 25 percent, noted with a partially filled circle (⊙)
- Highest rates, corresponding to the top 25 percent, noted with a solid circle (●)
- Neither the lowest nor highest rates, corresponding to the middle 50 percent, noted with a dash

Table 1 Ranking in State rates^a^ of opioid-related inpatient stays, by patient sex and age, 2014

State | Males | Females | Ages 1–24 years | Ages 25–44 years | Ages 45–64 years | Ages 65+ years
Arizona | – | – | – | – | ● | ●
Arkansas | ⊙ | ⊙ | ⊙ | – | – | ⊙
California | – | – | ⊙ | ⊙ | – | ●
Colorado | – | – | – | – | – | ●
Connecticut | ● | ● | – | ● | ● | ●
District of Columbia | ● | ● | – | ⊙ | ● | ●
Florida | – | – | – | – | – | –
Georgia | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | –
Hawaii | – | ⊙ | ⊙ | ⊙ | – | ⊙
Illinois | ● | – | – | – | ● | –
Indiana | – | – | – | – | – | –
Iowa | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | ⊙
Kansas | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | –
Kentucky | – | ● | ● | ● | – | ⊙
Louisiana | – | ⊙ | – | – | ⊙ | ⊙
Maine | – | ● | ● | ● | – | –
Maryland | ● | ● | ● | ● | ● | –
Massachusetts | ● | ● | ● | ● | ● | ●
Michigan | – | – | – | – | – | –
Minnesota | – | – | ● | – | – | ●
Missouri | – | – | – | – | – | –
Montana | – | – | – | – | – | ●
Nebraska | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | ⊙
Nevada | – | – | – | ⊙ | – | –
New Jersey | ● | – | ● | ● | ● | –
New Mexico | – | – | – | – | – | –
New York | ● | – | ● | ● | ● | –
North Carolina | – | – | – | – | – | –
North Dakota | ⊙ | – | – | – | ⊙ | –
Ohio | – | ● | ● | ● | – | –
Oklahoma | ⊙ | – | – | – | – | –
Oregon | – | ● | – | – | ● | ●
Pennsylvania | ● | – | – | ● | – | –
Rhode Island | ● | ● | – | ● | ● | –
South Carolina | ⊙ | ⊙ | ⊙ | – | ⊙ | ⊙
South Dakota | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | –
Tennessee | – | – | – | – | – | –
Texas | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | ⊙
Utah | – | – | – | – | – | –
Vermont | – | – | ● | – | ⊙ | ⊙
Virginia | – | – | – | – | – | –
Washington | ● | ● | ● | – | ● | ●
West Virginia | ● | ● | ● | ● | – | ⊙
Wisconsin | – | – | – | – | – | ●
Wyoming | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | ⊙

Key:

● States with the highest opioid-related inpatient rates (top 25 percent) in the patient subgroup

– States with opioid-related inpatient rates in the middle 50 percent in the patient subgroup

⊙ States with the lowest opioid-related inpatient rates (bottom 25 percent) in the patient subgroup

a Opioid-related inpatient rates are per 100,000 population. The actual inpatient rates for both sexes and each age group by State are provided in Appendix A.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), HCUP Fast Stats, Opioid-Related Hospital Use (www.hcup-us.ahrq.gov/faststats/landing.jsp) based on the HCUP State Inpatient Databases (SID)

Table 2 Ranking in State rates^a^ of opioid-related ED visits, by patient sex and age, 2014

State | Males | Females | Ages 1–24 years | Ages 25–44 years | Ages 45–64 years | Ages 65+ years
Arizona | – | ● | – | – | ● | ●
Arkansas | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | ⊙
California | – | – | – | – | – | ●
Connecticut | ● | – | ● | ● | ● | ⊙
Florida | – | – | – | – | – | ⊙
Georgia | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | –
Hawaii | – | ⊙ | ⊙ | ⊙ | – | –
Illinois | – | – | – | – | ● | –
Indiana | – | – | – | – | – | –
Iowa | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | ⊙
Kansas | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | –
Kentucky | – | ● | ● | ● | – | –
Maryland | ● | ● | ● | ● | ● | ●
Massachusetts | ● | ● | ● | ● | ● | ⊙
Minnesota | – | – | – | – | – | –
Missouri | – | – | – | – | – | –
Nebraska | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | –
Nevada | – | – | – | – | – | ●
New Jersey | ● | – | – | – | ● | ⊙
New York | ● | – | – | – | – | ⊙
North Carolina | – | – | – | – | – | ●
North Dakota | ⊙ | – | – | – | ⊙ | –
Ohio | ● | ● | ● | ● | – | –
Rhode Island | ● | ● | ● | ● | ● | –
South Carolina | – | – | – | – | – | –
South Dakota | ⊙ | ⊙ | ⊙ | ⊙ | ⊙ | –
Tennessee | – | – | – | – | – | ●
Utah | – | – | – | – | – | ●
Vermont | – | ● | ● | ● | – | –
Wisconsin | – | – | – | – | – | –

Key:

● States with the highest opioid-related ED visit rates (top 25 percent) in the patient subgroup

– States with opioid-related ED visit rates in the middle 50 percent in the patient subgroup

⊙ States with the lowest opioid-related ED visit rates (bottom 25 percent) in the patient subgroup

Abbreviation: ED, emergency department

a Opioid-related ED visit rates are per 100,000 population. The actual ED visit rates for both sexes and each age group by State are provided in Appendix B.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), HCUP Fast Stats, Opioid-Related Hospital Use (www.hcup-us.ahrq.gov/faststats/landing.jsp) based on the HCUP State Emergency Department Databases (SEDD)

Table 1 reports the relative ranking of opioid-related inpatient stays for each of 44 States and the District of Columbia that provided data in 2014.

■ Some States consistently ranked lowest or highest in rates of opioid-related inpatient stays in all patient sex and age groups in 2014.
  Four States consistently ranked as having among the lowest rates of opioid-related inpatient stays across all patient sex and age groups: Iowa, Nebraska, Texas, and Wyoming. Similarly, Georgia, Kansas, South Carolina, and South Dakota ranked among the States with the lowest rates in all but one sex or age group.
  One State, Massachusetts, consistently ranked as having among the highest rates of opioid-related inpatient stays across all patient sex and age groups. Connecticut, Maryland, and Washington ranked among the States with the highest rates in all but one sex or age group.
■ Some States ranked lowest for opioid-related inpatient stays for some patient sex and age groups but highest for other patient sex and age groups.
  Some States had consistently high rates or consistently low rates of inpatient stays for some age and sex groups. However, other States had high rates for some patient subgroups and low rates for other patient subgroups. For instance, California had among the lowest rates of opioid-related inpatient stays for patients aged 1–24 and 25–44 years but ranked among the States with the highest rates for patients aged 65 years and older. In contrast, Kentucky and West Virginia ranked among the States with the highest rates for the two younger age groups but among the States with the lowest rates for the oldest age group.

Table 2 reports the relative rankings of opioid-related ED visits for each of 30 States that provided data in 2014.

■ Some States consistently ranked lowest or highest in rates of opioid-related ED visits in all patient sex and age groups in 2014.
  Two States consistently ranked as having among the lowest rates of opioid-related ED visits across all patient sex and age groups: Arkansas and Iowa. Similarly, Georgia, Kansas, Nebraska, and South Dakota ranked among the States with the lowest rates in all but one sex and age group. One State, Maryland, consistently ranked as having among the highest rates of opioid-related ED visits across all patient sex and age groups. Massachusetts and Rhode Island ranked among the States with the highest rates in all but one sex or age group.
■ Some States ranked lowest in rates of opioid-related ED visits for some patient sex and age groups but highest for other patient sex and age groups.
  Some States had consistently high rates or consistently low rates of ED visits for some age and sex groups. However, other States had high rates for some patient subgroups and low rates for other patient subgroups. For instance, Connecticut and Massachusetts had among the highest rates of opioid-related ED visits for patients aged 1–24, 25–44, and 45–64 years but ranked among the States with the lowest rates for patients aged 65 years and older.

## Data Source

The estimates in this Statistical Brief are based upon data from the Healthcare Cost and Utilization Project (HCUP) 2005–2014 National (Nationwide) Inpatient Sample (NIS), 2005–2014 Nationwide Emergency Department Sample (NEDS), 2014 State Inpatient Databases (SID), and 2014 State Emergency Department Databases (SEDD). The statistics were generated from HCUP Fast Stats, a free, online tool that provides users with easy access to the latest HCUP-based statistics for health information topics, including opioid-related hospital use.^4^

Inpatient statistics from HCUP Fast Stats were available for the following 44 individual States and the District of Columbia in 2014: Arizona, Arkansas, California, Colorado, Connecticut, District of Columbia, Florida, Georgia, Hawaii, Illinois, Indiana, Iowa, Kansas, Kentucky, Louisiana, Maine, Maryland, Massachusetts, Michigan, Minnesota, Missouri, Montana, Nebraska, Nevada, New Jersey, New Mexico, New York, North Carolina, North Dakota, Ohio, Oklahoma, Oregon, Pennsylvania, Rhode Island, South Carolina, South Dakota, Tennessee, Texas, Utah, Vermont, Virginia, Washington, West Virginia, Wisconsin, and Wyoming.

Emergency department (ED) statistics from HCUP Fast Stats were available for the following 30 individual States in 2014: Arizona, Arkansas, California, Connecticut, Florida, Georgia, Hawaii, Illinois, Indiana, Iowa, Kansas, Kentucky, Maryland, Massachusetts, Minnesota, Missouri, Nebraska, Nevada, New Jersey, New York, North Carolina, North Dakota, Ohio, Rhode Island, South Carolina, South Dakota, Tennessee, Utah, Vermont, and Wisconsin.

Rates are presented in HCUP Fast Stats using population data obtained from Claritas, a vendor that compiles and adds value to data from the U.S. Census Bureau.^5^

## Definitions

### Diagnoses and ICD-9-CM

The principal diagnosis is that condition established after study to be chiefly responsible for the patient’s admission to the hospital. Secondary diagnoses are concomitant conditions that coexist at the time of admission or develop during the stay. All-listed diagnoses include the principal diagnosis plus these additional secondary conditions.

ICD-9-CM is the International Classification of Diseases, Ninth Revision, Clinical Modification, which assigns numeric codes to diagnoses. There are approximately 14,000 ICD-9-CM diagnosis codes.

### Case definition

Opioid-related hospital use was identified using the following all-listed ICD-9-CM diagnosis codes:

- 304.00–304.02: Opioid type dependence (unspecified; continuous; episodic)
- 304.70–304.72: Combinations of opioid type drug with any other drug dependence (unspecified; continuous; episodic)
- 305.50–305.52: Opioid abuse (unspecified; continuous; episodic)
- 965.00–965.02; 965.09: Poisoning by opium (alkaloids), unspecified; heroin; methadone; other opiates and related narcotics
- 970.1: Poisoning by opiate antagonists
- E850.0–E850.2: Accidental poisoning by heroin; methadone; other opiates and related narcotics
- E935.0–E935.2: Heroin, methadone, other opiates and related narcotics causing adverse effects in therapeutic use
- E940.1: Opiate antagonists causing adverse effects in therapeutic use

It should be noted that ICD-9-CM diagnosis codes related to opioid dependence or abuse “in remission” were not used to identify opioid-related hospital use because remission does not indicate active use of opioids. Potential changes in the use of ICD-9-CM codes identifying opioid use cannot be isolated in these analyses.

These codes include opioid-related use stemming from illicit opioids such as heroin, illegal use of prescription opioids, and the use of opioids as prescribed. Each type of opioid use is important for understanding and addressing the opioid epidemic in the United States.^6^ While there may be interest in examining how much each type of opioid use contributes to the overall opioid problem, many of the opioid-related codes under the ICD-9-CM clinical coding system do not allow heroin-related cases to be explicitly identified (e.g., in the 304.0x series, heroin is not distinguished from other opioids). In addition, the codes do not distinguish between illegal use of prescription drugs and their use as prescribed.

### Types of hospitals included in the HCUP National (Nationwide) Inpatient Sample

The National (Nationwide) Inpatient Sample (NIS) is based on data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). The NIS includes obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded are long-term care facilities such as rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. Beginning in 2012, long-term acute care hospitals are also excluded. However, if a patient received long-term care, rehabilitation, or treatment for a psychiatric or chemical dependency condition in a community hospital, the discharge record for that stay will be included in the NIS.

### Types of hospitals included in the HCUP Nationwide Emergency Department Sample

The Nationwide Emergency Department Sample (NEDS) is based on data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). The NEDS includes specialty, pediatric, public, and academic medical hospitals. Excluded are long-term care facilities such as rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. Hospitals included in the NEDS have hospital-owned emergency departments (EDs) and no more than 90 percent of their ED visits resulting in admission.

### Types of hospitals included in HCUP State Inpatient Databases

This analysis used State Inpatient Databases (SID) limited to data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). Community hospitals include obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded for this analysis are long-term care facilities such as rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. However, if a patient received long-term care, rehabilitation, or treatment for a psychiatric or chemical dependency condition in a community hospital, the discharge record for that stay was included in the analysis.

### Types of hospitals included in HCUP State Emergency Department Databases

This analysis used State Emergency Department Databases (SEDD) limited to data from community hospitals with a hospital-owned emergency department. Community hospitals are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). Community hospitals include specialty, pediatric, public, and academic medical hospitals. Excluded for this analysis are long-term care facilities such as rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals.

### Unit of analysis

The unit of analysis for inpatient data is the hospital discharge (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the hospital multiple times in 1 year will be counted each time as a separate discharge from the hospital. Inpatient stays include those for patients admitted through the emergency department (ED). Patients transferred between inpatient hospitals are counted only once.

The unit of analysis for ED data is the ED visit, not a person or patient. This means that a person who is seen in the ED multiple times in 1 year will be counted each time as a separate visit in the ED. ED visits exclude those for patients admitted to the same hospital and also exclude patients transferred to another hospital.

## For More Information

For other information on mental health and substance abuse, including opioids, refer to the HCUP Statistical Briefs located at www.hcup-us.ahrq.gov/reports/statbriefs/sb_mhsa.jsp.

For additional HCUP statistics, visit:

- HCUP Fast Stats at www.hcup-us.ahrq.gov/faststats/landing.jsp for easy access to the latest HCUP-based statistics for health information topics
- HCUPnet, HCUP’s interactive query system, at www.hcupnet.ahrq.gov/

For more information about HCUP, visit www.hcup-us.ahrq.gov/.

For a detailed description of HCUP and more information on the design of the National (Nationwide) Inpatient Sample, Nationwide Emergency Department Sample (NEDS), State Inpatient Databases (SID), or State Emergency Department Databases (SEDD), please refer to the following database documentation:

Agency for Healthcare Research and Quality. Overview of the National (Nationwide) Inpatient Sample (NIS). Healthcare Cost and Utilization Project (HCUP). Rockville, MD: Agency for Healthcare Research and Quality. Updated December 2016. www.hcup-us.ahrq.gov/nisoverview.jsp. Accessed January 31, 2017.

Agency for Healthcare Research and Quality. Overview of the Nationwide Emergency Department Sample (NEDS). Healthcare Cost and Utilization Project (HCUP). Rockville, MD: Agency for Healthcare Research and Quality. Updated December 2016. www.hcup-us.ahrq.gov/nedsoverview.jsp. Accessed January 31, 2017.

Agency for Healthcare Research and Quality. Overview of the State Inpatient Databases (SID). Healthcare Cost and Utilization Project (HCUP). Rockville, MD: Agency for Healthcare Research and Quality. Updated June 2016. www.hcup-us.ahrq.gov/sidoverview.jsp. Accessed January 31, 2017.

Agency for Healthcare Research and Quality. Overview of the State Emergency Department Databases (SEDD). Healthcare Cost and Utilization Project (HCUP). Rockville, MD: Agency for Healthcare Research and Quality. Updated June 2016. www.hcup-us.ahrq.gov/seddoverview.jsp. Accessed January 31, 2017.

1 Weiss AJ, Elixhauser A, Barrett ML, Steiner CA, Bailey MK, O’Malley L. Opioid-Related Inpatient Stays and Emergency Department Visits by State, 2009–2014. HCUP Statistical Brief #219. December 2016. Agency for Healthcare Research and Quality, Rockville, MD. www.hcup-us.ahrq.gov/reports/statbriefs/sb219-Opioid-Hospital-Stays-ED-Visits-by-State.pdf. Accessed February 9, 2017.

2 Agency for Healthcare Research and Quality. HCUP Fast Stats Web site, Opioid-Related Hospital Use path. www.hcup-us.ahrq.gov/faststats/landing.jsp. Accessed January 26, 2017.

3 Weiss et al., 2016. Op. cit.

4 Agency for Healthcare Research and Quality. HCUP Fast Stats Web site, Opioid-Related Hospital Use path. www.hcup-us.ahrq.gov/faststats/landing.jsp. Accessed January 26, 2017.

5 Claritas. Claritas Demographic Profile. www.claritas.com. Accessed June 23, 2017.

6 Compton WM, Jones CM, Baldwin GT. Relationship between nonmedical prescription-opioid use and heroin use. The New England Journal of Medicine. 2016;374:154–63.26760086