# Statistical Brief #222 Delivery Hospitalizations Involving Preeclampsia and Eclampsia, 2005–2014

## Introduction

Preeclampsia is a disorder of new-onset high blood pressure occurring after 20 weeks of gestation. The diagnosis of preeclampsia is characterized by high blood pressure^1^ and either excess protein in the urine^2^ or, in the absence of proteinuria, other signs or symptoms, such as thrombocytopenia, renal insufficiency, impaired liver function, pulmonary edema, or cerebral or visual symptoms.^3^

Although rare, eclampsia occurs when women suffering from preeclampsia during pregnancy develop seizures, which may be followed by coma, posing a threat to the life of the mother and baby.^4^

Women with preexisting hypertension (high blood pressure before pregnancy or within the first 20 weeks of gestation) and gestational hypertension (onset of high blood pressure after 20 weeks of gestation) are at increased risk for preeclampsia/eclampsia, although many women who develop preeclampsia/eclampsia have no history of high blood pressure.^5^ Other risk factors for preeclampsia/eclampsia include preexisting diabetes, renal disease, obesity, falling in the youngest or oldest categories of maternal age, multiple gestations, women giving birth for the first time, and race.^6,7^

Black women are more likely to develop preeclampsia and to experience poorer outcomes associated with the condition, including progression to eclampsia and in rare cases, death.^8,9^

In addition to increased risk of mortality, women with preeclampsia/eclampsia are more likely to experience cesarean section (C-section), placental abruption, disseminated intravascular coagulation, cerebral hemorrhage, pulmonary edema, and renal failure.^10,11,12^ Infants born to mothers with preeclampsia/eclampsia are more likely to have intrauterine growth restriction, premature birth, and intrauterine death.^13^

In the United States, preeclampsia/eclampsia and other hypertensive disorders of pregnancy have increased over the last 2 decades.^14^ Preeclampsia/eclampsia is estimated to complicate between 3 and 6 percent of all pregnancies and is considered one of the most preventable causes of maternal death.^15,16^ However, there is little recent national population-based data on the prevalence of the condition and its associated coexisting conditions and complications that can inform efforts to prevent preeclampsia/eclampsia.^17,18^

This Healthcare Cost and Utilization Project (HCUP) Statistical Brief presents data on the prevalence of preeclampsia/eclampsia among inpatient delivery hospitalizations in 2014. The Brief describes trends in the rate of preeclampsia/eclampsia from 2005 through 2014, overall and by patient and hospital characteristics. Characteristics of deliveries with preeclampsia/eclampsia are examined in 2014.

Deliveries with preeclampsia/eclampsia are compared with all other deliveries, with respect to patient and hospital characteristics, coexisting conditions, and infant and maternal outcomes.^19,20^ These characteristics are also compared across type of diagnosis: eclampsia, severe preeclampsia, mild or unspecified preeclampsia, and preeclampsia/eclampsia with preexisting hypertension.^21^

Delivery hospitalizations represent the hospital stay for the mother and not the infant. Descriptions of infant outcomes are those conditions that appear on the maternal record. All differences between estimates noted in the text are 10 percent or greater.

## Findings

Highlights

■ In 2014, almost 5 percent of all inpatient deliveries involved preeclampsia/eclampsia—a 21 percent increase from 2005.
■ Of the nearly 177,000 deliveries with the condition in 2014, 1 percent had eclampsia, 37 percent had severe preeclampsia, 47 percent had mild/unspecified preeclampsia, and 15 percent had preeclampsia/eclampsia with preexisting hypertension.
■ For black women, the rate of preeclampsia/eclampsia was 70 per 1,000 deliveries in 2014—60 percent higher than for white women (43 per 1,000).
■ The condition was less severe among white women than among black women. Over half of white women with the condition had mild/unspecified preeclampsia, compared with 37 percent of black women.
■ Compared with other deliveries, a higher percentage of those with preeclampsia/eclampsia were among women who were the youngest, the oldest, black, and from the poorest areas and the South.
■ Compared with other deliveries, mean length and cost of stays with preeclampsia/eclampsia were 70 percent higher.
■ Procedural interventions (such as cesarean section, blood transfusion, hysterectomy, ventilation) were more common among deliveries with preeclampsia/eclampsia than among other deliveries, as were severe obstetric morbidities (such as renal failure) and poor infant outcomes.

### Prevalence of delivery hospitalizations involving preeclampsia/eclampsia, 2014

The left side of Figure 1 displays all delivery hospitalizations in 2014 by presence of preeclampsia/eclampsia as well as other hypertension-related diagnoses complicating pregnancy, childbirth, and the puerperium. The right side of Figure 1 displays the subset of delivery hospitalizations with a diagnosis of preeclampsia/eclampsia in 2014 by type of preeclampsia/eclampsia diagnosis.

Figure 1 Hypertension-related diagnoses among delivery hospitalizations, 2014

^a^ Records with ICD-9-CM diagnosis code 642.7, which indicates that preeclampsia or eclampsia was present with preexisting hypertension but does not specify the severity of the condition.

^b^ Preexisting hypertension without preeclampsia or eclampsia.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS), 2014

Figure 1 is two pie charts, one showing the distribution of all delivery hospitalizations with and without hypertension-related diagnoses and the other showing the distribution of deliveries by type of preeclamsia/eclampsia. Total delivery hospitalizations: 3,796,490; no hypertension: 3,386,995, 89.2%; preeclampsia, eclampsia: 176,925, 4.7%; pre-existing hypertension: 63,920, 1.7%; gestational hypertension: 145,720, 3.8%; unspecified hypertension: 22,930, 0.6%. Total deliveries with preeclampsia/eclampsia: 176,925; mild or unspecified preeclampsia: 82,910, 46.9%; severe preeclampsia: 65,880, 37.2%; preeclampsia/eclampsia with pre-existing hypertension: 25,625, 14.5%; eclampsia: 2,510, 1.4%.

■ In 2014, more than 1 in 10 delivery hospitalizations had a diagnosis of hypertension. Among these deliveries with any hypertension-related diagnosis, preeclampsia/eclampsia was the most common.
  In 2014, 409,495 delivery hospitalizations had a diagnosis of hypertension complicating pregnancy, childbirth, and the puerperium, representing 10.8 percent of 3.8 million total deliveries. Preeclampsia/eclampsia was the most common type of hypertension-related diagnosis (4.7 percent), followed by gestational hypertension (3.8 percent), preexisting hypertension (1.7 percent), and unspecified hypertension (0.6 percent).
■ In 2014, of all delivery hospitalizations with a diagnosis of preeclampsia/eclampsia, over one-third had severe preeclampsia.
  In 2014, 176,925 delivery hospitalizations had a diagnosis of preeclampsia/eclampsia, representing 4.7 percent of 3.8 million total deliveries. Although the most severe form of the condition (eclampsia) was rare (1.4 percent), an additional 37.2 percent of deliveries with any diagnosis of preeclampsia/eclampsia had severe preeclampsia. Nearly half of deliveries with preeclampsia/eclampsia had mild or unspecified preeclampsia (46.9 percent), and 14.5 percent had preeclampsia/eclampsia with preexisting hypertension but lacked detail on the severity of the condition.
  In addition to the deliveries shown in Figure 1, in 2014 there were 21,180 hospitalizations during or after pregnancy involving preeclampsia/eclampsia, in which the hospital stay did not result in delivery (data not shown). Although this Brief focuses on delivery hospitalizations, these antepartum and postpartum stays contribute to the total burden of preeclampsia/eclampsia in the inpatient hospital setting.

### Characteristics of delivery hospitalizations involving preeclampsia/eclampsia, 2014

Table 1 compares patient and hospital characteristics among deliveries with preeclampsia/eclampsia with all other deliveries in 2014.

Table 1 Characteristics of deliveries with and without preeclampsia/eclampsia, 2014

Patient and hospital characteristics | Preeclampsia/eclampsia, total | All other deliveries | Type of preeclampsia/eclampsia
Patient and hospital characteristics | Preeclampsia/eclampsia, total | All other deliveries | Eclampsia | Severe preeclampsia | Mild or unspecified preeclampsia | Preeclampsia/eclampsia with preexisting hypertension^a^
Total, N | 176,925 | 3,619,565 | 2,510 | 65,880 | 82,910 | 25,625
Patient age, mean, years | 28.5 | 28.3 | 25.8 | 28.3 | 27.8 | 31.3
Patient age, years, %
<20 | 8.2 | 6.4 | 21.3 | 8.9 | 9.1 | 1.9
20–24 | 21.9 | 22.1 | 25.9 | 22.4 | 24.2 | 12.8
25–29 | 26.2 | 28.8 | 23.3 | 26.3 | 27.0 | 23.5
30–34 | 24.8 | 27.3 | 15.9 | 23.8 | 24.2 | 29.9
35–39 | 14.3 | 12.6 | 10.2 | 14.1 | 11.9 | 22.9
40+ | 4.6 | 2.8 | 3.4 | 4.4 | 3.5 | 8.9
Race/ethnicity, %
White | 46.6 | 50.3 | 44.8 | 42.9 | 51.6 | 39.7
Black | 20.1 | 13.1 | 23.5 | 20.8 | 16.0 | 31.3
Hispanic | 19.5 | 19.4 | 19.1 | 21.1 | 19.1 | 16.7
Asian/Pacific Islander | 3.4 | 5.5 | 2.2 | 3.7 | 3.2 | 3.2
Other | 4.9 | 5.2 | 4.8 | 5.3 | 4.9 | 4.0
Missing | 5.6 | 6.5 | 5.6 | 6.3 | 5.2 | 5.1
Expected payer, %
Medicare | 1.0 | 0.7 | 1.2 | 1.0 | 0.7 | 1.8
Medicaid | 45.2 | 42.9 | 56.8 | 45.9 | 43.1 | 49.5
Private insurance | 49.2 | 50.8 | 37.0 | 48.5 | 51.5 | 44.6
Uninsured | 2.1 | 2.8 | 2.6 | 2.3 | 2.1 | 1.8
Other | 2.5 | 2.8 | 2.4 | 2.4 | 2.5 | 2.4
Community income, %
Quartile 1 (poorest) | 31.9 | 27.7 | 39.6 | 32.1 | 30.3 | 36.1
Quartile 2 | 26.7 | 26.5 | 24.3 | 25.8 | 27.3 | 27.3
Quartile 3 | 22.9 | 24.0 | 21.9 | 23.2 | 23.4 | 20.7
Quartile 4 (wealthiest) | 18.4 | 21.9 | 14.2 | 18.9 | 19.0 | 15.8
Location of residence, %
Large metropolitan | 57.1 | 57.1 | 53.2 | 60.0 | 54.9 | 57.2
Small metropolitan | 29.1 | 29.6 | 30.5 | 28.1 | 29.7 | 29.4
Micropolitan | 8.2 | 8.0 | 8.8 | 6.9 | 9.3 | 7.8
Rural (noncore) | 5.6 | 5.3 | 7.6 | 4.9 | 6.1 | 5.6
Hospital region, %
Northeast | 15.5 | 16.0 | 12.7 | 16.4 | 15.0 | 14.9
Midwest | 20.3 | 21.3 | 18.5 | 20.3 | 20.5 | 19.4
South | 42.6 | 38.3 | 48.6 | 40.8 | 42.5 | 46.9
West | 21.7 | 24.3 | 20.1 | 22.5 | 22.0 | 18.7
Length of stay, mean, days | 4.4 | 2.6 | 4.4 | 4.8 | 3.7 | 5.4
Cost per stay, mean, $ | 7,500 | 4,400 | 9,000 | 8,500 | 6,300 | 8,900

a Records with ICD-9-CM diagnosis code 642.7, which indicates that preeclampsia or eclampsia was present with preexisting hypertension but does not specify the severity of the condition.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS), 2014

■ Compared with all other deliveries, those with preeclampsia/eclampsia were more likely to be among women in the youngest and oldest age categories, black women, women from the poorest areas, and women who delivered in the South.
  Overall, deliveries with preeclampsia/eclampsia were more likely than all other deliveries to be among women in the youngest and oldest age groups (8.2 vs. 6.4 percent among patients aged less than 20 years; 18.9 vs. 15.4 percent among women aged 35 years or older) and to be among black women (20.1 vs. 13.1 percent). In addition, preeclampsia/eclampsia was more common among women who resided in the poorest areas (31.9 vs. 27.7 percent in income quartile 1) and those who delivered in the South (42.6 vs. 38.3 percent).
■ The mean length of stay and hospital costs were over 70 percent higher for deliveries with preeclampsia/eclampsia, compared with all other deliveries.
  The mean length of stay was 71 percent higher for deliveries with preeclampsia/eclampsia compared with all other deliveries (4.4 vs. 2.6 days). The average hospital cost per stay was 70 percent higher for deliveries with preeclampsia/eclampsia compared with all other deliveries ($7,500 vs. $4,400).
■ There were differences in patient age and race/ethnicity across the types of preeclampsia/eclampsia.
  ○ Of deliveries with eclampsia, 21.3 percent were among teens. In comparison, less than 10 percent of deliveries with other diagnoses for severe preeclampsia or mild preeclampsia were among teens. Only 6.4 percent of all other deliveries without a diagnosis of preeclampsia/eclampsia were in this age group.
  ○ Nearly 1 in 3 deliveries (31.3 percent) with a diagnosis of preeclampsia/eclampsia with preexisting hypertension were among black women. In comparison, only 13.1 percent of all other deliveries were among black women.
■ Deliveries involving preeclampsia/eclampsia with preexisting hypertension were associated with longer hospital stays. Hospital stays for more severe forms of preeclampsia/eclampsia were more expensive than the mild or unspecified type.
  The mean length of stay was highest for deliveries with a diagnosis of preeclampsia/eclampsia with preexisting hypertension (5.4 days compared with 4.8 days or fewer among deliveries with other preeclampsia/eclampsia diagnoses). The average hospital cost per stay was lower for deliveries with mild or unspecified preeclampsia ($6,300) than for deliveries with the other preeclampsia/eclampsia diagnoses ($8,500–$9,000).

### Rate of preeclampsia/eclampsia among delivery hospitalizations, 2005–2014

Figure 2 displays the rate of preeclampsia/eclampsia per 1,000 deliveries by type of diagnosis from 2005 through 2014.

Figure 2 Rate of preeclampsia/eclampsia among delivery hospitalizations, 2005–2014

^a^ Records with ICD-9-CM diagnosis code 642.7, which indicates that preeclampsia or eclampsia was present with preexisting hypertension but does not specify the severity of the condition.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National (Nationwide) Inpatient Sample (NIS), 2005–2014

Figure 2 is a bar chart that shows the rate of preclampsia/eclampsia per 1,000 delivery hospitalizations by diagnosis type from 2005 through 2014. 2005: total, 38.4; preeclampsia/eclampsia with pre-existing hypertension, 3.7; mild or unspecified preeclampsia, 22.2; severe preeclampsia, 11.6; eclampsia, 0.9. 2006: total, 39.0; preeclampsia/eclampsia with pre-existing hypertension, 4.0; mild or unspecified preeclampsia, 22.5; severe preeclampsia, 11.7; eclampsia, 0.8. 2007: total, 39.3; preeclampsia/eclampsia with pre-existing hypertension, 4.3; mild or unspecified preeclampsia, 22.4; severe preeclampsia, 11.8; eclampsia, 0.8. 2008: total, 39.7; preeclampsia/eclampsia with pre-existing hypertension, 4.4; mild or unspecified preeclampsia, 21.5; severe preeclampsia, 13.0; eclampsia, 0.8. 2009: total, 41.7; preeclampsia/eclampsia with pre-existing hypertension, 5.1; mild or unspecified preeclampsia, 22.8; severe preeclampsia, 13.0; eclampsia, 0.8. 2010: total, 44.4; preeclampsia/eclampsia with pre-existing hypertension, 5.8; mild or unspecified preeclampsia, 23.2; severe preeclampsia, 14.6; eclampsia, 0.7. 2011: total, 43.8; preeclampsia/eclampsia with pre-existing hypertension, 5.7; mild or unspecified preeclampsia, 22.3; severe preeclampsia, 15.1; eclampsia, 0.7. 2012: total, 44.4; preeclampsia/eclampsia with pre-existing hypertension, 6.1; mild or unspecified preeclampsia, 21.9; severe preeclampsia, 15.8; eclampsia, 0.7. 2013: total, 45.3; preeclampsia/eclampsia with pre-existing hypertension, 6.4; mild or unspecified preeclampsia, 22.0; severe preeclampsia, 16.2; eclampsia, 0.7. 2014: total, 46.6; preeclampsia/eclampsia with pre-existing hypertension, 6.7; mild or unspecified preeclampsia, 21.8; severe preeclampsia, 17.4; eclampsia, 0.7. Percent change: total, +21%; preeclampsia/eclampsia with pre-existing hypertension, +83%; mild or unspecified preeclampsia, −2%; severe preeclampsia, +50%; eclampsia, −27%.

■ From 2005 through 2014, the total rate of preeclampsia/eclampsia among delivery hospitalizations increased by 21 percent.
  The total rate of preeclampsia/eclampsia increased from 38.4 per 1,000 deliveries in 2005 to 46.6 per 1,000 deliveries in 2014, an increase of 21 percent. The largest increases were for deliveries with preeclampsia/eclampsia with preexisting hypertension (which increased by 83 percent, from 3.7 to 6.7 per 1,000 deliveries) and deliveries with severe preeclampsia (which increased by 50 percent over the 10-year span, from 11.6 to 17.4 per 1,000 deliveries).
■ Although rare, the rate of eclampsia decreased by 27 percent from 2005 through 2014.
  From 2005 through 2014, the rate of eclampsia decreased from 0.9 to 0.7 per 1,000 deliveries, a decrease of 27 percent. Deliveries with mild or unspecified preeclampsia remained stable at around 22 per 1,000 deliveries.

Table 2 presents the total rate of preeclampsia/eclampsia per 1,000 deliveries in 2005 and 2014, by patient and hospital characteristics.

Table 2 Number and rate of preeclampsia/eclampsia deliveries by patient and hospital characteristics, 2005 and 2014

Patient and hospital characteristics | 2005 | | 2014 | | Percent change in rate, 2005–2014
Patient and hospital characteristics | Number of deliveries with preeclampsia/eclampsia, N | Rate of preeclampsia/eclampsia per 1,000 deliveries | Number of deliveries with preeclampsia/eclampsia, N | Rate of preeclampsia/eclampsia per 1,000 deliveries | Percent change in rate, 2005–2014
Total | 155,839 | 38.4 | 176,925 | 46.6 | 21
Patient age, years
<20 | 21,520 | 52.0 | 14,495 | 59.3 | 14
20–24 | 39,355 | 39.3 | 38,795 | 46.2 | 18
25–29 | 37,933 | 34.5 | 46,285 | 42.5 | 23
30–34 | 32,240 | 34.2 | 43,860 | 42.6 | 25
35–39 | 18,708 | 38.7 | 25,320 | 52.5 | 36
40+ | 6,068 | 54.1 | 8,170 | 73.5 | 36
Expected payer^a^
Medicare | 1,117 | 53.4 | 1,740 | 63.9 | 20
Medicaid | 69,766 | 41.2 | 79,805 | 49.0 | 19
Private insurance | 75,169 | 35.8 | 86,770 | 45.1 | 26
Uninsured | 5,224 | 35.9 | 3,770 | 36.2 | 1
Community income
Quartile 1 (poorest) | 46,904 | 44.3 | 55,360 | 53.2 | 20
Quartile 2 | 39,444 | 40.1 | 46,325 | 46.8 | 17
Quartile 3 | 36,939 | 36.7 | 39,765 | 44.5 | 21
Quartile 4 (wealthiest) | 28,354 | 30.8 | 31,915 | 39.4 | 28
Location of residence
Large metropolitan | 85,752 | 37.8 | 100,810 | 46.7 | 23
Small metropolitan | 43,582 | 37.2 | 51,325 | 45.8 | 23
Micropolitan | 15,808 | 42.6 | 14,420 | 47.6 | 12
Rural (noncore) | 10,206 | 43.7 | 9,880 | 48.7 | 12
Hospital region
Northeast | 25,572 | 34.6 | 27,350 | 45.0 | 30
Midwest | 32,663 | 38.6 | 35,845 | 44.4 | 15
South | 66,200 | 43.1 | 75,365 | 51.6 | 20
West | 31,405 | 33.6 | 38,365 | 41.7 | 24

a Other payers are not shown.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National (Nationwide) Inpatient Sample (NIS), 2005 and 2014

■ The rate of preeclampsia/eclampsia was highest among women in the oldest and youngest age groups in both 2005 and 2014, but the rate increased most rapidly among women aged 35 years or older.
  In 2005 and 2014, the rate of preeclampsia/eclampsia was highest among women younger than 20 years and women aged 40 years or older (59.3 and 73.5 per 1,000 deliveries, respectively, in 2014). From 2005 to 2014, the rate increased the most among women aged 35–39 years and 40 years and older (each with a 36 percent increase). The rate among women younger than 20 years increased by only 14 percent, the smallest increase of any age group.
■ The rate of preeclampsia/eclampsia was higher among deliveries paid by Medicaid than among those paid by private insurance, but the rate increased more over time among deliveries paid by private insurance.
  Medicaid and private insurance paid for the vast majority of deliveries. In 2005, the rate of preeclampsia/eclampsia was 15 percent higher among deliveries paid by Medicaid than among those paid by private insurance (41.2 vs. 35.8 per 1,000 deliveries). In 2014, this difference decreased (49.0 vs. 45.1 per 1,000 deliveries), reflecting a 19 percent increase in the rate of preeclampsia/eclampsia among deliveries with Medicaid versus a 26 percent increase in the rate among deliveries with private insurance.
  Although Medicare paid for relatively fewer deliveries compared with the other payers, the rate of preeclampsia/eclampsia was highest among women with Medicare (53.4 per 1,000 deliveries in 2005 and 63.9 per 1,000 deliveries in 2014).
■ The rate of preeclampsia/eclampsia was highest among women who resided in the poorest areas, but the rate rose more among those from the wealthiest areas.
  In both 2005 and 2014, the rate of preeclampsia/eclampsia was highest among women who resided in the poorest ZIP Codes (income quartile 1). During this time period, the rate increased from 44.3 to 53.2 per 1,000 deliveries among women in these areas—an increase of 20 percent. In comparison, the rate was 30.8 per 1,000 deliveries among women who resided in the wealthiest ZIP Codes (income quartile 4) in 2005 but increased by 28 percent to 39.4 per 1,000 deliveries in 2014.
■ The rate of preeclampsia/eclampsia was highest among women who resided in nonmetropolitan areas, but the rate rose more among those from metropolitan areas.
  The rate of preeclampsia/eclampsia was highest among women who resided in micropolitan and rural areas in 2005 (43–44 per 1,000 deliveries) and rose by 12 percent (to 48–49 per 1,000 deliveries in 2014). In comparison, in large and small metropolitan areas, the rate of preeclampsia/eclampsia was 37–38 per 1,000 deliveries in 2005 and increased by 23 percent to 46–47 per 1,000 deliveries in 2014.
■ The rate of preeclampsia/eclampsia was highest among women in the South, but the rate rose most rapidly in the Northeast.
  In both 2005 and 2014, the rate of preeclampsia/eclampsia was highest among deliveries in the South (43.1 and 51.6 per 1,000 deliveries, respectively). The rate of preeclampsia/eclampsia rose across all regions from 2005 through 2014. However, the increase was largest among deliveries in the Northeast, where the rate rose by 30 percent from 34.6 to 45.0 per 1,000 deliveries.

Figure 3 presents the rate of preeclampsia/eclampsia per 1,000 deliveries in 2014, by race/ethnicity and type of diagnosis.

Figure 3 Rate of preeclampsia/eclampsia per 1,000 deliveries, by race/ethnicity and type of diagnosis, 2014

Notes: Trends by race/ethnicity are not shown because in 2005 a number of States did not contribute data on race/ethnicity, resulting in 26 percent of records with missing data. By 2014, the percentage of delivery records with missing data on race/ethnicity was only 6 percent. “Other” and missing races/ethnicities are not shown.

^a^ Records with ICD-9-CM diagnosis code 642.7, which indicates that preeclampsia or eclampsia was present with preexisting hypertension but does not specify the severity of the condition.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS), 2014

Figure 3 is a bar chart that shows the rate of preeclampsia per 1,000 deliveries by race/ethnicity and diagnosis type in 2014. White: total, 43.3; preeclampsia/eclampsia with pre-existing hypertension, 5.3; mild or unspecified preeclampsia, 22.5; severe preeclampsia, 14.9; eclampsia, 0.6. Black: total, 69.8; preeclampsia/eclampsia with pre-existing hypertension, 15.7; mild or unspecified preeclampsia, 26.0; severe preeclampsia, 26.9; eclampsia, 1.2. Hispanic: total, 46.8; preeclampsia/eclampsia with pre-existing hypertension, 5.8; mild or unspecified preeclampsia, 21.5; severe preeclampsia, 18.8; eclampsia, 0.7. Asian/Pacific Islander: total, 28.8; preeclampsia/eclampsia with pre-existing hypertension, 4.0; mild or unspecified preeclampsia, 12.9; severe preeclampsia, 11.6; eclampsia, 0.3.

■ In 2014, the rate of preeclampsia/eclampsia was at least 50 percent higher among black women than among women of any other racial/ethnic group.
  In 2014, the total rate of preeclampsia/eclampsia was higher among black women than among women of other racial/ethnic groups. The total rate of preeclampsia/eclampsia was 69.8 per 1,000 deliveries among black women—about 60 percent higher than the rate among white women (43.3 per 1,000 deliveries).
  In 2014, there was no substantial difference in the total rate of preeclampsia/eclampsia between white women and Hispanic women (43.3 vs. 46.8 per 1,000 deliveries). Asian/Pacific Islanders had the lowest total rate of preeclampsia/eclampsia of any racial/ethnic group (28.8 per 1,000 deliveries).

Table 3 examines each type of preeclampsia/eclampsia as a percentage of total deliveries with any preeclampsia/eclampsia by race/ethnicity.

Table 3 Percentage of each type of preeclampsia/eclampsia, by race/ethnicity, 2014

Type of preeclampsia/eclampsia | White, % | Black, % | Hispanic, % | Asian/Pacific Islander, %
Total | 100.0 | 100.0 | 100.0 | 100.0
Eclampsia | 1.4 | 1.7 | 1.4 | 0.9
Severe preeclampsia | 34.3 | 38.5 | 40.3 | 40.4
Mild or unspecified preeclampsia | 51.9 | 37.3 | 45.9 | 44.9
Preeclampsia/eclampsia with preexisting hypertension^a^ | 12.3 | 22.5 | 12.4 | 13.8

a Records with ICD-9-CM diagnosis code 642.7, which indicates that preeclampsia or eclampsia was present with preexisting hypertension but does not specify the severity of the condition.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS), 2014

■ Among women with preeclampsia/eclampsia, black women were more likely than women of other races/ethnicities to have a more severe diagnosis.
  The rate of each type of preeclampsia/eclampsia diagnosis was higher among black women than among women of other races/ethnicities (Figure 3). When the rate for each type of preeclampsia/eclampsia was examined as a percentage of the total rate for any preeclampsia/eclampsia, black women were more likely than other women to have a more severe diagnosis. Among women with preeclampsia/eclampsia, the percentage with a diagnosis of preeclampsia/eclampsia with preexisting hypertension (which does not distinguish between severe and mild cases of the condition) was much greater for black women than for white women (22.5 vs. 12.3 percent), as was the percentage with eclampsia (1.7 vs. 1.4 percent) and severe preeclampsia (38.5 vs. 34.3 percent). At the same time, the percentage with mild or unspecified preeclampsia was much lower among black women than among white women (37.3 vs. 51.9 percent). The percentage of women with mild or unspecified preeclampsia was also lower for Hispanic and Asian/Pacific Islander women compared with white women (45–46 percent vs. 51.9 percent).

### Coexisting conditions and outcomes among deliveries with preeclampsia/eclampsia, 2014

Figure 4 displays the percentage of deliveries that resulted in C-section in 2014, according to the presence and type of preeclampsia/eclampsia.

Figure 4 Prevalence of C-section among deliveries with preeclampsia/eclampsia, compared with all other deliveries, 2014

Abbreviation: C-section, cesarean section

^a^ Records with ICD-9-CM diagnosis code 642.7, which indicates that preeclampsia or eclampsia was present with preexisting hypertension but does not specify the severity of the condition.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS), 2014

Figure 4 shows the percentage of cesarean sections among deliveries with preeclampsia/eclampsia in 2014 compared with all other deliveries and by type of preeclampsia or eclampsia. Total preeclampsia/eclampsia deliveries: 53.9%; all other deliveries: 31.7%. Eclampsia: 61.4%; severe preeclampsia: 62.1%; mild or unspecified preeclampsia: 44.3%; preeclampsia/eclampsia with pre-existing hypertension: 62.9%.

■ Over half of all deliveries with preeclampsia/eclampsia involved C-section.
  Among all deliveries with preeclampsia/eclampsia, 53.9 percent were by C-section, compared with 31.7 percent of deliveries not involving preeclampsia/eclampsia. The rate of C-section was over 60 percent for deliveries with a diagnosis of eclampsia, severe preeclampsia, and preeclampsia/eclampsia with preexisting hypertension. In comparison, the rate was 44.3 percent among deliveries with mild or unspecified preeclampsia.

Table 4 presents selected coexisting conditions for deliveries with preeclampsia/eclampsia, compared with all other deliveries, in 2014. The conditions displayed were chosen on the basis of prior literature and sorted according to their prevalence among deliveries with preeclampsia/eclampsia.

Table 4 Coexisting conditions among deliveries with preeclampsia/eclampsia, compared with all other deliveries, 2014

Coexisting condition | Preeclampsia/eclampsia, total | All other deliveries | Type of preeclampsia/eclampsia
Coexisting condition | Preeclampsia/eclampsia, total | All other deliveries | Eclampsia | Severe preeclampsia | Mild or unspecified preeclampsia | Preeclampsia/eclampsia with preexisting hypertension^a^
Total, N | 176,925 | 3,619,565 | 2,510 | 65,880 | 82,910 | 25,625
Coexisting condition, %
Anemia | 20.6 | 13.7 | 26.7 | 22.5 | 18.7 | 21.1
Obesity | 17.3 | 6.7 | 7.8 | 15.5 | 14.1 | 33.2
Gestational diabetes | 11.5 | 6.7 | 9.6 | 10.2 | 10.9 | 17.1
Multiple gestations | 6.0 | 1.7 | 4.8 | 7.4 | 5.3 | 4.6
Thyroid dysfunction | 4.9 | 3.6 | 3.2 | 5.4 | 4.1 | 6.4
Preexisting diabetes | 4.7 | 1.0 | 2.2 | 4.4 | 3.0 | 11.4
Cardiovascular disorders | 2.2 | 0.8 | 3.4 | 2.4 | 1.4 | 3.8

a Records with ICD-9-CM diagnosis code 642.7, which indicates that preeclampsia or eclampsia was present with preexisting hypertension but does not specify the severity of the condition.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS), 2014

■ Compared with all other deliveries, those with preeclampsia/eclampsia had a higher proportion of coexisting conditions.
  Coexisting conditions were more common among deliveries with preeclampsia/eclampsia than among all other deliveries. For example, obesity was a coexisting condition among 17.3 percent of deliveries with preeclampsia/eclampsia but among only 6.7 percent of all other deliveries.
  Among deliveries with preeclampsia/eclampsia, those with preexisting hypertension were more likely than those with other types of preeclampsia/eclampsia to have obesity (33.2 percent), gestational diabetes (17.1 percent), thyroid dysfunction (6.4 percent), preexisting diabetes (11.4 percent), and cardiovascular disorders (3.8 percent).
  Anemia occurred more frequently among deliveries with eclampsia (26.7 percent) than among deliveries with other types of preeclampsia/eclampsia (18.7 to 22.5 percent). Similarly, multiple gestations were more common among deliveries with severe preeclampsia (7.4 percent) than among deliveries with other types of preeclampsia/eclampsia (4.6 to 5.3 percent).

Table 5 presents select outcomes for deliveries with preeclampsia/eclampsia, compared with all other deliveries, in 2014. The conditions displayed were chosen on the basis of prior literature, grouped according to whether they were identified using procedure codes or diagnosis codes pertaining to the mother or infant, and sorted according to their prevalence among deliveries with preeclampsia/eclampsia.

Table 5 Outcomes among deliveries with preeclampsia/eclampsia, compared with all other deliveries, 2014

Delivery outcomes | Preeclampsia/eclampsia, total | All other deliveries | Type of preeclampsia/eclampsia
Delivery outcomes | Preeclampsia/eclampsia, total | All other deliveries | Eclampsia | Severe preeclampsia | Mild or unspecified preeclampsia | Preeclampsia/eclampsia with preexisting hypertension^a^
Total, N | 176,925 | 3,619,565 | 2,510 | 65,880 | 82,910 | 25,625
Delivery outcomes, number per 1,000 total deliveries
Procedures
Red blood cell or platelet transfusion | 42.7 | 10.5 | 79.7 | 63.5 | 26.9 | 36.9
Ventilation | 5.3 | 0.5 | 69.7 | 6.1 | 1.6 | 8.6
Hysterectomy | 1.6 | 1.0 | 6.0 | 1.7 | 0.9 | 2.9
Maternal diagnoses
Early onset of labor | 160.5 | 54.5 | 167.3 | 234.5 | 87.3 | 206.2
Placental abruption | 23.8 | 9.9 | 57.8 | 32.9 | 14.7 | 26.3
Disseminated intravascular coagulation | 9.9 | 2.6 | 33.9 | 15.3 | 5.7 | 7.8
Renal failure | 9.3 | 0.4 | 31.9 | 14.5 | 2.8 | 14.6
Heart failure | 5.4 | 1.6 | —^b^ | 7.2 | 3.1 | 8.2
Adult respiratory distress syndrome | 4.1 | 0.4 | 39.8 | 5.5 | 1.3 | 5.9
Peripartum cardiomyopathy | 2.9 | 0.4 | 6.0 | 3.0 | 1.1 | 8.4
Pulmonary edema | 1.4 | 0.1 | —^b^ | 2.2 | 0.5 | 2.1
Shock | 1.2 | 0.5 | 8.0 | 2.0 | 0.3 | 1.6
Puerperal cerebrovascular disorders | 1.2 | 0.3 | 12.0 | 1.4 | 0.5 | 1.8
Deep venous thrombosis | 1.1 | 0.6 | —^b^ | 1.5 | 0.7 | 1.2
Sepsis | 1.0 | 0.4 | —^b^ | 1.4 | 0.5 | 1.6
Pulmonary embolism | 0.8 | 0.2 | —^b^ | 1.2 | 0.5 | 1.0
Severe anesthesia complications | 0.4 | 0.1 | —^b^ | 0.8 | —^b^ | —^b^
In-hospital death | 0.3 | 0.0 | —^b^ | 0.4 | —^b^ | —^b^
Infant-related diagnoses on the maternal record
Poor fetal growth | 74.6 | 25.9 | 53.8 | 101.5 | 44.9 | 103.2
Intrauterine death | 11.6 | 6.2 | 27.9 | 15.5 | 6.1 | 18.0
Fetal distress | 1.8 | 1.2 | —^b^ | 1.7 | 1.8 | 1.6

a Records with ICD-9-CM diagnosis code 642.7, which indicates that preeclampsia or eclampsia was present with preexisting hypertension but does not specify the severity of the condition.

b Suppressed because of cell size <11 records.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS), 2014

■ The rates of procedural interventions and adverse maternal outcomes were higher among deliveries with preeclampsia/eclampsia than among all other deliveries.
  Procedural interventions were more common among deliveries with preeclampsia/eclampsia than among other types of deliveries: blood transfusion was 4 times more common (42.7 vs. 10.5 per 1,000 deliveries), ventilation was 10 times more common (5.3 vs. 0.5 per 1,000 deliveries), and hysterectomy was 50 percent more common (1.6 vs. 1.0 per 1,000 deliveries).
  Although rare, all the adverse maternal outcomes considered were more common among deliveries with preeclampsia/eclampsia than among other types of deliveries. This included renal failure, heart failure, and peripartum cardiomyopathy. These outcomes were also more common for each type of preeclampsia/eclampsia compared with all other deliveries, even for those with the least severe form of the condition, mild or unspecified preeclampsia.
■ Compared with all other deliveries, those with preeclampsia/eclampsia were more likely to have adverse infant outcomes.
  Adverse infant outcomes were more common among deliveries with preeclampsia/eclampsia than among other types of deliveries: poor fetal growth (74.6 vs. 25.9 per 1,000 deliveries), intrauterine death (11.6 vs. 6.2 per 1,000 deliveries), and fetal distress (1.8 vs. 1.2 per 1,000 deliveries).
  Among deliveries with preeclampsia/eclampsia, those with preexisting hypertension or severe preeclampsia had the highest proportion of poor fetal growth (over 100 per 1,000 deliveries). Intrauterine death was most prevalent among deliveries with eclampsia (27.9 per 1,000 deliveries).

## Data Source

The estimates in this Statistical Brief are based upon data from the Healthcare Cost and Utilization Project (HCUP) National Inpatient Sample (NIS), 2014. Historical data were drawn from the 2005–2013 National (Nationwide) Inpatient Sample (NIS).

## Definitions

### Diagnoses, procedures, ICD-9-CM, Clinical Classifications Software (CCS), and diagnosis-related groups (DRGs)

The principal diagnosis is that condition established after study to be chiefly responsible for the patient’s admission to the hospital. Secondary diagnoses are concomitant conditions that coexist at the time of admission or develop during the stay. All-listed diagnoses include the principal diagnosis plus these additional secondary conditions.

All-listed procedures include all procedures performed during the hospital stay, whether for definitive treatment or for diagnostic or exploratory purposes. The first-listed procedure is the procedure that is listed first on the discharge record. Inpatient data define this as the principal procedure—the procedure that is performed for definitive treatment rather than for diagnostic or exploratory purposes (i.e., the procedure that was necessary to take care of a complication).

ICD-9-CM is the International Classification of Diseases, Ninth Revision, Clinical Modification, which assigns numeric codes to diagnoses and procedures. There are approximately 14,000 ICD-9-CM diagnosis codes. There are approximately 4,000 ICD-9-CM procedure codes.

CCS categorizes ICD-9-CM diagnosis codes into a manageable number of clinically meaningful categories.^22^ This clinical grouper makes it easier to quickly understand patterns of diagnoses. CCS categories identified as Other typically are not reported; these categories include miscellaneous, otherwise unclassifiable diagnoses that may be difficult to interpret as a group.

DRGs comprise a patient classification system that categorizes patients into groups that are clinically coherent and homogeneous with respect to resource use. DRGs group patients according to diagnosis, type of treatment (procedure), age, and other relevant criteria. Each hospital stay has one assigned DRG.

### Case definition

The DRG and ICD-9-CM diagnosis codes used to identify delivery hospitalizations—overall and those with preeclampsia, eclampsia, and other types of hypertension complicating pregnancy, childbirth, and the puerperium—are shown in Tables 6 through 8.

Table 6 DRG codes defining delivery hospitalizations and delivery method

DRG January 2005–September 2007 | DRG October 2007–December 2013 | Description
370 | 765 | C-section w/CC/MCC
371 | 766 | C-section w/o CC/MCC
374 | 767 | Vaginal delivery w/sterilization and/or D&C
375 | 768 | Vaginal delivery w/other OR procedure
372 | 774 | Vaginal delivery w/CC/MCC
373 | 775 | Vaginal delivery w/o CC/MCC

Abbreviations: CC, complications or comorbidities; MCC, major complications or comorbidities; D&C, dilation and curettage; OR, operating room

Table 7 ICD-9-CM diagnosis codes defining preeclampsia/eclampsia and other types of hypertension complicating pregnancy, childbirth, and the puerperium

ICD-9-CM diagnosis code | Description | Type of hypertension^a^
642.0x | Benign essential hypertension complicating pregnancy, childbirth, and the puerperium | Preexisting
642.1x | Hypertension secondary to renal disease, complicating pregnancy, childbirth, and the puerperium | Preexisting
642.2x | Other pre-existing hypertension complicating pregnancy, childbirth, and the puerperium | Preexisting
642.3x | Transient hypertension of pregnancy | Gestational
642.9x | Unspecified hypertension complicating pregnancy, childbirth, and the puerperium | Unspecified
642.4x | Mild or unspecified pre-eclampsia | Preeclampsia/eclampsia
642.5x | Severe pre-eclampsia | Preeclampsia/eclampsia
642.6x | Eclampsia | Preeclampsia/eclampsia
642.7x | Pre-eclampsia or eclampsia superimposed on pre-existing hypertension | Preeclampsia/eclampsia

a Records with multiple codes were assigned to one category using the following hierarchy: preeclampsia/eclampsia, preexisting hypertension, gestational, unspecified.

Table 8 ICD-9-CM diagnosis codes defining types of preeclampsia/eclampsia

ICD-9-CM diagnosis code | Description | Type of preeclampsia/eclampsia^a^
642.40 | Mild or unspecified pre-eclampsia, unspecified as to episode of care or not applicable | Mild or unspecified preeclampsia
642.41 | Mild or unspecified pre-eclampsia, delivered, with or without mention of antepartum condition | Mild or unspecified preeclampsia
642.42 | Mild or unspecified pre-eclampsia, delivered, with mention of postpartum complication | Mild or unspecified preeclampsia
642.43 | Mild or unspecified pre-eclampsia, antepartum condition or complication | Mild or unspecified preeclampsia
642.44 | Mild or unspecified pre-eclampsia, postpartum condition or complication | Mild or unspecified preeclampsia
642.50 | Severe pre-eclampsia, unspecified as to episode of care or not applicable | Severe preeclampsia
642.51 | Severe pre-eclampsia, delivered, with or without mention of antepartum condition | Severe preeclampsia
642.52 | Severe pre-eclampsia, delivered, with mention of postpartum complication | Severe preeclampsia
642.53 | Severe pre-eclampsia, antepartum condition or complication | Severe preeclampsia
642.54 | Severe pre-eclampsia, postpartum condition or complication | Severe preeclampsia
642.60 | Eclampsia, unspecified as to episode of care or not applicable | Eclampsia
642.61 | Eclampsia, delivered, with or without mention of antepartum condition | Eclampsia
642.62 | Eclampsia, delivered, with mention of postpartum complication | Eclampsia
642.63 | Eclampsia, antepartum condition or complication | Eclampsia
642.64 | Eclampsia, postpartum condition or complication | Eclampsia
642.70 | Pre-eclampsia or eclampsia superimposed on pre-existing hypertension, unspecified as to episode of care or not applicable | Preeclampsia/eclampsia with preexisting hypertension
642.71 | Pre-eclampsia or eclampsia superimposed on pre-existing hypertension, delivered, with or without mention of antepartum condition | Preeclampsia/eclampsia with preexisting hypertension
642.72 | Pre-eclampsia or eclampsia superimposed on pre-existing hypertension, delivered, with mention of postpartum complication | Preeclampsia/eclampsia with preexisting hypertension
642.73 | Pre-eclampsia or eclampsia superimposed on pre-existing hypertension, antepartum condition or complication | Preeclampsia/eclampsia with preexisting hypertension
642.74 | Pre-eclampsia or eclampsia superimposed on pre-existing hypertension, postpartum condition or complication | Preeclampsia/eclampsia with preexisting hypertension

a Records with multiple codes were assigned to one category using the following hierarchy: eclampsia, severe preeclampsia, mild or unspecified preeclampsia, preeclampsia or eclampsia with preexisting hypertension.

ICD-9-CM diagnosis codes identifying coexisting conditions and maternal and infant outcomes are provided in Tables 9 and 10. Codes came from both Chapter 11 of the ICD manual on Complications of Pregnancy, Childbirth, and the Puerperium (ICD-9-CM codes 630–679), as well as from non-pregnancy-related chapters. Maternal outcomes are generally consistent with the definitions used by a prior study on severe obstetric morbidity.^23^

Table 9 ICD-9-CM diagnosis and CCS codes defining coexisting conditions at delivery

ICD-9-CM diagnosis code or CCS category | Description | Condition
648.2 | Anemia | Anemia
280 | Iron deficiency anemias | Anemia
281 | Other deficiency anemias | Anemia
282 | Hereditary hemolytic anemias | Anemia
283 | Acquired hemolytic anemias | Anemia
284 | Aplastic anemia and other bone marrow failure syndromes | Anemia
285 | Other and unspecified anemias | Anemia
648.5 | Congenital cardiovascular disorders | Cardiovascular disorders
648.6 | Other cardiovascular diseases | Cardiovascular disorders
745 | Bulbus cordis anomalies and anomalies of cardiac septal closure | Cardiovascular disorders
746 | Other congenital anomalies of heart | Cardiovascular disorders
747 | Other congenital anomalies of circulatory system | Cardiovascular disorders
390–392 | Acute rheumatic fever | Cardiovascular disorders
393–398 | Chronic rheumatic heart disease | Cardiovascular disorders
410–414 | Ischemic heart disease | Cardiovascular disorders
415–417 | Diseases of pulmonary circulation | Cardiovascular disorders
420–429 | Other forms of heart disease | Cardiovascular disorders
648.8 | Abnormal glucose tolerance | Gestational diabetes^a^
651 | Multiple gestation | Multiple gestations
V27.2 | Twins, both liveborn | Multiple gestations
V27.3 | Twins, one liveborn and one stillborn | Multiple gestations
V27.4 | Twins, both stillborn | Multiple gestations
V27.5 | Other multiple birth, all liveborn | Multiple gestations
V27.6 | Other multiple birth, some liveborn | Multiple gestations
V27.7 | Other multiple birth, all stillborn | Multiple gestations
649.1 | Obesity complicating pregnancy, childbirth, or the puerperium | Obesity
278.0 | Overweight and obesity | Obesity
V85.2 | Body Mass Index between 25–29, adult | Obesity
V85.3 | Body Mass Index between 30–39, adult | Obesity
V85.4 | Body Mass Index 40 and over, adult | Obesity
648.0 | Diabetes mellitus | Preexisting diabetes
CCS 49 | Diabetes mellitus without complications | Preexisting diabetes
CCS 50 | Diabetes mellitus with complications | Preexisting diabetes
648.1 | Thyroid dysfunction | Thyroid dysfunction
240–246 | Disorders of thyroid gland | Thyroid dysfunction

Abbreviation: CCS: Clinical Classifications Software

a Records with codes for both preexisting and gestational diabetes were categorized as preexisting diabetes.

Table 10 ICD-9-CM procedure codes defining maternal and infant outcomes at delivery

ICD-9-CM procedure code | Description | Outcome
Procedures
68.3 | Subtotal abdominal hysterectomy | Hysterectomy^a^
68.4 | Total abdominal hysterectomy | Hysterectomy^a^
68.5 | Vaginal hysterectomy | Hysterectomy^a^
68.6 | Radical abdominal hysterectomy | Hysterectomy^a^
68.7 | Radical vaginal hysterectomy | Hysterectomy^a^
68.8 | Pelvic evisceration | Hysterectomy^a^
68.9 | Other and unspecified hysterectomy | Hysterectomy^a^
99.04 | Transfusion of packed cells | Red blood cell or platelet transfusion
99.05 | Transfusion of platelets | Red blood cell or platelet transfusion
93.90 | Non-invasive mechanical ventilation | Ventilation^a^
96.01 | Insertion of nasopharyngeal airway | Ventilation^a^
96.02 | Insertion of oropharyngeal airway | Ventilation^a^
96.03 | Insertion of esophageal obturator airway | Ventilation^a^
96.04 | Insertion of endotracheal tube | Ventilation^a^
96.05 | Other intubation of respiratory tract | Ventilation^a^
96.7 | Other continuous invasive mechanical ventilation | Ventilation^a^
Maternal diagnoses
518.5 | Pulmonary insufficiency following trauma and surgery | Adult respiratory distress syndrome^a^
518.81 | Acute respiratory failure | Adult respiratory distress syndrome^a^
518.82 | Other pulmonary insufficiency, not elsewhere classified | Adult respiratory distress syndrome^a^
518.84 | Acute and chronic respiratory failure | Adult respiratory distress syndrome^a^
671.3 | Deep phlebothrombosis, antepartum | Deep venous thrombosis^a^
671.4 | Deep phlebothrombosis, postpartum | Deep venous thrombosis^a^
671.9 | Unspecified venous complication | Deep venous thrombosis^a^
451 | Phlebitis and thrombophlebitis | Deep venous thrombosis^a^
452 | Portal vein thrombosis | Deep venous thrombosis^a^
453 | Other venous embolism and thrombosis | Deep venous thrombosis^a^
666.3 | Postpartum coagulation defects | Disseminated intravascular coagulation^a^
286.6 | Defibrination syndrome | Disseminated intravascular coagulation^a^
286.9 | Other and unspecified coagulation defects | Disseminated intravascular coagulation^a^
644.2 | Early onset of delivery | Early onset of labor
669.4 | Other complications of obstetrical surgery and procedures | Heart failure^a^
427.5 | Cardiac arrest | Heart failure^a^
428.1 | Left heart failure | Heart failure^a^
428.21 | Systolic heart failure, acute | Heart failure^a^
428.31 | Diastolic heart failure, acute | Heart failure^a^
428.41 | Combined systolic and diastolic heart failure, acute | Heart failure^a^
997.1 | Cardiac complications | Heart failure^a^
674.5 | Peripartum cardiomyopathy | Peripartum cardiomyopathy
425 | Cardiomyopathy | Peripartum cardiomyopathy
641.2 | Abruptio placenta | Placental abruption
674.0 | Cerebrovascular disorders in the puerperium | Puerperal cerebrovascular disorders^a^
671.5 | Other phlebitis and thrombosis | Puerperal cerebrovascular disorders^a^
430 | Subarachnoid hemorrhage | Puerperal cerebrovascular disorders^a^
431 | Intracerebral hemorrhage | Puerperal cerebrovascular disorders^a^
432 | Other and unspecified intracranial hemorrhage | Puerperal cerebrovascular disorders^a^
433 | Occlusion and stenosis of precerebral arteries | Puerperal cerebrovascular disorders^a^
434 | Occlusion of cerebral arteries | Puerperal cerebrovascular disorders^a^
436 | Acute, but ill-defined, cerebrovascular disease | Puerperal cerebrovascular disorders^a^
437 | Other and ill-defined cerebrovascular disease | Puerperal cerebrovascular disorders^a^
997.2 | Peripheral vascular complications | Puerperal cerebrovascular disorders^a^
999.2 | Other vascular complications | Puerperal cerebrovascular disorders^a^
518.4 | Acute edema of lung, unspecified | Pulmonary edema^a^
428.1 | Left heart failure | Pulmonary edema^a^
673 | Obstetrical pulmonary embolism | Pulmonary embolism^a^
415.1 | Pulmonary embolism and infarction | Pulmonary embolism^a^
669.3 | Acute renal failure following labor and delivery | Renal failure^a^
584 | Acute renal failure | Renal failure^a^
038 | Septicemia | Sepsis^a^
995.1 | Sepsis | Sepsis^a^
995.2 | Severe sepsis | Sepsis^a^
668.0 | Pulmonary complications following administration of anesthetic or other sedation in labor and delivery | Severe anesthesia complications^a^
668.1 | Cardiac complications following administration of anesthetic or other sedation in labor and delivery | Severe anesthesia complications^a^
668.2 | Central nervous system complications following administration of anesthetic or other sedation in labor and delivery | Severe anesthesia complications^a^
669.1 | Shock during or following labor and delivery | Shock^a^
998.0 | Postoperative shock | Shock^a^
995.0 | Other anaphylactic shock | Shock^a^
995.4 | Shock due to anesthesia | Shock^a^
785.5 | Shock without mention of trauma | Shock^a^
Infant-related diagnoses on the maternal record
656.3 | Fetal distress | Fetal distress
656.4 | Intrauterine death | Intrauterine death
V27.1 | Single, stillborn | Intrauterine death
V27.3 | Twins, one liveborn and one stillborn | Intrauterine death
V27.4 | Twins, both stillborn | Intrauterine death
V27.6 | Other multiple birth, some liveborn | Intrauterine death
V27.7 | Other multiple birth, all stillborn | Intrauterine death
656.5 | Poor fetal growth | Poor fetal growth

a Definition consistent with measures of severe obstetric morbidity used by Kuklina EV, Meikle SF, Jamieson DJ, Whiteman MK, Barfield WD, Hills SD, . Severe Obstetric Morbidity in the United States: 1998–2005. Obstetrics and Gynecology. 2009;113(2 Pt 1): 293–9 .

### Types of hospitals included in the HCUP National (Nationwide) Inpatient Sample

The National (Nationwide) Inpatient Sample (NIS) is based on data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). The NIS includes obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded are long-term care facilities such as rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. Beginning in 2012, long-term acute care hospitals are also excluded. However, if a patient received long-term care, rehabilitation, or treatment for a psychiatric or chemical dependency condition in a community hospital, the discharge record for that stay will be included in the NIS.

### Unit of analysis

The unit of analysis is the hospital discharge (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the hospital multiple times in 1 year will be counted each time as a separate discharge from the hospital.

### Costs and charges

Total hospital charges were converted to costs using HCUP Cost-to-Charge Ratios based on hospital accounting reports from the Centers for Medicare & Medicaid Services (CMS).^24^ Costs reflect the actual expenses incurred in the production of hospital services, such as wages, supplies, and utility costs; charges represent the amount a hospital billed for the case. For each hospital, a hospital-wide cost-to-charge ratio is used. Hospital charges reflect the amount the hospital billed for the entire hospital stay and do not include professional (physician) fees. For the purposes of this Statistical Brief, costs are reported to the nearest hundred.

### Location of patients’ residence

Place of residence is based on the Urban Influence Codes (UIC) for the urban-rural classification scheme for U.S. counties:

- Large metropolitan areas with at least 1 million residents
- Small metropolitan areas with less than 1 million residents
- Micropolitan
- Nonmetropolitan and nonmicropolitan counties (rural, noncore)

### Median community-level income

Median community-level income is the median household income of the patient’s ZIP Code of residence. Income levels are separated into population-based quartiles with cut-offs determined using ZIP Code demographic data obtained from the Nielsen Company. The income quartile is missing for patients who are homeless or foreign.

### Payer

Payer is the expected payer for the hospital stay. To make coding uniform across all HCUP data sources, payer combines detailed categories into general groups:

- Medicare: includes patients covered by fee-for-service and managed care Medicare
- Medicaid: includes patients covered by fee-for-service and managed care Medicaid
- Private Insurance: includes Blue Cross, commercial carriers, and private health maintenance organizations (HMOs) and preferred provider organizations (PPOs)
- Uninsured: includes an insurance status of self-pay and no charge
- Other: includes Workers’ Compensation, TRICARE/CHAMPUS, CHAMPVA, Title V, and other government programs

Hospital stays billed to the State Children’s Health Insurance Program (SCHIP) may be classified as Medicaid, Private Insurance, or Other, depending on the structure of the State program. Because most State data do not identify patients in SCHIP specifically, it is not possible to present this information separately.

For this Statistical Brief, when more than one payer is listed for a hospital discharge, the first-listed payer is used.

### Region

Region is one of the four regions defined by the U.S. Census Bureau:

- Northeast: Maine, New Hampshire, Vermont, Massachusetts, Rhode Island, Connecticut, New York, New Jersey, and Pennsylvania
- Midwest: Ohio, Indiana, Illinois, Michigan, Wisconsin, Minnesota, Iowa, Missouri, North Dakota, South Dakota, Nebraska, and Kansas
- South: Delaware, Maryland, District of Columbia, Virginia, West Virginia, North Carolina, South Carolina, Georgia, Florida, Kentucky, Tennessee, Alabama, Mississippi, Arkansas, Louisiana, Oklahoma, and Texas
- West: Montana, Idaho, Wyoming, Colorado, New Mexico, Arizona, Utah, Nevada, Washington, Oregon, California, Alaska, and Hawaii

### Reporting of race and ethnicity

Data on Hispanic ethnicity are collected differently among the States and also can differ from the Census methodology of collecting information on race (White, Black, Asian/Pacific Islander, American Indian/Alaska Native, Other (including mixed race)) separately from ethnicity (Hispanic, non-Hispanic). State data organizations often collect Hispanic ethnicity as one of several categories that include race. Therefore, for multistate analyses, HCUP creates the combined categorization of race and ethnicity for data from States that report ethnicity separately. When a State data organization collects Hispanic ethnicity separately from race, HCUP uses Hispanic ethnicity to override any other race category to create a Hispanic category for the uniformly coded race/ethnicity data element, while also retaining the original race and ethnicity data. This Statistical Brief reports race/ethnicity for the following categories: Hispanic, non-Hispanic White, non-Hispanic Black, Asian/Pacific Islander, and non-Hispanic Other, including American Indian/Alaska Native.

## For More Information

For other information on pregnancy and childbirth, refer to the HCUP Statistical Briefs located at www.hcup-us.ahrq.gov/reports/statbriefs/sb_pregnancy.jsp.

For additional HCUP statistics, visit:

- HCUP Fast Stats at www.hcup-us.ahrq.gov/faststats/landing.jsp for easy access to the latest HCUP-based statistics for health information topics
- HCUPnet, HCUP’s interactive query system, at www.hcupnet.ahrq.gov/

For more information about HCUP, visit www.hcup-us.ahrq.gov/.

For a detailed description of HCUP and more information on the design of the National (Nationwide) Inpatient Sample (NIS), please refer to the following database documentation:

Agency for Healthcare Research and Quality. Overview of the National (Nationwide) Inpatient Sample (NIS). Healthcare Cost and Utilization Project (HCUP). Rockville, MD: Agency for Healthcare Research and Quality. Updated December 2016. www.hcup-us.ahrq.gov/nisoverview.jsp. Accessed January 31, 2017.

1 ≥140/90 mm Hg on two occasions 4 hours apart.

2 ≥300 mg/dL on a 24-hour urine protein test, protein:creatinine ratio of ≥0.3 mg/mmol, or urine protein dipstick reading >1 if quantitative analysis is not available.

3 American College of Obstetricians and Gynecologists. Hypertension in Pregnancy. Washington, DC: American College of Obstetricians and Gynecologists; 2013.

4 Ibid.

5 Mammaro A, Carrara S, Cavaliere A, Ermito S, Dinatale A, Pappalardo EM, . Hypertensive disorders of pregnancy. Journal of Prenatal Medicine. 2009;3(1):1–5.22439030

6 Ibid.

7 Report of the National High Blood Pressure Education Program Working Group on High Blood Pressure in Pregnancy. American Journal of Obstetrics & Gynecology. 2000;183:S1–S22.

8 Shahul S, Tung A, Minhaj M, Nizamuddin J, Wenger J, Mahmood E, . Racial disparities in comorbidities, complications, and maternal and fetal outcomes in women with preeclampsia/eclampsia. Hypertension in Pregnancy. 2015;34(4):506–15.26636247

9 Tanaka M, Jaamaa G, Kaiser M, Hills E, Soim A, Zhu M, . Racial disparity in hypertensive disorders of pregnancy in New York State: a 10-year longitudinal population-based study. American Journal of Public Health. 2007;97(1):163–70.17138931

10 Ibid.

11 Report of the National High Blood Pressure Education Program Working Group on High Blood Pressure in Pregnancy. American Journal of Obstetrics and Gynecology. 2000;183:S1–S22.

12 Kuklina EV, Ayala C, Callaghan WM. Hypertensive disorders and severe obstetric morbidity in the United States. Obstetrics and Gynecology. 2009;113(6):1299–306.19461426

13 Mammaro A, Carrara S, Cavaliere A, Ermito S, Dinatale A, Pappalardo EM, . Hypertensive disorders of pregnancy. Journal of Prenatal Medicine. 2009;3(1):1–5.22439030

14 Centers for Disease Control and Prevention. Data on Selected Pregnancy Complications in the United States. October 2016. www.cdc.gov/reproductivehealth/maternalinfanthealth/pregnancy-complications-data.htm. Accessed March 29, 2017.

15 Shahul et al., 2015. Op. cit.

16 D’Alton ME, Main EK, Menard MK, Levy BS. The National Partnership for Maternal Safety. Obstetrics and Gynecology. 2014;123:973–7.24785848

17 Ananth CV, Keyes KM, Wapner RJ. Pre-eclampsia rates in the United States, 1980–2010: age-period-cohort analysis. BMJ. 2013;347:f6564.24201165

18 Wallis AB, Saftlas AF, Hsia J, Atrash HK. Secular trends in the rates of preeclampsia, eclampsia, and gestational hypertension, United States, 1987–2004. American Journal of Hypertension. 2008;21:521–6.18437143

19 Kuklina EV, Meikle SF, Jamieson DJ, Whiteman MK, Barfield WD, Hills SD, . Severe obstetric morbidity in the United States: 1998–2005. Obstetrics and Gynecology. 2009;113(2 Pt 1):293–9.19155897

20 Callaghan WM, Creanga AA, Kuklina EV. Severe maternal morbidity among delivery and postpartum hospitalizations in the United States. Obstetrics and Gynecology. 2012;120(5):1029–36.23090519

21 The first three categories are defined by International Classification of Diseases, Ninth Revision, Clinical Modification (ICD-9-CM) diagnosis codes for mild or unspecified preeclampsia (642.4), severe preeclampsia (642.5), and eclampsia (642.6). These codes are used if preexisting hypertension was not present. The last category is defined by the code 642.7, which is used if preexisting hypertension was present with preeclampsia/eclampsia. However, records with this code lack detail on the severity of preeclampsia/eclampsia.

22 Agency for Healthcare Research and Quality. HCUP Clinical Classifications Software (CCS) for ICD-9-CM. Healthcare Cost and Utilization Project (HCUP). Rockville, MD: Agency for Healthcare Research and Quality. Updated October 2016. www.hcup-us.ahrq.gov/toolssoftware/ccs/ccs.jsp. Accessed January 31, 2017.

23 Kuklina EV, Meikle SF, Jamieson DJ, Whiteman MK, Barfield WD, Hills SD, . Severe obstetric morbidity in the United States: 1998–2005. Obstetrics and Gynecology. 2009;113(2 Pt 1):293–9.19155897

24 Agency for Healthcare Research and Quality. HCUP Cost-to-Charge Ratio (CCR) Files. Healthcare Cost and Utilization Project (HCUP). 2001–2014. Rockville, MD: Agency for Healthcare Research and Quality. Updated November 2016. www.hcup-us.ahrq.gov/db/state/costtocharge.jsp. Accessed January 31, 2017.