# Statistical Brief #219 Opioid-Related Inpatient Stays and Emergency Department Visits by State, 2009–2014

## Introduction

The opioid epidemic has reached alarming levels in many parts of the United States, affecting the lives of thousands of individuals and families. Between 2000 and 2014, the rate of overdose deaths involving opioids in the United States increased 200 percent.^1^ Between 2013 and 2014 alone, the rate of opioid overdose deaths increased 14 percent, from 7.9 to 9.0 per 100,000 population.^2^ Hospitalizations related to opioid misuse and dependence also have increased dramatically, with the rate of adult hospital inpatient stays per 100,000 population nearly doubling between 2000 and 2012.^3^ The substantial increase over the past decade in the misuse of opioids, which include prescription opioids and illicit opioids such as heroin, has been declared an “opioid epidemic” by the U.S. Department of Health and Human Services (HHS).^4^

In March 2015, HHS launched its Opioid Initiative to help reverse the increasing trend in opioid misuse, use disorder, and overdoses, and to support State efforts to address the opioid crisis.^5^ In response to HHS initiatives, in December 2016 the Agency for Healthcare Research and Quality released statistics on opioid-related hospital use by State in the interactive, online tool for the Healthcare Cost and Utilization Project (HCUP), HCUP Fast Stats.^6^

This HCUP Statistical Brief presents data from HCUP Fast Stats on the national rate of opioid-related hospital inpatient stays and emergency department (ED) visits from 2005 to 2014. Rates for more than 40 individual States and the District of Columbia are provided for 2014 along with changes in rates for the 6-year period from 2009 to 2014. Identification of opioid-related stays and visits is based on all-listed diagnoses and includes events associated with prescription opioids or illicit opioids such as heroin. Differences greater than 10 percent between estimates are noted in the text.

## Findings

Highlights

■ Between 2005 and 2014, the national rate of opioid-related inpatient stays increased 64.1 percent and the national rate of opioid-related emergency department (ED) visits increased 99.4 percent.
■ Across States, the rate of opioid-related inpatient stays in 2014 varied more than five-fold.
  ▪ The highest hospitalization rates occurred in Maryland (403.8 stays per 100,000 population), Massachusetts (393.7), and the District of Columbia (388.8).
  ▪ The lowest rates occurred in Iowa (72.7), Nebraska (78.6), and Wyoming (96.7).
■ The rate of opioid-related inpatient stays increased in most States between 2009 and 2014, with the greatest increases in Georgia (99.8 percent), North Carolina (70.9 percent), Oregon (60.2 percent), Washington (60.1 percent), and South Dakota (59.6 percent).
■ Across States, the rate of opioid-related ED visits in 2014 varied 10-fold.
  ▪ The highest rates occurred in Massachusetts (450.2 visits per 100,000 population), Maryland (300.7), and Rhode Island (298.3).
  ▪ The lowest rates occurred in Iowa (45.1), Nebraska (52.8), and South Dakota (63.1).
■ The rate of opioid-related ED visits increased in almost all States between 2009 and 2014, with the greatest increases in Ohio (106.4 percent), South Dakota (94.7 percent), and Georgia (85.2 percent).

### National rate of opioid-related inpatient stays and ED visits, 2005–2014

Figure 1 presents the national rate per 100,000 population of opioid-related inpatient stays and ED visits from 2005 through 2014.

Figure 1 National rate of opioid-related inpatient stays and emergency department visits, 2005–2014

Abbreviation: ED, emergency department

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), HCUP Fast Stats, Opioid-Related Hospital Use (http://www.hcup-us.ahrq.gov/faststats/landing.jsp) based on the HCUP National (Nationwide) Inpatient Sample (NIS) and the HCUP Nationwide Emergency Department Sample (NEDS)

Line graph that shows the rate of inpatient stays and emergency department visits per 100,000 population from 2005 to 2014. Inpatient stays: 2005, 136.8; 2006, 164.2; 2007, 159.0; 2008, 165.7; 2009, 181.4; 2010, 197.1; 2011, 207.8; 2012, 210.4; 2013, 213.7; 2014, 224.6, for a 64.1% cumulative increase and a 5.7% average annual growth rate. Emergency department visits: 2005, 89.1; 2006, 91.8; 2007, 82.6; 2008, 94.1; 2009, 107.4; 2010, 117.5; 2011, 131.2; 2012, 146.8; 2013, 166.2; 2014, 177.7, for a 99.4% cumulative increase and an 8.0% average annual growth rate.

■ Overall, the population rate of opioid-related inpatient stays was higher than the rate of opioid-related ED visits.
  Between 2005 and 2014, the population rate of opioid-related inpatient stays ranged from approximately 25 to 90 percent higher than the population rate of opioid-related ED visits.
■ The rate of increase for opioid-related ED visits was greater than that for opioid-related inpatient stays.
  Between 2005 and 2014, the rate of opioid-related inpatient stays increased 64.1 percent, from 136.8 per 100,000 population in 2005 to 224.6 per 100,000 population in 2014. This represented a 5.7 percent average annual growth rate. During this same time period, the rate of opioid-related ED visits increased 99.4 percent, from 89.1 per 100,000 population in 2005 to 177.7 per 100,000 population in 2014. This represented an 8.0 percent average annual growth rate.

### State rates of opioid-related inpatient stays, 2014

Figure 2 presents the rate per 100,000 population of opioid-related inpatient stays among 44 States and the District of Columbia that provided data in 2014. States are ordered according to their rate of opioid-related stays.

Figure 2 Rate of opioid-related inpatient stays by State, 2014

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), HCUP Fast Stats, Opioid-Related Hospital Use (http://www.hcup-us.ahrq.gov/faststats/landing.jsp) based on the HCUP National Inpatient Sample (NIS) and the HCUP State Inpatient Databases (SID)

Bar chart that shows the rate of opioid-related inpatient stays per 100,000 population by State. Maryland: 403.8; Massachusetts: 393.7; District of Columbia: 388.8; Rhode Island: 377.4; New York: 360.5; West Virginia: 349.3; Connecticut: 337.5; Washington: 313.2; Oregon: 307.0; Illinois: 306.6; Maine: 300.5; Ohio: 292.0; New Jersey: 288.7; Pennsylvania: 285.1; Kentucky: 280.4; Missouri: 261.4; Tennessee: 251.8; Minnesota: 247.2; Arizona: 247.0; Florida: 234.9; Michigan: 229.6; North Carolina: 220.0; New Mexico: 215.4; Montana: 213.6; Wisconsin: 212.8; Utah: 204.4; Vermont: 203.3; Indiana: 196.9; Colorado: 186.1; Nevada: 174.1; California: 168.3; Virginia: 166.6: North Dakota: 161.5; Louisiana: 156.5; Oklahoma: 155.1; Hawaii: 141.5; South Carolina: 141.5; Arkansas: 139.3; South Dakota: 128.3; Georgia: 119.5; Kansas: 104.3; Texas: 98.6; Wyoming: 96.7; Nebraska: 78.6; Iowa: 72.7. National rate of opioid-related stays per 100,000 population: 224.6.

■ The rate of opioid-related inpatient stays varied by a factor of 5.6 across 44 States and the District of Columbia in 2014.
  In 2014, the highest rate of opioid-related inpatient stays was in Maryland (403.8 stays per 100,000 population), which was 5.6 times higher than the lowest rate in Iowa (72.7). Following Maryland, the next highest rates of opioid-related inpatient stays were in Massachusetts (393.7), the District of Columbia (388.8), Rhode Island (377.4), and New York (360.5).
  The next lowest rates of opioid-related inpatient stays above Iowa were in Nebraska (78.6), Wyoming (96.7), Texas (98.6), and Kansas (104.3).

Figure 3 illustrates the percent change in the population rate of opioid-related inpatient stays from 2009 to 2014 among 43 States with data available in both years. States are ordered according to the percent change in their rate of opioid-related stays over the 6-year time period.

Figure 3 Cumulative percent change in the rate of opioid-related inpatient stays by State, 2009–2014

Note: Percent change could not be calculated for North Dakota or the District of Columbia because data were not available in 2009.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), HCUP Fast Stats, Opioid-Related Hospital Use (http://www.hcup-us.ahrq.gov/faststats/landing.jsp) based on the HCUP National (Nationwide) Inpatient Sample (NIS) and the HCUP State Inpatient Databases (SID)

Bar chart that shows the cumulative percent change in the rate of opioid-related inpatient stays per 100,000 population by State. Georgia: 99.8; North Carolina: 70.9; Oregon: 60.2; Washington: 60.1; South Dakota: 59.6; Pennsylvania: 58.9; Rhode Island: 54.6; Ohio: 52.0; Utah: 51.0; West Virginia: 49.4; Vermont: 47.4; Tennessee: 42.6; Massachusetts: 41.8; Arizona: 39.9; Florida: 39.3; Virginia: 38.0; Colorado: 36.1; Missouri: 34.4; Indiana: 32.2; South Carolina: 31.7; California: 30.0; Connecticut: 28.5; Hawaii: 27.8; Nevada: 26.3; New Mexico: 25.1; Montana: 24.5; Kentucky: 24.2; Arkansas: 23.8; Michigan: 21.4; Minnesota: 20.7; Wisconsin: 19.1; Oklahoma: 17.2; Wyoming: 16.8; Texas: 15.6; New Jersey: 14.2; Iowa: 11.5; Nebraska: 8.0; New York: 2.9; Maine: 2.7; Louisiana: −4.8; Illinois: −5.5; Maryland: −9.7; Kansas: −18.0. National average: 23.8.

■ Most States had an increase in the rate of opioid-related inpatient stays between 2009 and 2014, with Georgia having the largest increase at 99.8 percent.
  The vast majority of States (36 of 43 States) had an increase of at least 10 percent in the population-based rate of opioid-related inpatient stays between 2009 and 2014. The largest increases occurred in Georgia (99.8 percent increase), North Carolina (70.9 percent increase), Oregon (60.2 percent increase), Washington (60.1 percent increase), and South Dakota (59.6 percent increase).
  Six States had a relatively stable rate of opioid-related inpatient stays, with a 6-year change in rate (increase or decrease) of less than 10 percent: Nebraska, New York, Maine, Louisiana, Illinois, and Maryland. In 2014, New York, Illinois, and Maryland were among the top 10 States in rate of opioid-related inpatient stays, as shown in Figure 2.
  Only one State, Kansas, showed a substantial decrease in the rate of opioid-related hospital inpatient stays (18.0 percent decrease). In 2014, Kansas was among the States with the lowest rate of opioid-related inpatient stays (104.3 stays per 100,000 population, as shown in Figure 2).

### State rates of opioid-related ED visits, 2014

Figure 4 presents the rate per 100,000 population of opioid-related ED visits among 30 States that provided data in 2014. States are ordered according to their rate of opioid-related ED visits.

Figure 4 Rate of opioid-related emergency department visits by State, 2014

Abbreviation: ED, emergency department

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), HCUP Fast Stats, Opioid-Related Hospital Use (http://www.hcup-us.ahrq.gov/faststats/landing.jsp) based on the HCUP Nationwide Emergency Department Sample (NEDS) and the HCUP State Emergency Department Databases (SEDD)

Bar chart that shows the rate of opioid-related emergency department visits per 100,000 population by State. Massachusetts: 450.2; Maryland: 300.7; Rhode Island: 298.3; Ohio: 287.9; Connecticut: 254.6; Vermont: 223.7; Kentucky: 219.7; Arizona: 214.9; New Jersey: 214.5; New York: 185.8; Nevada: 183.1; North Carolina: 178.4; Utah: 173.2; Missouri: 169.4; Illinois: 169.1; Wisconsin: 156.8; California: 156.4; Indiana: 152.3; Tennessee: 145.6; Minnesota: 134.1; Hawaii: 112.3; Florida: 109.1; South Carolina: 105.8; North Dakota: 100.3; Georgia: 95.4; Kansas: 81.8; Arkansas: 71.6; South Dakota: 63.1; Nebraska: 52.8; Iowa: 45.1. National average: 177.7.

■ The rate of opioid-related ED visits varied 10-fold across 30 States in 2014.
  In 2014, the highest rate of opioid-related ED visits was in Massachusetts (450.2 visits per 100,000 population), which was approximately 10 times higher than the lowest rate in Iowa (45.1). Following Massachusetts, the next highest rates of opioid-related ED visits were in Maryland (300.7), Rhode Island (298.3), Ohio (287.9), and Connecticut (254.6).
  The next lowest rates above Iowa were in Nebraska (52.8), South Dakota (63.1), Arkansas (71.6), and Kansas (81.8).
  States with the highest opioid-related rate for inpatient stays also tended to have the highest opioid-related rate for ED visits: there was a strong, positive correlation (0.85) between States’ opioid-related population rates for inpatient stays and ED visits.

Figure 5 illustrates the percent change in the population rate of opioid-related ED visits from 2009 to 2014 among 27 States with data available in both years. States are ordered according to the percent change in their rate of opioid-related ED visits over the 6-year time period.

Figure 5 Cumulative percent change in the rate of opioid-related emergency department visits by State, 2009–2014

Abbreviation: ED, emergency department

Notes: Percent change could not be calculated for three States (Arkansas, Nevada, North Dakota) because rates were not available in 2009.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), HCUP Fast Stats, Opioid-Related Hospital Use (http://www.hcup-us.ahrq.gov/faststats/landing.jsp) based on the HCUP Nationwide Emergency Department Sample (NEDS) and the HCUP State Emergency Department Databases (SEDD)

Bar chart that shows the cumulative percent change in the rate of opioid-related emergency department visits per 100,000 population by State. Ohio: 106.4; South Dakota: 94.7; Georgia: 85.2; Minnesota: 83.3; Illinois: 82.7; Maryland: 81.0; Arizona: 79.7; California: 79.0; Missouri: 77.3; New York: 72.6; Massachusetts: 71.2; Rhode Island: 70.8; Wisconsin: 68.6; Kentucky: 65.6; North Carolina: 55.2; Hawaii: 54.7; Indiana: 54.6; Nebraska: 54.0; South Carolina: 50.3; New Jersey: 48.1; Tennessee: 43.4; Connecticut: 35.1; Florida: 32.3; Vermont: 18.8; Utah: 15.2; Kansas: 11.4; Iowa: −15.6. National average: 65.5.

■ Almost all States had an increase in the rate of opioid-related ED visits between 2009 and 2014, with Ohio having the largest increase at 106.4 percent.
  Almost all States (26 of 27 States) had an increase of at least 10 percent in the population rate of opioid-related ED visits between 2009 and 2014. The highest rate increases occurred in Ohio (106.4 percent increase), South Dakota (94.7 percent increase), and Georgia (85.2 percent increase).
  Only one State, Iowa, showed a substantial decrease in the rate of opioid-related ED visits (15.6 percent decrease). Iowa also had the lowest rate of opioid-related ED visits (45.1 visits per 100,000 population, as shown in Figure 4).

## Data Source

The estimates in this Statistical Brief are based upon data from the Healthcare Cost and Utilization Project (HCUP) 2005–2014 National (Nationwide) Inpatient Sample (NIS), 2005–2014 Nationwide Emergency Department Sample (NEDS), 2009–2014 State Inpatient Databases (SID), and 2009–2014 State Emergency Department Databases (SEDD). The statistics were generated from HCUP Fast Stats, a free, online tool that provides users with easy access to the latest HCUP-based statistics for health information topics, including opioid-related hospital use.^7^

Inpatient statistics from HCUP Fast Stats were available for the following 44 individual States and the District of Columbia in 2009 and 2014: Arizona, Arkansas, California, Colorado, Connecticut, District of Columbia (2014 only), Florida, Georgia, Hawaii, Illinois, Indiana, Iowa, Kansas, Kentucky, Louisiana, Maine, Maryland, Massachusetts, Michigan, Minnesota, Missouri, Montana, Nebraska, Nevada, New Jersey, New Mexico, New York, North Carolina, North Dakota (2014 only), Ohio, Oklahoma, Oregon, Pennsylvania, Rhode Island, South Carolina, South Dakota, Tennessee, Texas, Utah, Vermont, Virginia, Washington, West Virginia, Wisconsin, and Wyoming.

Emergency department (ED) statistics from HCUP Fast Stats were available for the following 30 individual States in 2009 and 2014: Arizona, Arkansas (2014 only), California, Connecticut, Florida, Georgia, Hawaii, Illinois, Indiana, Iowa, Kansas, Kentucky, Maryland, Massachusetts, Minnesota, Missouri, Nebraska, Nevada (2014 only), New Jersey, New York, North Carolina, North Dakota (2014 only), Ohio, Rhode Island, South Carolina, South Dakota, Tennessee, Utah, Vermont, and Wisconsin.

## Definitions

### Diagnoses and ICD-9-CM

The principal diagnosis is that condition established after study to be chiefly responsible for the patient’s admission to the hospital. Secondary diagnoses are concomitant conditions that coexist at the time of admission or develop during the stay. All-listed diagnoses include the principal diagnosis plus these additional secondary conditions.

ICD-9-CM is the International Classification of Diseases, Ninth Revision, Clinical Modification, which assigns numeric codes to diagnoses. There are approximately 14,000 ICD-9-CM diagnosis codes.

### Case definition

Opioid-related hospital use was identified using the following all-listed ICD-9-CM diagnosis codes:

- 304.00–304.02: Opioid type dependence (unspecified; continuous; episodic)
- 304.70–304.72: Combinations of opioid type drug with any other drug dependence (unspecified; continuous; episodic)
- 305.50–305.52: Opioid abuse (unspecified; continuous; episodic)
- 965.00–965.02; 965.09: Poisoning by opium (alkaloids), unspecified; heroin; methadone; other opiates and related narcotics
- 970.1: Poisoning by opiate antagonists
- E850.0–E850.2: Accidental poisoning by heroin; methadone; other opiates and related narcotics
- E935.0–E935.2: Heroin, methadone, other opiates and related narcotics causing adverse effects in therapeutic use
- E940.1: Opiate antagonists causing adverse effects in therapeutic use

It should be noted that ICD-9-CM diagnosis codes related to opioid dependence or abuse “in remission” were not used to identify opioid-related hospital use because remission does not indicate active use of opioids. Potential changes in the use of ICD-9-CM codes identifying opioid use cannot be isolated in these analyses.

### Types of hospitals included in the HCUP National (Nationwide) Inpatient Sample

The National (Nationwide) Inpatient Sample (NIS) is based on data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). The NIS includes obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded are long-term care facilities such as rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. Beginning in 2012, long-term acute care hospitals are also excluded. However, if a patient received long-term care, rehabilitation, or treatment for a psychiatric or chemical dependency condition in a community hospital, the discharge record for that stay will be included in the NIS.

### Types of hospitals included in the HCUP Nationwide Emergency Department Sample

The Nationwide Emergency Department Sample (NEDS) is based on data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). The NEDS includes specialty, pediatric, public, and academic medical hospitals. Excluded are long-term care facilities such as rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. Hospitals included in the NEDS have hospital-owned emergency departments (EDs) and no more than 90 percent of their ED visits resulting in admission.

### Types of hospitals included in HCUP State Inpatient Databases

This analysis used State Inpatient Databases (SID) limited to data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). Community hospitals include obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded for this analysis are long-term care facilities such as rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. However, if a patient received long-term care, rehabilitation, or treatment for a psychiatric or chemical dependency condition in a community hospital, the discharge record for that stay was included in the analysis.

### Types of hospitals included in HCUP State Emergency Department Databases

This analysis used State Emergency Department Databases (SEDD) limited to data from community hospitals with a hospital-owned emergency department. Community hospitals are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). Community hospitals include specialty, pediatric, public, and academic medical hospitals. Excluded for this analysis are long-term care facilities such as rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals.

### Unit of analysis

The unit of analysis for inpatient data is the hospital discharge (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the hospital multiple times in 1 year will be counted each time as a separate discharge from the hospital. Inpatient stays include those admitted through the emergency department (ED).

The unit of analysis for ED data is the ED visit, not a person or patient. This means that a person who is seen in the ED multiple times in 1 year will be counted each time as a separate visit in the ED. ED visits exclude those for patients admitted to the hospital, including patients transferred to other hospitals.

### Average annual percent change

Average annual percent change (i.e., growth rate) was calculated using the following formula:

Average annual percent change = [ ( (End value)/(Beginning value) )^(1)/(change in years)^ - 1 ] × 100

## For More Information

For other information on mental health and substance abuse, including opioids, refer to the HCUP Statistical Briefs located at http://www.hcup-us.ahrq.gov/reports/statbriefs/sb_mhsa.jsp.

For additional HCUP statistics, visit:

- HCUP Fast Stats at http://www.hcup-us.ahrq.gov/faststats/landing.jsp for easy access to the latest HCUP-based statistics for health information topics
- HCUPnet, HCUP’s interactive query system, at http://hcupnet.ahrq.gov/

For more information about HCUP, visit http://www.hcup-us.ahrq.gov/.

For a detailed description of HCUP and more information on the design of the National (Nationwide) Inpatient Sample, Nationwide Emergency Department Sample (NEDS), State Inpatient Databases (SID), or State Emergency Department Databases (SEDD), please refer to the following database documentation:

Agency for Healthcare Research and Quality. Overview of the National (Nationwide) Inpatient Sample (NIS). Healthcare Cost and Utilization Project (HCUP). Rockville, MD: Agency for Healthcare Research and Quality. Updated November 2015. http://www.hcup-us.ahrq.gov/nisoverview.jsp. Accessed February 17, 2016.

Agency for Healthcare Research and Quality. Overview of the Nationwide Emergency Department Sample (NEDS). Healthcare Cost and Utilization Project (HCUP). Rockville, MD: Agency for Healthcare Research and Quality. Updated January 2016. http://www.hcup-us.ahrq.gov/nedsoverview.jsp. Accessed February 17, 2016.

Agency for Healthcare Research and Quality. Overview of the State Inpatient Databases (SID). Healthcare Cost and Utilization Project (HCUP). Rockville, MD: Agency for Healthcare Research and Quality. Updated January 2016. http://www.hcup-us.ahrq.gov/sidoverview.jsp. Accessed February 17, 2016.

Agency for Healthcare Research and Quality. Overview of the State Emergency Department Databases (SEDD). Healthcare Cost and Utilization Project (HCUP). Rockville, MD: Agency for Healthcare Research and Quality. Updated January 2016. http://www.hcup-us.ahrq.gov/seddoverview.jsp. Accessed February 17, 2016.

* This Statistical Brief was revised to include opioid-related external cause of injury codes (E codes) for accidental poisoning and adverse effects (E850.0–E850.2, E935.0–E935.2, E940.1) in the calculation of the State-level rates. This affected the number of inpatient stays and emergency department (ED) visits involving opioids at the State level, resulting in an increase in the rates reported for all States. Consequently, some shifts occurred in the rankings among States, both in the 2014 rate and in the percent change in rate between 2009 and 2014. Additionally, Maine was added to the list of States reported with inpatient data. The numbers for national rates, both inpatient and ED, are unchanged as E codes were included originally for national estimates.

1 Rudd RA, Aleshire N, Zibbell JE, Gladden RM. Increases in drug and opioid overdose deaths—United States 2000–2014. Morbidity and Mortality Weekly Report. 2016;64:1374–82.

2 Ibid.

3 Owens PL, Barrett ML, Weiss AJ, Washington RE, Kronick R. Hospital Inpatient Utilization Related to Opioid Overuse Among Adults, 1993–2012. HCUP Statistical Brief #177. August 2014. Agency for Healthcare Research and Quality, Rockville, MD. https://www.hcup-us.ahrq.gov/reports/statbriefs/sb177-Hospitalizations-for-Opioid-Overuse.jsp. Accessed December 1, 2016.

4 U.S. Department of Health and Human Services. The U.S. Opioid Epidemic. Updated October 31, 2016. http://www.hhs.gov/opioids/about-the-epidemic/#us-epidemic. Accessed December 1, 2016.

5 U.S. Department of Health and Human Services. Opioid Abuse in the U.S. and HHS Actions to Address Opioid-Drug Related Overdoses and Deaths. March 26, 2015. https://aspe.hhs.gov/basic-report/opioid-abuse-us-and-hhs-actions-address-opioid-drug-related-overdoses-and-deaths. Accessed December 1, 2016.

6 Agency for Healthcare Research and Quality. HCUP Fast Stats Web site, Opioid-Related Hospital Use path. http://www.hcup-us.ahrq.gov/faststats/landing.jsp. Accessed January 26, 2017.

7 Agency for Healthcare Research and Quality. HCUP Fast Stats Web site, Opioid-Related Hospital Use path. http://www.hcup-us.ahrq.gov/faststats/landing.jsp. Accessed January 26, 2017.