# Statistical Brief #207 Sports-Related Emergency Department Visits and Hospital Inpatient Stays, 2013

## Introduction

With most Americans engaging in some type of sports or physical fitness activity each year,^1^ it is important to understand the types of injuries that are most commonly seen in the hospital and emergency department (ED) and which sports account for those injuries. Prevention of sports-related injuries is part of the current research agenda of the Centers for Disease Control and Prevention.^2^

Sports and recreation-related injuries are a common type of injury seen in hospital EDs.^3^ Sports-related ED visits are most common among older children and young adults and among males.^4^ One recent study reported that, among children aged 5–18 years, the number of sports-related injuries seen in the ED across 21 selected sports increased annually between 2001 and 2013.^5^ Of the four sports that accounted for three-fourths of these sports-related injuries, football and soccer showed a significant increase in injuries from 2001 to 2013 whereas basketball and baseball showed a significant decrease in injuries.^6^

Some sports-related injuries are severe enough to require hospitalization.^7^ Certain types of sports-related injuries, such as concussions and traumatic brain injuries (TBIs), have received increasing national attention. Between 2001 and 2009, there was an estimated 62 percent increase in sports-related TBI visits to the ED among children aged 19 years and under.^8^

This Healthcare Cost and Utilization Project (HCUP) Statistical Brief presents data on the most common sports activities associated with two types of hospital use in 2013: inpatient stays and ED visits that were discharged. We examine the most common sports-related ED and hospital inpatient use by patient sex and age. Finally, we present the types of injuries most frequently associated with sports-related ED visits and inpatient stays.

This Statistical Brief is based upon external cause of injury diagnosis codes (“E codes”) from the International Classification of Diseases, Ninth Revision, Clinical Modification (ICD-9-CM) coding system used for hospital inpatient and ED discharge records. E codes provide supplemental information about the nature of the hospital stay or ED visit, but they are not mandatory for reporting in all instances.^9^ Consequently, the counts in this Statistical Brief are likely lower than the actual volume of sports-related ED visits and inpatient stays. Analysis suggests that E codes are present for over 90 percent of HCUP inpatient and ED visit records with an injury diagnosis, although E codes for sports injuries in particular were not examined.^10^ Nonetheless, we do not expect that any undercounting of sports E codes generally would affect the patterns reported here for the most common types of sports and injuries.

## Findings

Highlights

■ The most common sports-related reasons for hospital use were bicycling, and walking, marching, and hiking. In 2013, bicycling accounted for 383,790 ED visits and 26,530 hospital stays. Walking, marching, and hiking resulted in 340,290 ED visits and 30,650 hospital stays.
■ Other top-ranked reasons for sport-related hospital use were basketball, football, school recess and summer camp, running, roller skating and skateboarding, soccer (ED only), baseball (ED only), downhill skiing and snowboarding (inpatient only), and horseback riding (inpatient only).
■ Among children, the most common sports-related reasons for hospital stays and ED visits included American tackle football (boys only), bicycle riding, and school recess and summer camp activities.
■ Bicycle riding was the most common sports-related reason for hospital stays and ED visits among males aged 18–64 years and females aged 18–44 years (inpatient only). Walking, marching, and hiking was the most common sports-related reason among males aged 65+ years and females aged 18–44 years (ED only) and 45+ years.
■ Sport-related hospital stays were primarily for fractures (59 percent of all sports-related stays) and intracranial injury (11 percent). Sports-related ED visits were for sprains (24 percent of all sports-related ED visits), fractures (21 percent), superficial injuries (18 percent), and open wounds (12 percent).

### Frequency of sports-related emergency department and hospital inpatient use, 2013

Figure 1 presents sports-related ED and hospital inpatient use categorized by the general type of sports activity in 2013. Activities are sorted by the total number of sports-related ED visits (discharged) and inpatient stays combined. Appendix A lists the specific sports that constitute each general type of sports activity category; details on specific sports are described later in this report.

Figure 1 Number of sports-related emergency department visits (discharged) and hospital inpatient stays by general type of sports activity, 2013

Abbreviation: ED, emergency department

Note: For fewer than 1% of ED visits and inpatient stays, more than one sports activity was identified. In these cases, the visit or stay is counted separately for each identified sports activity.

^a^ The “other specified sports and athletics” category includes boxing, wrestling, and martial arts.

^b^ The “other muscle strengthening exercises” category includes exercise machines, free weights, and Pilates.

^c^ The “other cardiorespiratory exercise” category includes calisthenics, aerobics, and circuit training.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS) and Nationwide Emergency Department Sample (NEDS), 2013

Figure 1 is a bar chart that shows the number of sports-related ED visits or inpatient stays by type of sports activity. Team or group sports: visits: 947,030; stays: 14,230. Individual sports: visits: 580,740; stays: 35,630. Walking and running: visits: 488,940; stays: 32,890. Sports, nonspecific: visits: 288,380; stays: 4,970. Ice and snow sports: visits: 134,770; stays: 7,170. Dancing and other rhythmic movement: visits: 113,330; stays: 1,770. Other specified sports and athletics: visits: 86,140; stays: 1,930. Water and water craft sports: visits: 77,610; stays: 3,750. Other muscle strengthening exercises: visits: 42,200; stays: 1,080. Climbing, rappelling, and jumping off: visits: 35,300; stays: 1,550. Other cardiorespiratory exercise: visits: 13,430; stays: 500.

Appendix A Number of emergency department visits (discharged) and hospital inpatient stays associated with sports-related activities, by general type of and specific sports activity, 2013

Sports activity | ED visits (discharged), n | Inpatient stays, n
All activities | 2,807,880 | 105,490
Walking and running | 488,940 | 32,890
Walking, marching, and hiking | 340,290 | 30,650
Running | 148,650 | 2,240
Water and water craft sports | 77,610 | 3,750
Swimming | 26,750 | 770
Springboard and platform diving | 8,340 | 860
Water polo | 1,000 | *
Water aerobics and water exercise | 120 | *
Underwater diving and snorkeling | 3,100 | 210
Rowing, canoeing, kayaking, rafting, and tubing | 5,340 | 170
Water skiing and wake boarding | 6,080 | 420
Surfing, windsurfing, and boogie boarding | 11,620 | 340
Water sliding | 3,180 | *
Water and watercraft | 12,090 | 900
Ice and snow sports | 134,770 | 7,170
Ice skating | 12,530 | 360
Ice hockey | 14,540 | 290
Snow (alpine) (downhill) skiing, snowboarding, sledding, tobogganing, and snow tubing | 91,210 | 5,320
Cross-country skiing | 620 | *
Ice and snow, other activity | 15,870 | 1,150
Climbing, rappelling, and jumping off | 35,300 | 1,550
Mountain climbing, rock climbing, and wall climbing | 3,380 | 370
Rappelling | 180 | *
BASE jumping | 740 | *
Bungee jumping | 100 | *
Hang gliding | 130 | *
Climbing, rappelling, and jumping off, other activity | 30,760 | 1,050
Dancing and other rhythmic movement | 113,330 | 1,770
Dancing | 22,880 | 480
Yoga | 1,010 | *
Gymnastics | 22,310 | 240
Trampoline | 43,050 | 810
Cheerleading | 18,490 | *
Dancing and other rhythmic movements, other activity | 5,574 | 150
Other sports and athletics played individually | 580,740 | 35,630
Roller skating (inline) and skateboarding | 143,780 | 4,600
Horseback riding | 18,830 | 2,220
Golf | 8,430 | 510
Bowling | 5,240 | 150
Bicycle riding (total) | 383,790 | 26,530
- Bicycle riding - Motor vehicle traffic | 49,230 | 6,810
- Bicycle riding - Nontraffic vehicle | 2,370 | 240
- Bicycle riding - Other bicycle accident | 332,190 | 19,470
Jumping rope | 1,490 | *
Nonrunning track and field events | 1,070 | *
Other sports and athletics played individually, other activity | 18,110 | 1,540
Other sports and athletics played as a team or group | 947,030 | 14,230
American tackle football | 211,220 | 2,830
American flag or touch football | 10,280 | 150
Rugby | 6,640 | 140
Baseball | 113,420 | 1,370
Lacrosse and field hockey | 15,640 | 170
Soccer | 128,950 | 1,820
Basketball | 268,580 | 2,020
Volleyball (beach) (court) | 27,870 | 170
Physical games generally associated with school recess, summer camp, and children | 150,150 | 5,140
Other sports and athletics played as a team or group, other activity | 14,270 | 400
Other specified sports and athletics | 86,140 | 1,930
Boxing | 6,390 | 110
Wrestling | 40,920 | 490
Racquet and hand sports | 9,800 | 150
Frisbee | 2,830 | *
Martial arts | 15,450 | 160
Other specified sports and athletics activity | 10,750 | 940
Other cardiorespiratory exercise | 13,430 | 500
Exercise machines primarily for cardiorespiratory conditioning | 4,900 | 230
Calisthenics | 1,420 | *
Aerobic and step exercise | 1,800 | *
Circuit training | 220 | *
Obstacle course | 590 | *
Grass drills | 150 | *
Cardiorespiratory exercise, other activity | 4,370 | 200
Other muscle strengthening exercises | 42,200 | 1,080
Exercise machines primarily for muscle strengthening | 3,560 | 120
Push-ups, pull-ups, sit-ups | 4,300 | *
Free weights | 21,300 | 300
Pilates | 160 | *
Other muscle strengthening exercises, other activity | 12,890 | 580
Sports activity, not elsewhere classified | 288,380 | 4,970

Abbreviations: BASE, building, antenna, span, earth; ED, Emergency department

Note: For fewer than 1% of ED visits and inpatient stays, more than one sports activity was identified. In these cases, the visit or stay is counted separately for each identified sports activity.

* Indicates fewer than 100 discharge records.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS) and Nationwide Emergency Department Sample (NEDS), 2013

■ Sports-related ED visits (discharged) were far more common than sports-related inpatient stays.
  In 2013 there were 2,807,880 ED visits and 105,490 hospital inpatient stays related to sports activities. Sports-related ED visits were 27 times more frequent than sports-related inpatient stays. In contrast, ED visits for any reason were only 3 times more common than inpatient stays for any reason (data not shown).
■ Team or group sports, individual sports, and walking and running constituted the majority of sports-related ED visits (discharged) and inpatient stays in 2013.
  In 2013, 71.8 percent of sports-related ED visits and 78.5 percent of sports-related inpatient stays were associated with one of three general types of sports activities: team or group sports (such as football, baseball, basketball, and soccer), individual sports (such as bicycle riding, roller skating, horseback riding, and golf), and walking and running.

Figure 2 ranks these general activities by the percentage of sports-related ED visits and hospital inpatient stays that each sport constitutes.

Figure 2 Percentage of sports-related emergency department visits (discharged) and hospital inpatient stays by general type of sports activity, 2013

Abbreviation: ED, emergency department

Note: For fewer than 1% of ED visits and inpatient stays, more than one sports activity was identified. In these cases, the visit or stay is counted separately for each identified sports activity.

^a^ The “other specified sports and athletics” category includes boxing, wrestling, and martial arts.

^b^ The “other muscle strengthening exercises” category includes exercise machines, free weights, and Pilates.

^c^ The “other cardiorespiratory exercise” category includes calisthenics, aerobics, and circuit training.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS) and Nationwide Emergency Department Sample (NEDS), 2013

Figure 2 is a bar chart that shows the percentage of sports-related ED visits or inpatient stays by type of sports activity. Team or group sports: visits: 33.7; stays: 13.5. Individual sports: visits: 20.7; stays: 33.8. Walking and running: visits: 17.4; stays 31.2. Sports, nonspecific: visits: 10.3; stays: 4.7. Ice and snow sports: visits: 4.8; stays: 6.8. Dancing and other rhythmic movement: visits: 4.0; stays: 1.7. Other specified sports and athletics: visits: 3.1; stays: 1.8. Water and water craft sports: visits: 2.8; stays: 3.6. Other muscle strengthening exercises: visits: 1.5; stays: 1.0. Climbing, rappelling, and jumping off: visits: 1.3; stays: 1.5. Other cardiorespiratory exercise: visits: 0.5; stays: 0.5.

■ In 2013, about one-third of sports-related ED visits (discharged) involved team or group sports, whereas individual sports, and walking and running each constituted about one-third of sports-related inpatient stays.
  Team or group sports—such as football, basketball, and soccer—constituted one-third (33.7 percent) of all sports-related ED visits but only 13.5 percent of sports-related inpatient stays. The reverse was true for individual sports—such as bicycle riding and roller skating—and walking and running. Individual sports accounted for 33.8 percent of sports-related inpatient stays but only 20.7 percent of sports-related ED visits. Walking and running constituted 31.2 percent of sports-related inpatient stays but only 17.4 percent of sports-related ED visits.

### Most common specific sports activities associated with ED and hospital inpatient use, 2013

Table 1 presents the 10 most common specific sports activities associated with ED visits (discharged) and hospital inpatient stays in 2013.

Table 1 Top 10 specific sports activities associated with emergency department visits (discharged) and hospital inpatient stays, 2013

Specific sports activity | ED visits (discharged) | | | Inpatient stays
Specific sports activity | Rank | n | % of all sports-related visits | Rank | n | % of all sports-related stays
All sports activities | | 2,807,880 | 100.0 | | 105,490 | 100.0
Bicycle riding | 1 | 383,790 | 13.7 | 2 | 26,530 | 25.1
Walking, marching, and hiking | 2 | 340,290 | 12.1 | 1 | 30,650 | 29.1
Other unspecified sports activity^a^ | 3 | 288,380 | 10.3 | 5 | 4,970 | 4.7
Basketball | 4 | 268,580 | 9.6 | 10 | 2,020 | 1.9
American tackle football | 5 | 211,220 | 7.5 | 7 | 2,830 | 2.7
School recess and summer camp^b^ | 6 | 150,150 | 5.3 | 4 | 5,140 | 4.9
Running | 7 | 148,650 | 5.3 | 8 | 2,240 | 2.1
Roller skating and skateboarding | 8 | 143,780 | 5.1 | 6 | 4,600 | 4.4
Soccer | 9 | 128,950 | 4.6
Baseball | 10 | 113,420 | 4.0
Downhill skiing and snowboarding^c^ | | | | 3 | 5,320 | 5.0
Horseback riding | | | | 9 | 2,220 | 2.1

Abbreviation: ED, emergency department

Note: For fewer than 1% of ED visits and inpatient stays, more than one sports activity was identified. In these cases, the visit or stay is counted separately for each identified sports activity.

a More specific information about the sports activity is not available in the ICD-9-CM diagnosis codes in this category.

b Physical games generally associated with school recess, summer camp, and children.

c Snow (alpine) (downhill) skiing, snowboarding, sledding, tobogganing, and snow tubing.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS) and Nationwide Emergency Department Sample (NEDS), 2013

■ Bicycle riding and walking, marching, and hiking were the two most common sports activities associated with both ED visits (discharged) and inpatient stays in 2013.
  The following were the most common specific reasons for a sports-related ED visit in 2013:
  - Bicycle riding (13.7 percent of all sports-related ED visits)
  - Walking, marching, and hiking (12.1 percent)
  - Basketball (9.6 percent)
  - American tackle football (7.5 percent)
  The following were the most common reasons for a sports-related inpatient stay in 2013:
  - Walking, marching, and hiking (29.1 percent of all sports-related inpatient stays)
  - Bicycle riding (25.1 percent)
  - Downhill skiing and snowboarding (5.0 percent)
  - School recess and summer camp activities (4.9 percent)
  Soccer and baseball were among the 10 most common reasons for sports-related ED visits but not for inpatient stays. Downhill skiing and snowboarding, and horseback riding were among the 10 most common reasons for sports-related inpatient stays but not for ED visits.

Table 2 focuses on ED visits and presents the five most common sports activities associated with ED visits for males and females across age groups in 2013.

Table 2 Top five sports activities associated with emergency department visits (discharged), by patient sex and age group, 2013

Rank | ED visits for males | | | ED visits for females
Rank | Sports activity | n | %^a^ | Sports activity | n | %^a^
Ages <18 years | | 1,018,630 | 100.0 | Ages <18 years | 516,780 | 100.0
1 | American tackle football | 167,350 | 16.4 | School recess and summer camp^c^ | 66,230 | 12.8
2 | Other unspecified sports activity^b^ | 138,470 | 13.6 | Bicycle riding | 50,870 | 9.8
3 | Bicycle riding | 120,170 | 11.8 | Other unspecified sports activity^b^ | 48,330 | 9.4
4 | Basketball | 118,140 | 11.6 | Running | 40,520 | 7.8
5 | School recess and summer camp^c^ | 76,920 | 7.6 | Soccer | 40,320 | 7.8
Ages 18–44 years | | 602,410 | 100.0 | Ages 18–44 years | 255,490 | 100.0
1 | Bicycle riding | 96,570 | 16.0 | Walking, marching, and hiking | 65,330 | 25.6
2 | Basketball | 96,180 | 16.0 | Bicycle riding | 29,310 | 11.5
3 | Other unspecified sports activity^b^ | 73,220 | 12.2 | Other unspecified sports activity^b^ | 16,200 | 6.3
4 | Walking, marching, and hiking | 42,920 | 7.1 | Running | 16,180 | 6.3
5 | Roller skating and skateboarding | 37,780 | 6.3 | Roller skating and skateboarding | 14,480 | 5.7
Ages 45–64 years | | 150,850 | 100.0 | Ages 45–64 years | 122,780 | 100.0
1 | Bicycle riding | 52,680 | 34.9 | Walking, marching, and hiking | 60,200 | 49.0
2 | Walking, marching, and hiking | 32,250 | 21.4 | Bicycle riding | 19,360 | 15.8
3 | Other unspecified sports activity^b^ | 7,740 | 5.1 | Running | 5,140 | 4.2
4 | Basketball | 6,130 | 4.1 | Downhill skiing and snowboarding^d^ | 4,260 | 3.5
5 | Downhill skiing and snowboarding^d^ | 5,990 | 4.0 | Roller skating and skateboarding | 3,470 | 2.8
Ages 65+ years | | 57,170 | 100.0 | Ages 65+ years | 83,680 | 100.0
1 | Walking, marching, and hiking | 31,060 | 54.3 | Walking, marching, and hiking | 66,730 | 79.7
2 | Bicycle riding | 10,400 | 18.2 | Bicycle riding | 4,400 | 5.3
3 | Golf | 2,010 | 3.5 | Ice and snow, other activity | 1,200 | 1.4
4 | Downhill skiing and snowboarding^d^ | 1,580 | 2.8 | Running | 1,090 | 1.3
5 | Running | 1,270 | 2.2 | Dancing | 1,020 | 1.2

Abbreviation: ED, emergency department

Notes: For fewer than 1% of ED visits, more than one sports activity was identified. In these cases, the visit is counted separately for each identified sports activity.

a The tabled % value refers to the percentage of all sports-related ED visits for the specified sex-age group.

b More specific information about the sports activity is not available in the ICD-9-CM diagnosis codes in this category.

c Physical games generally associated with school recess, summer camp, and children.

d Snow (alpine) (downhill) skiing, snowboarding, sledding, tobogganing, and snow tubing.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Emergency Department Sample (NEDS), 2013

■ Among children and younger adults, males had about twice as many sports-related ED visits (discharged) as did females.
  There were twice as many sports-related ED visits among male children (just over 1 million) as among female children (approximately 517,000). This pattern held among 18–44-year-olds as well—there were over 600,000 sports-related ED visits among males compared with approximately 255,000 visits among females.
  Among 45–64-year-olds, the number of sports-related ED visits for males (150,850) and females (122,780) were more similar. In the oldest age group, females had more sports-related ED visits (83,680) than did males (57,170). This sex differential held even when adjusting for the relatively larger population of older females, with a rate of 333.3 sports-related ED visits per 100,000 female population aged 65 years and older versus 291.7 per 100,000 male population aged 65 years and older (data not shown).
■ Among children, the most common sports-related reasons for ED visits (discharged) were American tackle football (males only), school recess and summer camp activities, and bicycle riding.
  Among male children under 18 years, American tackle football accounted for over 16 percent of all sports-related ED visits. Bicycle riding, and school recess and summer camp activities were among the five most common sports activities associated with ED visits for both male and female children. For male children, basketball also was a common reason for sports-related ED visits (constituting 11.6 percent of all sports-related ED visits) whereas running and soccer were common for female children (each constituting 7.8 percent of visits).
■ Among males aged 18–64 years, bicycle riding was the most common sports-related reason for ED visits (discharged).
  Bicycle riding was the most common sports-related reason for ED visits among adult males aged 18–44 years (96,570 visits) and aged 45–64 years (52,680 visits). Among 18–44-year-old males, basketball was a close second with 96,180 visits.
  Among adult females of all ages, walking, marching, and hiking was by far the most common sports-related reason for ED visits—accounting for about a quarter of sports-related ED visits for 18–44-year-olds, nearly half of 45–64-year-old visits, and over three-quarters of sports-related ED visits for women aged 65 years and older. Bicycling was the second most common sports-related reason for ED visits among females but was far less common, especially in the older age groups.
  The following were other common reasons for sports-related ED visits among adults:
  - Running—females of all ages
  - Downhill skiing and snowboarding—males aged 45 years and older and females aged 45–64 years
  - Roller skating and skateboarding—males and females aged 18–44 years and females aged 45–64 years
  Among those aged 65 years and older, the most common sports-related reasons for ED visits included golf for males and dancing for females.

Table 3 focuses on hospital inpatient stays and presents the five most common sports activities associated with hospital stays for males and females across age groups in 2013.

Table 3 Top five sports activities associated with hospital inpatient stays, by patient sex and age group, 2013

Rank | Inpatient stays for males | | | Inpatient stays for females
Rank | Sports activity | n | %^a^ | Sports activity | n | %^a^
Ages <18 years | | 18,860 | 100.0 | Ages <18 years | 6,990 | 100.0
1 | Bicycle riding | 3,850 | 20.4 | School recess and summer camp^b^ | 2,070 | 29.6
2 | School recess and summer camp^b^ | 2,680 | 14.2 | Bicycle riding | 1,100 | 15.7
3 | Other unspecified sports activity^c^ | 2,300 | 12.2 | Other unspecified sports activity^c^ | 430 | 6.2
4 | American tackle football | 2,050 | 10.9 | Downhill skiing and snowboarding^d^ | 350 | 5.0
5 | Roller skating and skateboarding | 1,570 | 8.3 | Roller skating and skateboarding | 330 | 4.7
Ages 18–44 years | | 21,090 | 100.0 | Ages 18–44 years | 6,570 | 100.0
1 | Bicycle riding | 6,730 | 31.9 | Bicycle riding | 1,580 | 24.0
2 | Downhill skiing and snowboarding^d^ | 1,630 | 7.7 | Walking, marching, and hiking | 1,110 | 16.9
3 | Other unspecified sports activity^c^ | 1,540 | 7.3 | Roller skating and skateboarding | 600 | 9.1
4 | Roller skating and skateboarding | 1,530 | 7.3 | Downhill skiing and snowboarding^d^ | 500 | 7.6
5 | Walking, marching, and hiking | 1,510 | 7.2 | Horseback riding | 390 | 5.9
Ages 45–64 years | | 14,540 | 100.0 | Ages 45–64 years | 8,550 | 100.0
1 | Bicycle riding | 7,510 | 51.7 | Walking, marching, and hiking | 3,380 | 39.5
2 | Walking, marching, and hiking | 2,620 | 18.0 | Bicycle riding | 2,220 | 26.0
3 | Downhill skiing and snowboarding^d^ | 920 | 6.3 | Downhill skiing and snowboarding^d^ | 650 | 7.6
4 | Horseback riding | 420 | 2.9 | Horseback riding | 600 | 7.0
5 | Other unspecified sports activity^b^ | 260 | 1.8 | Roller skating and skateboarding | 240 | 2.8
Ages 65+ years | | 11,510 | 100.0 | Ages 65+ years | 17,330 | 100.0
1 | Walking, marching, and hiking | 6,580 | 57.2 | Walking, marching, and hiking | 14,750 | 85.1
2 | Bicycle riding | 2,800 | 24.3 | Bicycle riding | 710 | 4.1
3 | Downhill skiing and snowboarding^d^ | 330 | 2.9 | Ice and snow, other activity | 250 | 1.4
4 | Ice and snow, other activity | 230 | 2.0 | Other muscle strengthening | 190 | 1.1
5 | Horseback riding | 220 | 1.9 | Horseback riding | 150 | 0.9

Notes: For fewer than 1% of inpatient stays, more than one sports activity was identified. In these cases, the stay is counted separately for each identified sports activity.

a The tabled % value refers to the percentage of all sports-related inpatient stays for the specified sex-age group.

b Physical games generally associated with school recess, summer camp, and children.

c More specific information about the sports activity is not available in the ICD-9-CM diagnosis codes in this category.

d Snow (alpine) (downhill) skiing, snowboarding, sledding, tobogganing, and snow tubing.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS), 2013

■ As shown for sports-related ED visits, males accounted for more sports-related inpatient stays than females in all age groups except for those aged 65 years and older.
  There were more than twice as many sports-related inpatient stays among male children compared with female children (18,860 vs. 6,990) and more than 3 times as many sports-related inpatient stays for males aged 18–44 years compared with females in that age group (21,090 vs. 6,570).
  Similarly, among 45–64-year-olds, there were more sports-related inpatient stays for males (14,540) than for females (8,550). In the oldest age group, females had more sports-related inpatient stays than did males (17,330 vs. 11,510). This sex differential held even when adjusting for the relatively larger population of older females, with a rate of 69.0 sports-related inpatient stays per 100,000 female population aged 65 years and older versus 58.7 per 100,000 male population aged 65 years and older (data not shown).
■ Among children, the most common sports-related reasons for hospital inpatient stays were bicycle riding, and school recess and summer camp activities
  Among children under 18 years, bicycle riding, and school recess and summer camp activities were the two most common sports associated with inpatient stays for both males and females. For males, bicycling ranked first, accounting for over 20 percent of sports-related inpatient stays. For females, school recess and summer camp activities ranked first, accounting for 30 percent of sports-related inpatient stays.
  Among male children, American tackle football was common among sports-related inpatient stays (10.9 percent) whereas downhill skiing and snowboarding was in the top 5 for females (5.0 percent). Roller skating and skateboarding also was in the five sports activities most frequently associated with inpatient stays for both male and female children.
■ Among adult males aged 18–64 years, bicycle riding was the most common sports-related reason for hospital inpatient stays.
  Bicycle riding was the most common sports-related reason for inpatient stays among young and middle-aged adult males, constituting nearly a third of all sports-related inpatient stays for 18–44-year-olds (31.9 percent) and over half of sports-related stays for 45–64-year-olds (51.7 percent). Bicycle riding was the second most common reason for sports-related inpatient stays among males aged 65 years and older, after walking, marching, and hiking, which accounted for over half of all sports-related stays in this age group (57.2 percent).
  Among females aged 18–44 years, bicycle riding was the number one reason for sports-related inpatient stays, constituting nearly a quarter (24.0 percent) of stays. For females aged 45–64 years, bicycle riding was the second most common reason for sports-related inpatient stays (26.0 percent), after walking, marching, and hiking, which accounted for 39.5 percent of sports-related stays.
  The following are other common reasons for sports-related inpatient stays among adults:
  - Downhill skiing and snowboarding—which accounted for 6–8 percent of sports-related stays for adult males and females aged 18–64 years
  - Horseback riding—adult females of all ages and males aged 45 years and older
  - Roller skating and skateboarding—males and females aged 18–44 years and females aged 45–64 years

### Most common injuries associated with sports-related ED and hospital inpatient use, 2013

Figure 3 presents information on the types of injuries associated with sports-related ED visits (discharged) and hospital inpatient stays in 2013.

Figure 3 Primary type of injurya associated with sports-related emergency department visits (discharged) and hospital inpatient stays, 2013

Abbreviation: ED, emergency department

Note: For fewer than 1% of ED visits and inpatient stays, more than one sports activity was identified. In these cases, the visit or stay is counted separately for each identified sports activity.

^a^ Type of injury was based on the Clinical Classifications Software (CCS) principal diagnosis.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS) and Nationwide Emergency Department Sample (NEDS), 2013

Figure 3 is a two-part pie chart—one part shows the percentage of discharged ED visits and the other shows the percentage of inpatient stays, both broken out by primary type of injury. Emergency department visits: sprain: 24; fracture: 21; superficial injury: 18; other injury: 14; open wound: 12; other diagnosis: 6; intracranial injury: 5. Inpatient stays: fracture: 59; other diagnosis: 14; intracranial injury: 11; other injury: 10; crushing injury: 6.

■ The most common injuries for sports-related ED visits (discharged) were sprains, fractures, and superficial injuries, accounting for nearly two-thirds of all visits (63 percent). Fractures and intracranial injury accounted for 70 percent of all sports-related inpatient stays.
  The most common types of injuries among sports-related ED visits were sprains (24 percent), fractures (21 percent), and superficial injuries (18 percent). Other common, specific types of injuries included open wounds (12 percent) and intracranial injuries (5 percent).
  The most common types of injuries among sports-related inpatient stays were fractures (59 percent), intracranial injuries (11 percent), and crushing injuries (6 percent).
  Other noninjury diagnoses reported frequently as primary reasons for sports-related ED visits included: other nontraumatic joint disorders, spondylosis (back problems), headache, syncope (fainting), and nonspecific chest pain. Other noninjury diagnoses reported frequently as primary reasons for sports-related inpatient stays included: skin or tissue infection, other connective tissue disease, septicemia, syncope, spondylosis, and cardiac dysrhythmias.

Figure 4 focuses on ED visits and provides additional details on the types of injuries for the 10 most common sports activities associated with ED visits in 2013.

Figure 4 Primary type of injurya among the 10 most common sports activities associated with emergency department visits (discharged), 2013

Abbreviation: ED, emergency department

Note: For fewer than 1% of ED visits, more than one sports activity was identified. In these cases, the visit is counted separately for each identified sports activity.

^a^ Type of injury was based on the Clinical Classifications Software (CCS) principal diagnosis.

^b^ More specific information about the sports activity is not available in the ICD-9-CM diagnosis codes in this category.

^c^ Physical games generally associated with school recess, summer camp, and children.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Emergency Department Sample (NEDS), 2013

Figure 4 is a stacked bar chart that shows the percentage of discharged ED visits by primary type of injury among the 10 most common sports activities. Bicycle riding: sprain: 11; fracture: 22; superficial injury: 26; open wound: 19; intracranial injury: 4; other injury: 13; other diagnosis: 6. Walking, marching, and hiking: sprain: 24; fracture: 18; superficial injury: 20; open wound: 15; intracranial injury: 2; other injury: 12; other diagnosis: 10. Other unspecified sports activity: sprain: 19; fracture: 18; superficial injury: 21; open wound: 12; intracranial injury: 7; other injury: 16; other diagnosis: 5. Basketball: sprain: 40; fracture: 16; superficial injury: 11; open wound: 10; intracranial injury: 3; other injury: 14; other diagnosis: 5. American tackle football: sprain: 27; fracture: 21; superficial injury: 16; open wound: 4; intracranial injury: 9; other injury: 17; other diagnosis: 6. School recess and summer camp: sprain: 13; fracture: 42; superficial injury: 15; open wound: 10; intracranial injury: 3; other injury: 13; other diagnosis: 5. Running: sprain: 28; fracture: 14; superficial injury: 15; open wound: 24; intracranial injury: 2; other injury: 12; other diagnosis: 6. Roller skating and skateboarding: sprain: 21; fracture: 33; superficial injury: 17; open wound: 9; intracranial injury: 3; other injury: 11; other diagnosis: 5. Soccer: sprain: 31; other injury: 21; superficial injury: 15; open wound: 6; intracranial injury: 6; other injury: 15; other diagnosis: 5. Baseball: sprain: 23; fracture: 19; superficial injury: 24; open wound: 10; intracranial injury: 4; other injury: 15; other diagnosis: 5.

■ The most common injuries among sports-related ED visits (discharged) included sprains—seen in 40 percent of basketball-related visits—and fractures—seen in 42 percent of visits related to school recess and summer camp activities.
  Among the 10 most common sports activities associated with ED visits in 2013 (from Table 1), the frequency of types of injuries varied by specific sports activity:
  - Sprains—basketball (40 percent); soccer (31 percent); running (28 percent); American tackle football (27 percent); walking, marching, and hiking (24 percent); baseball (23 percent); and roller skating and skateboarding (21 percent)
  - Fractures—school recess and summer camp activities (42 percent), roller skating and skateboarding (33 percent), bicycle riding (22 percent), American tackle football (21 percent), and soccer (21 percent)
  - Superficial injuries—bicycle riding (26 percent), baseball (24 percent), and walking, marching, and hiking (20 percent)
  - Open wounds—running (24 percent) and bicycle riding (19 percent)
  - Intracranial injury—tackle football (9 percent)

Figure 5 focuses on hospital inpatient stays and presents information on the types of injuries for the 10 most common sports activities associated with inpatient stays in 2013.

Figure 5 Primary type of injurya among the 10 most common sports activities associated with hospital inpatient stays, 2013

Note: For fewer than 1% of inpatient stays, more than one sports activity was identified. In these cases, the visit or stay is counted separately for each identified sports activity.

^a^ Type of injury was based on the Clinical Classifications Software (CCS) principal diagnosis.

^b^ Snow (alpine) (downhill) skiing, snowboarding, sledding, tobogganing, and snow tubing.

^c^ Physical games generally associated with school recess, summer camp, and children.

^d^ More specific information about the sports activity is not available in the ICD-9-CM diagnosis codes in this category.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS), 2013

Figure 5 is a stacked bar chart that shows the percentage of inpatient stays by primary type of injury among the 10 most common sports activities. Walking, marching, and hiking: fracture: 59; intracranial injury: 8; crushing injury: 2; other injury: 8; other diagnosis: 24. Bicycle riding: fracture: 55; intracranial injury: 18; crushing injury: 9; other injury: 9; other diagnosis: 8. Downhill skiing and snowboarding: fracture: 72; intracranial injury: 7; crushing injury: 12; other injury: 6; other diagnosis: 3. School recess and summer camp: fracture: 84; intracranial injury: 7; crushing injury: 3; other injury: 4; other diagnosis: 3. Other unspecified sports activity: fracture: 55; intracranial injury: 13; crushing injury: 10; other injury: 13; other diagnosis: 10. Roller skating and skateboarding: fracture: 64; intracranial injury: 22; crushing injury: 3; other injury: 4; other diagnosis: 7. American tackle football: fracture: 55; intracranial injury: 8; crushing injury: 11; other injury: 15; other diagnosis: 10. Running: fracture: 55; intracranial injury: 8; crushing injury: 4; other injury: 14; other diagnosis: 18. Horseback riding: fracture: 60; intracranial injury: 13; crushing injury: 16; other injury: 6; other diagnosis: 6. Basketball: fracture: 55; intracranial injury: 8; crushing injury: 4; other injury: 22; other diagnosis: 11.

■ Fractures accounted for more than half of inpatient stays for each of the 10 most common sports-related reasons for hospitalization.
  Among the 10 most common sports activities associated with inpatient stays in 2013 (from Table 1), fracture was the most frequent type of injury. Fractures accounted for more than half of inpatient stays for each sports activity, reaching as high as 84 percent of sports-related inpatient stays involving school recess and summer camp activities, 72 percent of stays related to downhill skiing and snowboarding, and 64 percent of roller skating and skateboarding-related stays.
■ Sports-related inpatient stays for intracranial injury were most common for roller skating and skateboarding. Stays for crushing injury were most common for horseback riding.
  Among the 10 most common sports activities associated with inpatient stays in 2013, intracranial injury was most frequent for roller skating and skateboarding (22 percent) and bicycle riding (18 percent). Crushing injury was most frequent for horseback riding (16 percent) and downhill skiing and snowboarding (12 percent).

## Data Source

The estimates in this Statistical Brief are based upon data from the Healthcare Cost and Utilization Project (HCUP) 2013 National Inpatient Sample (NIS) and Nationwide Emergency Department Sample (NEDS).

## Definitions

### Diagnoses, ICD-9-CM, and Clinical Classifications Software (CCS)

The principal diagnosis is that condition established after study to be chiefly responsible for the patient’s admission to the hospital. Secondary diagnoses are concomitant conditions that coexist at the time of admission or develop during the stay. All-listed diagnoses include the principal diagnosis plus these additional secondary conditions.

ICD-9-CM is the International Classification of Diseases, Ninth Revision, Clinical Modification, which assigns numeric codes to diagnoses. There are approximately 14,000 ICD-9-CM diagnosis codes.

CCS categorizes ICD-9-CM diagnosis codes or procedure codes into a manageable number of clinically meaningful categories.^11^ This clinical grouper makes it easier to quickly understand patterns of diagnoses or procedure use. CCS categories identified as Other typically are not reported; these categories include miscellaneous, otherwise unclassifiable diagnoses or procedures that may be difficult to interpret as a group.

### Case definition

In this study we focused on identifying sports activities using the ICD-9-CM “activity” external cause of injury codes (E codes), E001–E030, as presented in Table 4. We also searched to identify any other E codes that could indicate that the hospital stay or emergency department (ED) visit was associated with a sports activity. These additional E codes that were included as part of a specific sports activity category also are provided in Table 4. Finally, we included three E codes (E886.0, E917.0, and E917.5) that specified that an injury occurred during sports, but there was no further information provided (i.e., by a more specific E code on the record) to indicate which specific sports activity was involved. These records are coded to the “other unspecified sports” (sports not elsewhere classified) category.

Table 4 ICD-9-CM E codes identifying sports activities

ICD-9-CM activity E code | Sports activity description | ICD-9-CM other E code | Other E code description
Walking and running
E001.0 | Walking, marching, and hiking
E001.1 | Running
Water and water craft sports
E002.0 | Swimming | E830.5, E831.5, E832.5, E833.5, E834.5, E835.5, E836.5, E837.5, E838.5 | Water transport accidents injuring swimmer
E002.1 | Springboard and platform diving | E883.0 | Accident from diving or jumping into water (swimming pool)
E002.2 | Water polo
E002.3 | Water aerobics and water exercise
E002.4 | Underwater diving and snorkeling | E902.2 | High and low air pressure and changes in air pressure - due to diving
E002.4 | Underwater diving and snorkeling | E910.1 | Accidental drowning and submersion while engaged in other sport or recreational activity with diving equipment
E002.5 | Rowing, canoeing, kayaking, rafting, and tubing
E002.6 | Water skiing and wakeboarding | E830.4, E831.4, E832.4, E833.4, E834.4, E835.4, E836.4, E837.4, E838.4 | Water transport accidents injuring water skier
E002.6 | Water skiing and wakeboarding | E910.0 | Accidental drowning and submersion while water skiing
E002.7 | Surfing, windsurfing, and boogie boarding
E002.8 | Water sliding
E002.9 | Water and watercraft | E910.2 | Accidental drowning and submersion while engaged in other sport or recreational activity without diving equipment
Ice and snow sports
E003.0 | Ice skating
E003.1 | Ice hockey
E003.2 | Snow (alpine) (downhill) skiing, snowboarding, sledding, tobogganing, and snow tubing | E885.3, E885.4 | Fall from skis, snowboard
E003.3 | Cross-country skiing
E003.9 | Ice and snow, other activity
Climbing, rappelling, and jumping off
E004.0 | Mountain climbing, rock climbing, and wall climbing
E004.1 | Rappelling
E004.2 | BASE jumping
E004.3 | Bungee jumping
E004.4 | Hang gliding
E004.9 | Climbing, rappelling, and jumping off, other activity
Dancing and other rhythmic movement
E005.0 | Dancing
E005.1 | Yoga
E005.2 | Gymnastics
E005.3 | Trampoline
E005.4 | Cheerleading
E005.9 | Dancing and other rhythmic movements, other activity
Other sports and athletics played individually
E006.0 | Roller skating (inline) and skateboarding | E885.1, E885.2 | Fall from roller skates, skateboard
E006.1 | Horseback riding
E006.2 | Golf
E006.3 | Bowling
E006.4 | Bicycle riding | E800.3, E801.3, E802.3, E803.3, E804.3, E805.3, E806.3, E807.3 | Railway accidents injuring pedal cyclist
E006.4 | Bicycle riding | E810.6, E811.6, E812.6, E813.6, E814.6, E815.6, E816.6, E817.6, E818.6, E819.6 | Motor vehicle traffic accidents injuring pedal cyclist
E006.4 | Bicycle riding | E820.6, E821.6, E822.6, E823.6, E824.6, E825.6 | Motor vehicle nontraffic accidents injuring pedal cyclist
E006.4 | Bicycle riding | E826.1 | Pedal cycle accident injuring pedal cyclist
E006.5 | Jumping rope
E006.6 | Nonrunning track and field events
E006.9 | Other sports and athletics played individually, other activity
Other sports and athletics played as a team or group
E007.0 | American tackle football
E007.1 | American flag or touch football
E007.2 | Rugby
E007.3 | Baseball
E007.4 | Lacrosse and field hockey
E007.5 | Soccer
E007.6 | Basketball
E007.7 | Volleyball (beach) (court)
E007.8 | Physical games generally associated with school recess, summer camp, and children | E884.0 | Fall from playground equipment
E007.9 | Other sports and athletics played as a team or group, other activity
Other specified sports and athletics
E008.0 | Boxing
E008.1 | Wrestling
E008.2 | Racquet and hand sports
E008.3 | Frisbee
E008.4 | Martial arts
E008.9 | Other specified sports and athletics activity
Other cardiorespiratory exercise
E009.0 | Exercise machines primarily for cardiorespiratory conditioning
E009.1 | Calisthenics
E009.2 | Aerobic and step exercise
E009.3 | Circuit training
E009.4 | Obstacle course
E009.5 | Grass drills
E009.9 | Cardiorespiratory exercise, other activity
Other muscle strengthening exercises
E010.0 | Exercise machines primarily for muscle strengthening
E010.1 | Push-ups, pull-ups, sit-ups
E010.2 | Free weights
E010.3 | Pilates
E010.9 | Other muscle strengthening exercises, other activity
Sports activity, not elsewhere classified
| Other unspecified sports activity | E886.0 | Fall on same level from collision, pushing, or shoving, by or with other person – in sports
| Other unspecified sports activity | E917.0, E917.5 | Striking against or struck accidentally by objects or persons in sports, without or with subsequent fall

Abbreviation: BASE, building, antenna, span, earth

Each relevant E code was classified into one of three categories:

1. Nonspecific Sports E Codes: E002.9, E003.9, E004.9, E005.9, E006.9, E007.9, E008.9, E009.9, E010.9
2. Sports NEC (“not elsewhere classified”) Codes: E886.0, E917.0, E917.5
3. Specific Sports E Codes: all other codes listed in the Sports E Codes

Each discharge record (ED visit that resulted in discharge or hospital inpatient stay) was classified into one or more of the sports activity categories based on the following rules:

1. If a Specific Sports E Code was present anywhere on the record, then the record was classified into that sports activity.
2. If no Specific Sports E Codes were present anywhere on the record, then:
  - If a Nonspecific Sports E Code was present anywhere on the record, the record was classified into that sports activity.
3. If no Specific Sports E Codes and no Nonspecific Sports E Codes were present anywhere on the record, then:
  - If a Sports NEC Code was present anywhere on the record, the record was classified into the “Other unspecified sports activity” category.

For bicycle riding, each discharge record was further subset into one of three categories based on the following hierarchy:

1. If any one of the following codes was on the record—E810.6, E811.6, E812.6, E813.6, E814.6, E815.6, E816.6, E817.6, E818.6, E819.6—then the record was classified as bicycle riding: motor vehicle traffic.
2. Else, if any of the following codes were on the record—E800.3, E801.3, E802.3, E803.3, E804.3, E805.3, E806.3, E807.3, E820.6, E821.6, E822.6, E823.6, E824.6, E825.6—then the record was classified as bicycle riding: nontraffic vehicle.
3. Else, the record was classified as bicycle riding: other bicycle.

Note that the following E codes associated with gun-related injuries were not included in any of the categories of sports activities examined in this Statistical Brief.

Table 5 Gun-related ICD-9-CM E codes not included

ICD-9-CM E code | Description
E922.2 | Accident caused by hunting rifle
E922.4 | Accident caused by air gun
E922.5 | Accident caused by paintball gun

### Types of hospitals included in the HCUP National (Nationwide) Inpatient Sample

The National (Nationwide) Inpatient Sample (NIS) is based on data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). The NIS includes obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded are long-term care facilities such as rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. Beginning in 2012, long-term acute care hospitals are also excluded. However, if a patient received long-term care, rehabilitation, or treatment for a psychiatric or chemical dependency condition in a community hospital, the discharge record for that stay will be included in the NIS.

### Types of hospitals included in the HCUP Nationwide Emergency Department Sample

The Nationwide Emergency Department Sample (NEDS) is based on data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). The NEDS includes specialty, pediatric, public, and academic medical hospitals. Excluded are long-term care facilities such as rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. Hospitals included in the NEDS have hospital-owned emergency departments and no more than 90 percent of their ED visits resulting in admission.

### Unit of analysis

The unit of analysis is the hospital discharge (i.e., the hospital stay) or the ED encounter, not a person or patient. This means that a person who is admitted to the hospital or seen in the ED multiple times in 1 year will be counted each time as a separate discharge from the hospital or encounter in the ED.

## For More Information

For more information about HCUP, visit http://www.hcup-us.ahrq.gov/.

For additional HCUP statistics, visit HCUP Fast Stats at http://www.hcup-us.ahrq.gov/faststats/landing.jsp for easy access to the latest HCUP-based statistics for health information topics, or visit HCUPnet, HCUP’s interactive query system, at http://hcupnet.ahrq.gov/.

For information on other hospitalizations in the United States, refer to the following HCUP Statistical Briefs located at http://www.hcup-us.ahrq.gov/reports/statbriefs/statbriefs.jsp:

- Statistical Brief #180, Overview of Hospital Stays in the United States, 2012
- Statistical Brief #181, Costs for Hospital Stays in the United States, 2012
- Statistical Brief #186, Most Frequent Operating Room Procedures Performed in U.S. Hospitals, 2003–2012
- Statistical Brief #162, Most Frequent Conditions in U.S. Hospitals, 2011

For a detailed description of HCUP and more information on the design of the National Inpatient Sample (NIS) and the Nationwide Emergency Department Sample (NEDS), please refer to the following database documentation:

Agency for Healthcare Research and Quality. Overview of the National (Nationwide) Inpatient Sample (NIS). Healthcare Cost and Utilization Project (HCUP). .

Agency for Healthcare Research and Quality. Overview of the Nationwide Emergency Department Sample (NEDS). Healthcare Cost and Utilization Project (HCUP). .

1 Physical Activity Council. 2016 Participation Report: The Physical Activity Council’s Annual Study Tracking Sports, Fitness, and Recreation Participation in the US.

2 Centers for Disease Control and Prevention. CDC Injury Center Research Priorities.

3 Centers for Disease Control and Prevention. (2002). Nonfatal sports- and recreation-related injuries treated in emergency departments—United States, July 2000–June 2001. MMWR Weekly.

4 Ibid.

5 Bayt DR, Bell TM. (2015). Trends in paediatric sports-related injuries presenting to US emergency departments, 2001–2013. Injury Prevention.

6 Ibid.

7 Wier L, Miller A, Steiner C. (2009). Sports injuries in children requiring hospital emergency care, 2006.

8 Centers for Disease Control and Prevention. (2011). Nonfatal traumatic brain injuries related to sports and recreation activities among persons aged ≤ 19 years—United States 2001–2009.

9 Practice Management Information Corporation. (2012). International Classification of Diseases, 9^th^ Revision, Clinical Modification 6th ed. (ICD-9-CM), 2013.

10 Barrett M, Steiner C. (2015). Healthcare Cost and Utilization Project (HCUP) External Cause of Injury Code (E Code) Evaluation Report (Updated with 2012 Data). HCUP Methods Series Report #2015-03 ONLINE.

11 Agency for Healthcare Research and Quality. HCUP Clinical Classifications Software (CCS). Healthcare Cost and Utilization Project (HCUP).