# Statistical Brief #201 Trends in Bilateral and Unilateral Mastectomies in Hospital Inpatient and Ambulatory Settings, 2005–2013

## Introduction

Mastectomy (surgical removal of the breast) is a common procedure used in the treatment of breast cancer. Although 97–99 percent of breast cancers occur in only one breast,^1^ some women choose also to remove the healthy breast—a contralateral prophylactic mastectomy (CPM). Reasons that women elect to undergo CPM include physician advice, fear of a subsequent breast cancer diagnosis, desire for cosmetic symmetry, family history of breast cancer, and genetic susceptibility to breast cancer due to mutations in the BRCA1 and BRCA2 genes.^2,3^ Some women, such as those with a genetic predisposition to breast cancer, may choose to have prophylactic bilateral mastectomy without occurrence of cancer in either breast.

Research indicates that the proportion of women choosing mastectomy over breast-conserving surgery, such as lumpectomy, increased from 1998 to 2011.^4^ Much of this increase is attributed to an increase in bilateral mastectomy involving early-stage cancer in one breast and CPM of the other breast.^5^ Indeed, among women undergoing treatment for early-stage breast cancer, the percentage of those having CPM increased more than fivefold between 1998 and 2011 (from 1.9 to 11.2 percent).^6^ During this approximate time period, from 2002 through 2012, the incidence of breast cancer overall remained stable at around 130 per 100,000 women.^7^

At the same time that mastectomies have been increasing, research suggests that mastectomy procedures are shifting to an outpatient setting.^8^ In 2003, approximately 22 percent of mastectomies across 17 States were performed in a hospital outpatient setting.^9^ By 2012, about 42 percent of mastectomies were done outpatient.^10^

This Healthcare Cost and Utilization Project (HCUP) Statistical Brief presents data on bilateral and unilateral mastectomies among adult women in two hospital settings: hospital inpatient and hospital-based ambulatory surgery. The analysis is limited to hospitals within 13 States—representing more than one-fourth of the U.S. population—for which bilateral versus unilateral mastectomies could be identified in both the inpatient and ambulatory surgery settings. Bilateral mastectomies with a cancer diagnosis are likely unilateral mastectomies for cancer with a CPM. Bilateral mastectomies without a cancer diagnosis are likely prophylactic bilateral mastectomies. Unilateral mastectomies without a cancer diagnosis are likely CPMs following a prior unilateral mastectomy with cancer in the other breast.

In this Statistical Brief we provide an overview of characteristics of mastectomies by hospital setting (inpatient and ambulatory surgery) in 2013. We present trends in the overall rates of bilateral and unilateral mastectomies and by hospital setting from 2005 through 2013. The cumulative percentage change over the 9-year time period in the rate of mastectomies based on hospital setting and presence of breast cancer also is provided. Finally, the proportion of all hospital-based mastectomies by type of mastectomy and presence of breast cancer is presented. All differences noted in the text differ by at least 10 percent.

## Findings

Highlights

■ Between 2005 and 2013, the overall rate of mastectomy increased 21 percent, from 74 to 90 per 100,000 adult women. The rate of hospital-based bilateral mastectomies (inpatient and outpatient combined) tripled, from 10.0 to 29.7 per 100,000 adult women, whereas the rate of unilateral mastectomies remained relatively stable at around 64 per 100,000 women.
■ Women who had a bilateral mastectomy in 2013 were about 10 years younger than those who had a unilateral mastectomy.
■ From 2005 to 2013, the rate of bilateral outpatient mastectomies increased more than fivefold and the inpatient rate more than doubled. The rate of unilateral mastectomies nearly doubled in the outpatient setting but decreased 36 percent in the inpatient setting. By 2013, nearly half of all mastectomies were performed outpatient.
■ Regardless of hospital setting, between 2005 and 2013, bilateral mastectomies with cancer more than tripled and bilateral mastectomies without cancer more than doubled. The rate of unilateral mastectomies without cancer also increased (by 23 percent), but the rate of unilateral mastectomies with cancer remained stable.
■ The proportion of hospital-based mastectomies shifted away from unilateral mastectomies with breast cancer and toward bilateral mastectomies, with and without breast cancer. By 2013, more than one in four hospital-based mastectomies were bilateral with cancer.

### Characteristics of hospitalizations for mastectomy, 2013

Table 1 presents characteristics of bilateral and unilateral mastectomies performed in the hospital inpatient setting compared with the hospital-based ambulatory surgery setting in 2013.

Table 1 Characteristics of mastectomy hospitalizations by type of mastectomy and hospital setting, in 13 States, 2013

Characteristic | Bilateral mastectomy | | Unilateral mastectomy
Characteristic | Inpatient surgery | Hospital-based ambulatory surgery | Inpatient surgery | Hospital-based ambulatory surgery
Total number of cases | 6,574 | 3,332 | 9,858 | 10,337
Mastectomies, % | 66 | 34 | 49 | 51
Patient characteristics
Age, mean | 51.3 | 51.8 | 60.4 | 62.0
Age in years, %
18–24 | 0.4 | 1.0 | 0.1 | 0.2
25–34 | 5.5 | 7.4 | 2.2 | 2.2
35–44 | 22.1 | 19.9 | 10.7 | 8.5
45–54 | 35.8 | 32.4 | 23.3 | 19.6
55–64 | 22.9 | 21.3 | 24.8 | 24.7
65–74 | 10.3 | 14.0 | 21.4 | 24.8
75+ | 2.9 | 3.9 | 17.4 | 20.1
Race/ethnicity, %
White | 69.8 | 76.0 | 61.8 | 70.2
Black | 8.6 | 5.3 | 16.1 | 11.5
Hispanic | 3.8 | 1.6 | 5.2 | 2.4
Other^a^ | 7.0 | 3.8 | 8.4 | 5.4
Missing/Invalid^b^ | 10.8 | 13.4 | 8.5 | 10.5
Expected primary payer, %
Medicare | 14.7 | 19.0 | 37.9 | 44.5
Medicaid | 7.7 | 7.1 | 11.4 | 8.6
Private | 73.7 | 70.5 | 47.0 | 42.8
Uninsured | 1.2 | 1.4 | 1.6 | 2.0
Other | 2.6 | 2.0 | 2.1 | 2.0
Community-level income, %
Quartile 1 (lowest) | 11.1 | 17.4 | 18.8 | 24.6
Quartile 2 | 15.5 | 24.5 | 20.2 | 27.4
Quartile 3 | 23.9 | 27.5 | 22.0 | 25.1
Quartile 4 (highest) | 48.2 | 29.9 | 36.8 | 21.9
Hospital stay characteristics
Length of stay, mean days | 2.2 | 0.9 | 2.3 | 0.8
Total hospital charges,^c^ mean $ | 59,900 | 44,600 | 40,400 | 26,500

a Other race/ethnicity includes Asian/Pacific Islander and American Indian/Alaska Native.

b Two of the 13 States included in this analysis did not report race/ethnicity information.

c We report hospital charges rather than costs because Cost-to-Charge Ratios are not available for ambulatory surgery data.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), State Inpatient Databases (SID) and State Ambulatory Surgery and Services Databases (SASD) from 13 States, 2013

■ Two-thirds of mastectomies performed across 13 States were unilateral; the remaining one-third were bilateral.
  Of 30,101 mastectomies performed across 13 States in 2013, two-thirds were unilateral (20,195 mastectomies) and one-third were bilateral (9,906 mastectomies).
■ About one-third of bilateral mastectomies were performed in the outpatient setting, and half of unilateral mastectomies were done outpatient.
  Of the 9,906 bilateral mastectomies, one-third were outpatient and two-thirds were inpatient. Of the 20,195 unilateral mastectomies, approximately half were performed outpatient and half were inpatient. By 2013, 45 percent of all mastectomies were performed in the hospital-based ambulatory surgery setting.
■ On average, women who had a bilateral mastectomy were approximately 10 years younger than those who had a unilateral mastectomy.
  In 2013, the average age among women who had an inpatient bilateral mastectomy was 51.3 years compared with 60.4 years for unilateral mastectomy. Similarly, the average age for an outpatient bilateral mastectomy was 51.8 years compared with 62.0 years for unilateral mastectomy. Nearly two-thirds of bilateral mastectomies across settings were among women under aged 55 years compared with about one-third of unilateral mastectomies.
■ Black women were a larger proportion of unilateral and inpatient mastectomies than bilateral and outpatient mastectomies.
  Black women were twice the proportion of unilateral as bilateral mastectomies, in both the inpatient setting (16.1 vs. 8.6 percent) and outpatient setting (11.5 vs. 5.3 percent). For both types of mastectomies, Black, Hispanic, and other (non-White) women were a higher proportion of inpatient than outpatient surgeries. In contrast, White women were a smaller proportion of inpatient versus outpatient surgeries (bilateral: 69.8 vs. 76.0 percent; unilateral: 61.8 vs. 70.2 percent).
■ Nearly three-fourths of women who had a bilateral mastectomy had private insurance as the expected primary payer compared with fewer than half of women who had a unilateral mastectomy.
  Over 70 percent of women who had a bilateral mastectomy had an expected primary payer of private insurance in both the inpatient setting (73.7 percent) and outpatient setting (70.5 percent). The share of women who had a unilateral mastectomy was approximately evenly divided between private insurance and Medicare (inpatient: 47.0 percent private insurance and 37.9 percent Medicare; outpatient: 42.8 percent private insurance and 44.5 percent Medicare). Women with Medicare were a higher proportion of outpatient than inpatient surgeries for both types of mastectomy (bilateral: 19.0 vs. 14.7 percent; unilateral: 44.5 vs. 37.9 percent).
■ Nearly half of inpatient bilateral mastectomies were among women from the highest income communities.
  Approximately half of all inpatient bilateral mastectomies (48.2 percent) and more than one-third of inpatient unilateral mastectomies (36.8 percent) occurred among women from the highest income communities. Women from the lowest income communities were a larger proportion of outpatient than inpatient mastectomies (bilateral: 17.4 vs. 11.1 percent for Quartile 1 and 24.5 vs. 15.5 percent for Quartile 2; unilateral: 24.6 vs. 18.8 percent for Quartile 1 and 27.4 vs. 20.2 percent for Quartile 2).
■ Compared with outpatient bilateral and unilateral mastectomies, average hospital charges were 34 percent higher for inpatient bilateral mastectomies and 52 percent higher for inpatient unilateral mastectomies.
  Average hospital charges were approximately $15,000 more for mastectomies performed inpatient compared with outpatient (bilateral: $59,900 vs. $44,600; unilateral: $40,400 vs. $26,500). Average length of stay also was higher for inpatient mastectomies (2.2–2.3 days) compared with outpatient mastectomies (0.8–0.9 days). Average hospital charges were approximately $18,000–$20,000 higher overall for bilateral versus unilateral mastectomies, but length of stay was similar for the two types of mastectomies.

### Trends in hospital-based mastectomies, 2005–2013

Figure 1 presents trends in the rate of hospitalization for bilateral and unilateral mastectomies from 2005 through 2013. Hospital inpatient surgeries and hospital-based ambulatory surgeries are combined.

Figure 1 Rate of bilateral and unilateral mastectomies in hospital inpatient and hospital-based ambulatory surgery settings combined, in 13 States, 2005–2013

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), State Inpatient Databases (SID) and State Ambulatory Surgery and Services Databases (SASD) from 13 States, 2005, 2007, 2009, 2011, 2013

■ The rate of bilateral mastectomies tripled between 2005 and 2013, whereas the rate of unilateral mastectomies remained relatively constant and then decreased during this period.
  Mastectomy rates varied somewhat over the 9-year time period from 2005 to 2013. While the bilateral mastectomy rate tripled from 2005 to 2013, the rate more than doubled between 2005 and 2009, from 10.0 to 21.5 per 100,000 adult women. After 2009, the rate of bilateral mastectomies continued to increase to 29.7 per 100,000 adult women in 2013. On the other hand, the rate of unilateral mastectomies remained relatively constant at 64.4 per 100,000 adult women in 2005 and 69.8 per 100,000 adult women in 2009, and then decreased to 60.6 per 100,000 adult women in 2013.
■ The overall rate of mastectomy increased by 21 percent between 2005 and 2013.
  Between 2005 and 2013, the overall, combined rate of unilateral and bilateral mastectomy increased from 74 per 100,000 women to 90 per 100,000 women, a 21 percent increase.

Figure 2 presents trends in the rate of bilateral and unilateral mastectomies that were performed in the hospital inpatient and hospital-based ambulatory surgery settings from 2005 through 2013.

Figure 2 Rate of bilateral and unilateral mastectomies by hospital setting, in 13 States, 2005–2013

Note: Cumulative percentage change was calculated from rates that were not rounded.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), State Inpatient Databases (SID) and State Ambulatory Surgery and Services Databases (SASD) from 13 States, 2005, 2007, 2009, 2011, 2013

■ The rate of bilateral mastectomies increased between 2005 and 2013 in both the inpatient and outpatient settings.
  Between 2005 and 2013, the rate of bilateral mastectomies performed in the ambulatory surgery setting increased over fivefold, from 1.9 to 10.0 per 100,000 adult women. The rate of inpatient bilateral mastectomies more than doubled, from 8.1 to 19.7 per 100,000 adult women.
■ In 2013, unilateral mastectomies were as common in the outpatient as in the inpatient setting.
  The rate of unilateral mastectomies in the ambulatory surgery setting nearly doubled between 2005 and 2013, from 18.2 to 31.0 per 100,000 adult women. However, the rate of inpatient unilateral mastectomies decreased 36 percent, from 46.3 to 29.6 per 100,000 adult women. By 2013, unilateral mastectomies were as common in the outpatient as in the inpatient setting.

Table 2 presents the rate of hospitalization for bilateral and unilateral mastectomies by hospital setting (inpatient vs. ambulatory surgery) and presence of breast cancer in 2005 and 2013, along with the cumulative percentage change over the 9-year time period.

Table 2 Rate of hospitalization for bilateral and unilateral mastectomies by hospital setting and presence of breast cancer, in 13 States, 2005 and 2013

Hospital setting and presence of breast cancer | Bilateral mastectomy | | | Unilateral mastectomy
Hospital setting and presence of breast cancer | Rate per 100,000 adult women | | Cumulative percentage change, % | Rate per 100,000 adult women | | Cumulative percentage change, %
Hospital setting and presence of breast cancer | 2005 | 2013 | Cumulative percentage change, % | 2005 | 2013 | Cumulative percentage change, %
All hospital settings
Cancer diagnosis | 7.8 | 25.3 | 222.6 | 61.4 | 56.9 | –7.4
Cancer in situ of breast | 1.8 | 4.8 | 158.8 | 8.3 | 7.3 | –11.9
Other breast cancer (not in situ) | 6.0 | 20.5 | 242.2 | 53.1 | 49.6 | –6.7
No cancer diagnosis | 2.1 | 4.4 | 105.6 | 3.0 | 3.7 | 22.7
Inpatient surgery
Cancer diagnosis | 6.9 | 16.9 | 144.1 | 44.5 | 28.0 | –37.2
Cancer in situ of breast | 1.6 | 3.2 | 96.8 | 5.9 | 3.5 | –40.8
Other breast cancer (not in situ) | 5.3 | 13.7 | 158.6 | 38.6 | 24.5 | –36.6
No cancer diagnosis | 1.2 | 2.8 | 138.3 | 1.8 | 1.6 | –10.0
Hospital-based ambulatory surgery
Cancer diagnosis | 0.9 | 8.4 | 803.2 | 16.9 | 28.9 | 70.8
Cancer in situ of breast | 0.2 | 1.6 | 596.3 | 2.4 | 3.8 | 58.2
Other breast cancer (not in situ) | 0.7 | 6.8 | 870.7 | 14.5 | 25.1 | 72.8
No cancer diagnosis | 0.9 | 1.6 | 64.4 | 1.2 | 2.1 | 70.7

Note: Cumulative percentage change was calculated from rates that were not rounded.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), State Inpatient Databases (SID) and State Ambulatory Surgery and Services Databases (SASD) from 13 States, 2005 and 2013

■ The rate of bilateral mastectomies increased substantially between 2005 and 2013, regardless of presence or severity of breast cancer diagnosis or hospital-based surgical setting.
  Between 2005 and 2013, the rate of bilateral mastectomies that included a breast cancer diagnosis more than tripled, from 7.8 to 25.3 per 100,000 adult women. This increase was observed for bilateral mastectomies with breast cancer in situ—a less severe form of the disease—which nearly tripled, as well as for bilateral mastectomies with other breast cancer diagnoses, which more than tripled. The largest increase in the bilateral mastectomy rate occurred for those surgeries that involved a cancer diagnosis (not in situ) and were performed in the ambulatory surgery setting—a nearly 10-fold increase, from 0.7 to 6.8 per 100,000 adult women.
  The rate of bilateral mastectomies without any diagnosis of breast cancer more than doubled over the 9-year time period, from 2.1 to 4.4 per 100,000 adult women. The rate of bilateral mastectomies without breast cancer more than doubled in the inpatient setting and increased 64.4 percent in the outpatient setting.
■ The rate of unilateral mastectomies with breast cancer remained stable overall between 2005 and 2013, but the rate of unilateral mastectomies without breast cancer increased.
  Between 2005 and 2013, the rate of unilateral mastectomies that included a breast cancer diagnosis remained relatively stable at 61.4 per 100,000 adult women in 2005 and at 56.9 per 100,000 adult women in 2013. The rate of unilateral mastectomies with breast cancer decreased 37.2 percent in the inpatient setting but increased 70.8 percent in the outpatient setting.
  The rate of unilateral mastectomies without any diagnosis of breast cancer increased 22.7 percent overall, with most of the increase in rate occurring among those surgeries performed in the ambulatory surgery setting—which nearly doubled, from 1.2 to 2.1 per 100,000 adult women.

Figure 3 presents the proportion of all hospital-based mastectomies (inpatient and ambulatory surgery) as a function of type of mastectomy (bilateral vs. unilateral) and presence of breast cancer from 2005 through 2013.

Figure 3 Proportion of hospital-based mastectomies (inpatient and ambulatory surgery) by type of mastectomy and presence of breast cancer, in 13 States, 2005–2013

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), State Inpatient Databases (SID) and State Ambulatory Surgery and Services Databases (SASD) from 13 States, 2013

■ Between 2005 and 2013, bilateral mastectomies, with and without breast cancer, increased as a proportion of all hospital-based mastectomies.
  Bilateral mastectomies with cancer increased from 10.5 percent of all hospital-based mastectomies in 2005 to 28.0 percent in 2013—more than one in four mastectomies. Similarly, the proportion of bilateral mastectomies without cancer increased from 2.9 to 4.9 percent of all mastectomies. During this same 9-year time period, the proportion of unilateral mastectomies with cancer decreased from 82.6 to 63.0 percent of all mastectomies, and the proportion of unilateral mastectomies without cancer remained constant at about 4.0 percent.

## Data Source

The volumes and rates in this Statistical Brief are based upon data from the Healthcare Cost and Utilization Project (HCUP) 2013 State Inpatient Databases (SID) and State Ambulatory Surgery and Services Databases (SASD). This report evaluates inpatient and outpatient procedure data from 13 States that contributed to the 2013 SID and 2013 SASD: Connecticut, Indiana, Kansas, Maryland, Minnesota, Nebraska, New Jersey, New York, Ohio, South Carolina, Tennessee, Vermont, and Wisconsin. Historical data were drawn from the same 13 States in the 2005, 2007, 2009, and 2011 SID and SASD. Analysis was limited to hospitals within the 13 States that had cases in the inpatient and ambulatory surgery settings in each data year and for which bilateral versus unilateral mastectomies could be identified. In particular, States were included only if they provided complete outpatient procedure coding that would allow the identification of bilateral versus unilateral mastectomies, by International Classification of Diseases, Ninth Revision, Clinical Modification (ICD-9-CM) procedure codes, by Current Procedural Terminology (CPT^®^) procedure codes that included CPT modifiers, or by both.

Supplemental sources included population denominator data for use with HCUP databases, derived from information available from the Nielsen Company.^11^

## Definitions

### Diagnoses, procedures, ICD-9-CM, and CPT^®^

The principal diagnosis is that condition established after study to be chiefly responsible for the patient's admission to the hospital. Secondary diagnoses are concomitant conditions that coexist at the time of admission or develop during the stay. All-listed diagnoses include the principal diagnosis plus these additional secondary conditions.

All-listed procedures include all procedures performed during the hospital stay, whether for definitive treatment or for diagnostic or exploratory purposes. The first-listed procedure is the procedure that is listed first on the discharge record. Inpatient data define this as the “principal procedure”—the procedure that is performed for definitive treatment rather than for diagnostic or exploratory purposes (i.e., the procedure that was necessary to take care of a complication).

Procedures on inpatient hospitalization records are coded using the ICD-9-CM; procedures on ambulatory surgery and services records can be coded using either ICD-9-CM or the CPT.

ICD-9-CM assigns numeric codes to diagnoses and procedures. There are approximately 14,000 ICD-9-CM diagnosis codes and 4,000 ICD-9-CM procedure codes. CPT assigns numeric codes to procedures. There are approximately 9,600 CPT procedure codes.

### Case definition

Hospital discharge and ambulatory surgery visit records with mastectomy procedures were defined based on all-listed procedure codes as identified using the ICD-9-CM and CPT procedure codes in Table 3.

Table 3 ICD-9-CM and CPT procedure codes for defining mastectomy procedures

Type of mastectomy | ICD-9-CM procedure codes | CPT procedure codes
Bilateral mastectomy | - 85.35; - 85.36; - 85.42; - 85.44; - 85.46; - 85.48 | - 19303 (19180 in 2005); - 19304 (19182 in 2005); - 19305 (19200 in 2005); - 19306 (19220 in 2005); - 19307 (19240 in 2005); - [underlined: with] CPT modifier=50
Unilateral mastectomy | - 85.33; - 85.34; - 85.41; - 85.43; - 85.45; - 85.47 | - 19303 (19180 in 2005); - 19304 (19182 in 2005); - 19305 (19200 in 2005); - 19306 (19220 in 2005); - 19307 (19240 in 2005); - [underlined: without] CPT modifier=50

Presence of breast cancer was defined using the ICD-9-CM diagnosis codes in Table 4. If codes for both cancer in situ and cancer not in situ were indicated on the same record, the record was categorized as cancer not in situ.

Table 4 ICD-9-CM diagnosis codes for defining breast cancer

Presence of breast cancer | ICD-9-CM diagnosis code
Cancer in situ of breast | - 233.0
Other breast cancer (not in situ) | - 174.0; - 174.1; - 174.2; - 174.3; - 174.4; - 174.5; - 174.6; - 174.8; - 174.9

Two additional ICD-9-CM V codes were considered for this Statistical Brief: V5041 (prophylactic breast removal) and V8401 (genetic susceptibility to malignant neoplasm of breast). The proportion of mastectomies without a cancer diagnosis that included one or both of these V codes increased substantially between 2005 and 2013, for bilateral and unilateral mastectomies as well as inpatient and outpatient mastectomies. We did not include the V codes as part of our primary analysis because it is unclear whether this increase represented an actual shift in the characteristics of patients who underwent a mastectomy or a medical practice change to more complete reporting of the nature of mastectomy procedures.

### Types of hospitals included in HCUP State Inpatient Databases

This analysis used State Inpatient Databases (SID) limited to data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). Community hospitals include obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded for this analysis are long-term care facilities such as rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. However, if a patient received long-term care, rehabilitation, or treatment for psychiatric or chemical dependency conditions in a community hospital, the discharge record for that stay was included in the analysis. The analysis was limited to hospitals that had at least one mastectomy procedure performed in both the SID and the SASD in each data year.

### Types of hospitals included in HCUP State Ambulatory Surgery and Services Databases

This analysis used State Ambulatory Surgery and Services Databases (SASD) limited to data from hospital-owned ambulatory surgery facilities. Although some SASD include data from facilities not owned by a hospital, those facilities were excluded from this analysis. The designation of a facility as hospital-owned is specific to its financial relationship with a hospital that provides inpatient care and is not related to its physical location. Ambulatory surgery performed in hospital-owned facilities may be performed within the hospital, in a facility attached to the hospital, or in a facility physically separated from the hospital. The analysis was further limited to ambulatory surgeries performed at facilities owned by community hospitals. Community hospitals are defined as short-term, non-Federal, general, and other specialty hospitals, excluding hospital units of other institutions (e.g., prisons). The analysis was limited to hospitals that had at least one mastectomy procedure performed in both the SID and the SASD in each data year.

### Unit of analysis

The unit of analysis is the hospital discharge (i.e., the hospital stay) for an inpatient stay or ambulatory surgery visit, not a person or patient. This means that a person who is admitted to the hospital to have surgery multiple times in 1 year will be counted each time as a separate discharge from the hospital or visit.

### Charges

Charges represent what the hospital billed for the discharge. Hospital charges reflect the amount the hospital charged for the entire hospital stay and do not include professional (physician) fees. We report hospital charges rather than costs because Cost-to-Charge Ratios are not available for ambulatory surgery data. For the purposes of this Statistical Brief, charges are rounded to the nearest hundred dollars.

### Median community-level income

Median community-level income is the median household income of the patient's ZIP Code of residence. Income levels are separated into population-based quartiles with cut-offs determined using ZIP Code demographic data obtained from the Nielsen Company. The income quartile is missing for patients who are homeless or foreign.

### Payer

Payer is the expected payer for the hospital stay. To make coding uniform across all HCUP data sources, payer combines detailed categories into general groups:

- Medicare: includes patients covered by fee-for-service and managed care Medicare
- Medicaid: includes patients covered by fee-for-service and managed care Medicaid
- Private Insurance: includes Blue Cross, commercial carriers, and private health maintenance organizations (HMOs) and preferred provider organizations (PPOs)
- Uninsured: includes an insurance status of self-pay and no charge
- Other: includes Workers' Compensation, TRICARE/CHAMPUS, CHAMPVA, Title V, and other government programs.

For this Statistical Brief, when more than one payer is listed for a hospital discharge, the first-listed payer is used.

### Reporting of race and ethnicity

Data on Hispanic ethnicity are collected differently among the States and also can differ from the Census methodology of collecting information on race (White, Black, Asian/Pacific Islander, American Indian/Alaska Native, Other (including mixed race)) separately from ethnicity (Hispanic, non-Hispanic). State data organizations often collect Hispanic ethnicity as one of several categories that include race. Therefore, for multistate analyses, HCUP creates the combined categorization of race and ethnicity for data from States that report ethnicity separately. When a State data organization collects Hispanic ethnicity separately from race, HCUP uses Hispanic ethnicity to override any other race category to create a Hispanic category for the uniformly coded race/ethnicity data element, while also retaining the original race and ethnicity data. All of the States included in the analyses for this Statistical Brief report Hispanic ethnicity. This Statistical Brief reports race/ethnicity for the following categories: Hispanic, non-Hispanic White, non-Hispanic Black, non-Hispanic Other (includes Asian/Pacific Islander, American Indian/Alaska Native, and Other).

## For More Information

For more information about HCUP, visit http://www.hcup-us.ahrq.gov/.

For additional HCUP statistics, visit HCUPnet, our interactive query system, at http://hcupnet.ahrq.gov/.

For information on other hospitalizations in the United States, refer to the following HCUP Statistical Briefs located at http://www.hcup-us.ahrq.gov/reports/statbriefs/statbriefs.jsp:

- Statistical Brief #180, Overview of Hospital Stays in the United States, 2012
- Statistical Brief #181, Costs for Hospital Stays in the United States, 2012
- Statistical Brief #186, Most Frequent Operating Room Procedures Performed in U.S. Hospitals, 2003–2012
- Statistical Brief #162, Most Frequent Conditions in U.S. Hospitals, 2011

For a detailed description of HCUP and more information on the design of the State Inpatient Databases (SID) and State Ambulatory Surgery and Services Databases (SASD), please refer to the following database documentation:

Agency for Healthcare Research and Quality. Overview of the State Inpatient Databases (SID). Healthcare Cost and Utilization Project (HCUP). .

Agency for Healthcare Research and Quality. Overview of the State Ambulatory Surgery and Services Databases (SASD). Healthcare Cost and Utilization Project (HCUP). .

1 Polednak AP. (2003). Bilateral synchronous breast cancer: a population-based study of characteristics, method of detection, and survival. Surgery. .

2 Yi M, Meric-Bernstam F, Middleton LP, Arun BK, Bedrosian I, Babiera GV, et al. (2009). Predictors of contralateral breast cancer in patients with unilateral breast cancer undergoing contralateral prophylactic mastectomy. Cancer. .

3 Kurian AW, Lichtensztajn DY, Keegan THM, Nelson DO, Clarke CA, Gomez SL. (2014). Use of and mortality after bilateral mastectomy compared with other surgical treatments for breast cancer in California, 1998–2011. JAMA. .

4 Kummerow KL, Du L, Penson DF, Shyr Y, Hooks MA. (2015). Nationwide trends in mastectomy for early-stage breast cancer. JAMA Surg. .

5 Ibid.

6 Ibid.

7 National Cancer Institute. SEER Stat Fact Sheets: Breast Cancer. .

8 Case C, Johantgen M, Steiner C. (2001). Outpatient mastectomy: clinical, payer, and geographic influences. Health Serv Res. .

9 Russo CA, VanLandeghem K, Davis PH, Elixhauser A. (2006). Hospital and Ambulatory Surgery Care for Women's Cancers. .

10 Wier LM, Steiner CA, Owens PL. (2015). Surgeries in Hospital-Owned Outpatient Facilities, 2012. .

11 Barrett M, Lopez-Gonzalez L, Coffey R, Levit K. (2014). Population Denominator Data for Use with the HCUP Databases (Updated with 2013 Population Data). .