# Statistical Brief #195 Trends in Potentially Preventable Inpatient Hospital Admissions and Emergency Department Visits

## Introduction

Reducing potentially preventable hospitalizations is important for increasing quality of care and containing hospital costs. Medical conditions such as asthma, urinary tract infections, and complications of diabetes are considered ambulatory care sensitive conditions, meaning that when those conditions are present, primary or preventive health care can reduce the need for emergency department (ED) visits and inpatient hospitalization. From 2000 through 2012, the rate of potentially preventable hospitalizations among adults aged 18 years and older decreased by 25 percent.^1^

Although the decrease in potentially preventable hospitalizations could reflect improvements in access to quality ambulatory care, it also may be an artifact of an overall decrease in inpatient admissions in recent years. The total rate of inpatient hospital stays decreased by 0.3 percent per year from 2003 through 2008 and by 1.9 percent per year from 2008 through 2012.^2^ The Great Recession, which officially began in December 2007, was associated with a decrease in inpatient stays as unemployment increased and access to health insurance decreased.^3^ For those who had health insurance during the Recession, copayments and deductibles increased.^4^

Recent initiatives that penalize hospitals for high readmission rates are leading to more scrutiny over potentially preventable hospitalizations.^5^ EDs and observation services play an important role in evaluating whether hospitalization is necessary. Although overall inpatient hospital stays have declined, increasingly patients are being seen in EDs and placed under observation, which may result in more individuals being discharged home rather than admitted as an inpatient.^6,7^ From 2006 through 2012, the total rate of ED visits, including those that resulted in the patient being treated and released and those that resulted in the patient being admitted to the hospital, increased by 5 percent from 40,200 to 42,100 per 100,000 population.^8^

This Healthcare Cost and Utilization Project (HCUP) Statistical Brief presents rates of potentially preventable inpatient hospital stays from 2005 through 2012 and rates of potentially preventable ED visits that did not result in inpatient admission (i.e., treat-and-release visits) from 2008 through 2012. Potentially preventable stays and ED visits were estimated using the Agency for Healthcare Research and Quality (AHRQ) Prevention Quality Indicators (PQIs) software version 4.4. We examined the rate of potentially preventable inpatient stays for all conditions and for acute and chronic conditions grouped together. We also examined potentially preventable stays and visits for each underlying individual condition separately. Rates of potentially preventable hospitalizations and ED visits are age-sex adjusted and calculated among adults aged 18 years and older. Because the PQIs are defined using the first-listed diagnosis, they exclude records that fall in the maternal/neonatal service line that have a pregnancy-related first-listed diagnosis. For comparison, we present age-sex adjusted rates of total inpatient stays and treat-and-release ED visits, which also were calculated among adults aged 18 years and older and exclude records that fall in the maternal/neonatal service line. Only differences greater than 10 percent are noted in the text.

## Findings

Highlights

■ The rate of potentially preventable adult inpatient (IP) stays decreased 19 percent between 2005 and 2012, from 1,941 to 1,582 stays per 100,000 population—more than twice the decrease in rate of all adult IP stays.
■ This decrease in potentially preventable IP stays among adults was greater for acute conditions (25 percent) than for chronic conditions (14 percent).
■ Although the rate of potentially preventable IP stays decreased, the rate of treat-and-release emergency department (ED) visits for the same conditions increased from 2008 through 2012 by 11 percent (from 2,350 to 2,618 visits per 100,000 population).
■ From 2008 through 2012, potentially preventable IP stays decreased and ED visits increased for chronic obstructive pulmonary disease (12 percent IP decrease, 12 percent ED increase) and uncontrolled diabetes (25 percent IP decrease, 32 percent ED increase).
■ During the same 5-year period, the rate of potentially preventable IP stays decreased 31 percent for dehydration, 15 percent for bacterial pneumonia, 14 percent for congestive heart failure, and 15 percent for asthma. The rate of treat-and-release ED visits for these conditions remained stable.
■ The rate of treat-and-release ED visits increased 17 percent for urinary tract infection and 23 percent for hypertension, while the rate of IP stays for these conditions remained stable.
■ Rates of IP stays and treat-and-release ED visits for diabetes with short-term complications both increased more than 20 percent.

### Trends in potentially preventable hospital inpatient stays, 2005–2012

Figure 1 presents the age-sex adjusted rate of potentially preventable inpatient stays among adults aged 18 years and older, for all conditions and for acute and chronic conditions separately, from 2005 through 2012.

Figure 1 Age-sex adjusted rate of potentially preventable inpatient stays among adults aged 18 years and older, overall and for acute and chronic conditions, 2005–2012

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2005–2011; State Inpatient Databases (SID), 2012, weighted to provide national estimates using the same methodology as the 2005–2011 NIS; and the AHRQ Quality Indicators, version 4.4

Figure 1 is a line graph that shows the age-adjusted rate of potentially preventable inpatient stays overall and for acute and chronic conditions for adults 18 years and older from 2005 through 2012. For all conditions, the age-sex adjusted rate of potentially preventable stays declined from 1,941 in 2005 to 1814 in 2007, rose slightly to 1,815 in 2008, declined to 1,658 in 2010, rose to 1,669 in 2011, and declined to 1,582 in 2012, an 18.5% cumulative decrease. For chronic conditions, the age-sex adjusted rate of potentially preventable stays declined from 1,118 in 2005 to 1053 in 2007, rose to 1,078 in 2008, and then declined steadily to 961 in 2012, a cumulative 14.1% decrease. For acute conditions, the age-sex adjusted rate of potentially preventable stays declined steadily from 823 in 2005 to 645 in 2010, rose to 657 in 2011, and declined to 621 in 2012, a cumulative 24.5% decrease.

■ The rate of potentially preventable inpatient stays for all conditions decreased by 19 percent from 2005 through 2012, with the largest decline among stays with acute conditions (by 25 percent).
  The rate of potentially preventable inpatient stays for all conditions among adults aged 18 years and older decreased by 18.5 percent, from 1,941 stays per 100,000 population in 2005 to 1,582 stays per 100,000 population in 2012. Compared with potentially preventable stays for chronic conditions, those for acute conditions decreased more, by 24.5 percent, from 823 stays per 100,000 population in 2005 to 621 stays per 100,000 population in 2012. In comparison, the rate of potentially preventable inpatient stays for chronic conditions decreased by 14.1 percent, from 1,118 to 961 stays per 100,000 population.

Table 1 presents the cumulative change in the rate of all nonmaternal inpatient hospital stays among adults aged 18 years and older from 2005 through 2012, by hospital service line, compared with potentially preventable stays for acute and chronic conditions.

Table 1 Age-sex adjusted rate of nonmaternal inpatient hospital stays among adults aged 18 years and older, by hospital service line, compared with potentially preventable stays, 2005–2012

Type of inpatient stay | Age-sex adjusted rate per 100,000 population | | | % change in rate
Type of inpatient stay | 2005 | 2008 | 2012 | 2005–2008 | 2008–2012 | 2005–2012
All nonmaternal inpatient stays by service line
Total | 12,303 | 12,227 | 11,385 | −0.6 | −6.9 | −7.5
Medical | 7,382 | 7,291 | 6,913 | −1.2 | −5.2 | −6.4
Surgical | 3,466 | 3,421 | 2,980 | −1.3 | −12.9 | −14.0
Mental health | 752 | 780 | 799 | 3.7 | 2.5 | 6.3
Injury | 701 | 707 | 681 | 0.9 | −3.7 | −2.8
Potentially preventable inpatient stays
All conditions | 1,941 | 1,815 | 1,582 | −6.5 | −12.8 | −18.5
Acute conditions | 823 | 736 | 621 | −10.5 | −15.6 | −24.5
Chronic conditions | 1,118 | 1,078 | 961 | −3.6 | −10.9 | −14.1

Notes: Each discharge was assigned to a single hospital service line hierarchically, based on the following order: maternal and neonatal (excluded), mental health, injury, surgical, and medical. All nonmaternal inpatient stays include potentially preventable stays.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2005 and 2008; State Inpatient Databases (SID), 2012, weighted to provide national estimates using the same methodology as the 2005 and 2008 NIS; and the AHRQ Quality Indicators, version 4.4

■ Potentially preventable inpatient stays decreased at a faster rate than inpatient stays overall.
  From 2005 through 2012, the 18.5 percent decrease in the rate of potentially preventable inpatient stays for all conditions among adults aged 18 years and older was more than 2 times greater than the 7.5 percent decrease in the total rate of nonmaternal adult inpatient stays.
■ The decrease in the rate of all inpatient stays was largest for surgical stays.
  For inpatient stays by service line, surgical was the only service line that decreased by more than 10 percent from 2005 through 2012. From 2005 through 2012, surgical inpatient stays among adults aged 18 years and older decreased by 14.0 percent, from 3,466 to 2,980 per 100,000 population. Mental health was the only service line for which inpatient stays increased during this time period, although not by more than 10 percent.
■ The rate of potentially preventable inpatient stays decreased more quickly after 2008.
  The rate of potentially preventable inpatient stays for all conditions remained relatively stable from 2005 through 2008, decreasing by less than 10 percent. Subsequently, the rate decreased by 12.8 percent from 2008 through 2012.

### Trends in potentially preventable ED visits, 2008–2012

Figure 2 presents the age-sex adjusted rate of potentially preventable treat-and-release ED visits among adults aged 18 years and older, for all conditions and for acute and chronic conditions separately, from 2008 through 2012.

Figure 2 Age-sex adjusted rate of potentially preventable treat-and-release ED visits among adults aged 18 years and older, overall and for acute and chronic conditions, 2008–2012

Abbreviation: ED, emergency department

Note: Although ED data are available starting in 2006, this Statistical Brief uses data from 2008 that were compiled for the National Healthcare Quality and Disparities Reports.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Emergency Department Sample (NEDS), 2008–2012, and the AHRQ Quality Indicators, version 4.4

Figure 2 is a line graph that shows the age-sex adjusted rate of potentially preventable treat-and-release emergency department visits overall and for acute and chronic conditions for adults 18 years and older from 2008 through 2012. For all conditions, the age-sex adjusted rate of potentially preventable treat-and-release emergency department visits increased steadily from 2,350 in 2008 to 2,618 in 2012, an 11.4% cumulative increase. For acute conditions, the age-sex adjusted rate of potentially preventable treat-and-release emergency department visits increased steadily from 1,229 in 2008 to 1,382 in 2012, a 12.5% cumulative increase. For chronic conditions, the age-sex adjusted rate of potentially preventable treat-and-release emergency department visits increased steadily from 1,121 in 2008 to 1,235 in 2012, a 10.2% cumulative increase.

■ The rate of potentially preventable treat-and-release ED visits for all conditions increased by 11 percent from 2008 through 2012, with the largest increase among visits for acute conditions (by 13 percent).
  From 2008 through 2012, the rate of potentially preventable treat-and-release ED visits among adults aged 18 years and older increased by 11.4 percent for all conditions, by 12.5 percent for acute conditions, and by 10.2 percent for chronic conditions.

Table 2 presents the cumulative change in the rate of nonmaternal treat-and-release ED visits among adults aged 18 years and older from 2008 through 2012, by hospital service line, compared with potentially preventable visits for acute and chronic conditions.

Table 2 Age-sex adjusted rates of nonmaternal treat-and-release ED visits among adults aged 18 years and older, by hospital service line, compared with potentially preventable visits, 2008–2012

Type of ED visit | Age-sex adjusted rate per 100,000 population | | % change in rate, 2008–2012
Type of ED visit | 2008 | 2012 | % change in rate, 2008–2012
All nonmaternal treat-and-release ED visits by service line
Total | 33,692 | 36,208 | 7.5
General medical | 24,275 | 26,837 | 10.6
Injury | 8,000 | 7,681 | −4.0
Mental health | 1,417 | 1,690 | 19.3
Potentially preventable treat-and-release ED visits
All conditions | 2,350 | 2,618 | 11.4
Acute conditions | 1,229 | 1,382 | 12.5
Chronic conditions | 1,121 | 1,235 | 10.2

Abbreviation: ED, emergency department

Notes: Because the surgical and medical groups are defined using diagnosis-related groups, which are not available in the ED data, ED visits not classified as maternal/neonatal, mental health, or injury were grouped into a general medical category. All nonmaternal treat-and-release ED visits include potentially preventable visits.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Emergency Department Sample (NEDS), 2008 and 2012, and the AHRQ Quality Indicators, version 4.4. Although the NEDS is available starting in 2006, this Statistical Brief uses data from 2008 that were compiled for the 2008–2012 National Healthcare Quality and Disparities Reports.

■ Potentially preventable ED visits increased at a faster rate than ED visits overall.
  From 2008 through 2012, the 11.4 percent increase in the rate of potentially preventable treat-and-release ED visits for all conditions among adults aged 18 years and older was 1.5 times greater than the 7.5 percent increase in the total rate of nonmaternal adult treat-and-release ED visits.
■ The increase in the rate of treat-and-release ED visits was largest for mental health-related visits.
  From 2008 through 2012, the rate of adult treat-and-release ED visits for mental health increased by 19.3 percent, from 1,417 to 1,690 visits per 100,000 population. The rate of all other nonmaternal adult treat-and-release ED visits for reasons other than injury and mental health increased by 10.6 percent, from 24,275 to 26,837 per 100,000 population.

### Comparison of trends in potentially preventable hospital inpatient stays and ED visits, 2008–2012

Figure 3 presents the cumulative percentage change from 2008 through 2012 in the age-sex adjusted rate of potentially preventable inpatient stays and treat-and-release ED visits among adults aged 18 years and older, for all conditions and for acute and chronic conditions separately.

Figure 3 Cumulative percentage change in the age-sex adjusted rate of potentially preventable inpatient stays and treat-and-release ED visits among adults aged 18 years and older, 2008–2012

Abbreviation: ED, emergency department

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2008; State Inpatient Databases (SID), 2012, weighted to provide national estimates using the same methodology as the 2008 NIS; Nationwide Emergency Department Sample (NEDS), 2008 and 2012; and the AHRQ Quality Indicators, version 4.4

Figure 3 is a bar chart that shows the cumulative percentage change in the age-sex adjusted rate of potentially preventable inpatient stays and treat-and-release emergency department visits for adults aged 18 years and older from 2008 through 2012. For all conditions, the cumulative percentage change in age-sex adjusted rate of potentially preventable inpatient stays was −12.8% and the change in the rate of potentially preventable treat-and-release emergency department visits was +11.4%. For acute conditions, the cumulative percentage change in age-sex adjusted rate of potentially preventable inpatient stays was −15.6% and the change in the rate of potentially preventable treat-and-release emergency department visits was +12.5%. For chronic conditions, the cumulative percentage change in age-sex adjusted rate of potentially preventable inpatient stays was −10.9% and the change in the rate of potentially preventable treat-and-release emergency department visits was +10.2%.

■ Whereas the rate of potentially preventable inpatient stays decreased from 2008 through 2012, the rate of potentially preventable treat-and-release ED visits for the same conditions increased.

The rate of potentially preventable inpatient stays among adults aged 18 years and older decreased by 12.8 percent for all conditions, by 15.6 percent for acute conditions, and by 10.9 percent for chronic conditions. In contrast, the rate of potentially preventable treat-and-release ED visits for the same conditions increased by 11.4, 12.5, and 10.2 percent, respectively.

Table 3 presents the cumulative change in the rate of potentially preventable inpatient stays and treat-and-release ED visits among adults aged 18 years and older from 2008 through 2012, by condition that was the reason for the stay or visit. Figure 4 compares the cumulative percentage change from 2008 through 2012 for rates of potentially preventable inpatient stays and ED visits among adults aged 18 years and older.

Table 3 Age-sex adjusted rate of potentially preventable inpatient stays and treat-and-release ED visits among adults aged 18 years and older, by condition, 2008–2012

Condition | Rate of potentially preventable inpatient stays per 100,000 population | | % change in rate of inpatient stays, 2008–2012 | Rate of potentially preventable ED visits per 100,000 population | | % change in rate of ED visits, 2008–2012
Condition | 2008 | 2012 | % change in rate of inpatient stays, 2008–2012 | 2008 | 2012 | % change in rate of ED visits, 2008–2012
All conditions | 1,815 | 1,582 | −12.8 | 2,350 | 2,618 | 11.4
Acute conditions | 736 | 621 | −15.6 | 1,229 | 1,382 | 12.5
Dehydration | 174 | 121 | −30.5 | 171 | 179 | 4.9
Bacterial pneumonia | 360 | 306 | −15.0 | 218 | 223 | 2.1
Urinary tract infection | 202 | 195 | −3.9 | 841 | 981 | 16.7
Chronic conditions | 1,078 | 961 | −10.9 | 1,121 | 1,235 | 10.2
Diabetes with short-term complications | 60 | 73 | 21.7 | 7 | 9 | 20.2
Diabetes with long-term complications | 129 | 116 | −9.7 | 123 | 116 | −6.3
Uncontrolled diabetes without complications | 23 | 17 | −24.5 | 17 | 23 | 32.3
Lower extremity amputations for diabetes | 18 | 17 | −1.1 | DSU | DSU | DSU
Chronic obstructive pulmonary disease^a^ | 575 | 507 | −12.0 | 629 | 703 | 11.8
Asthma^b^ | 59 | 50 | −15.3 | 527 | 572 | 8.6
Hypertension | 61 | 60 | −1.9 | 258 | 318 | 23.3
Congestive heart failure | 397 | 341 | −14.2 | 83 | 81 | −3.0

Abbreviations: ED, emergency department; DSU, data statistically unreliable.

a Rate per 100,000 adults aged 40 years or older.

b Rate per 100,000 adults aged 18–39 years.

Notes: All rates are per 100,000 population aged 18 years and older, unless otherwise noted. Although angina is included in the rate of potentially preventable stays and visits overall and for chronic conditions grouped together, the individual rate is not presented because this measure is soon to be retired; rates of angina are low in frequency, and coding changes over time make trends less reliable.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2008; State Inpatient Databases (SID), 2012, weighted to provide national estimates using the same methodology as the 2008 NIS; Nationwide Emergency Department Sample (NEDS), 2008 and 2012; and the AHRQ Quality Indicators, version 4.4

■ In 2008 and 2012, chronic obstructive pulmonary disease was the most common condition among potentially preventable inpatient admissions and the second most common condition among potentially preventable treat-and-release ED visits.
  The highest rate of potentially preventable inpatient stays among adults was for chronic obstructive pulmonary disease, accounting for 575 stays per 100,000 population in 2008. This condition was the second most common condition among potentially preventable treat-and-release ED visits, accounting for 629 visits per 100,000 population in 2008. From 2008 through 2012, the rate of potentially preventable inpatient stays for chronic obstructive pulmonary disease decreased by 12.0 percent, while the rate of potentially preventable treat-and-release ED visits for this condition increased by 11.8 percent.
■ Urinary tract infection was the most common condition among potentially preventable treat-and-release ED visits.
  The highest rate of potentially preventable treat-and-release ED visits among adults was for urinary tract infection, accounting for 841 stays per 100,000 population in 2008. From 2008 through 2012, the rate of potentially preventable treat-and-release ED visits for urinary tract infection increased by 16.7 percent, while the rate of potentially preventable inpatient stays for the same condition remained relatively stable.
■ The rate of potentially preventable inpatient stays for dehydration, bacterial pneumonia, asthma, and congestive heart failure decreased by more than 10 percent, with no increase 10 percent or greater in the rate of treat-and-release ED visits for the same conditions.
  From 2008 through 2012, the rate of potentially preventable adult inpatient stays decreased by 30.5 percent for dehydration, 15.0 percent for bacterial pneumonia, 15.3 percent for asthma, and 14.2 percent for congestive heart failure. At the same time, the rate of treat-and-release ED visits for these same conditions remained relatively stable, changing less than 10 percent.
■ Although the rate of potentially preventable inpatient stays decreased by more than 10 percent for uncontrolled diabetes and chronic obstructive pulmonary disease, the increase in treat-and-release ED visits was similar to or larger than the decrease in inpatient stays for these conditions.
  From 2008 through 2012, the rate of potentially preventable adult inpatient stays decreased by 24.5 percent for uncontrolled diabetes, while the rate of treat-and-release ED visits for the same condition increased by 32.3 percent. Similarly, the rate of potentially preventable inpatient stays for chronic obstructive pulmonary disease decreased by 12.0 percent, while the rate of treat-and-release ED visits for the same condition increased by 11.8 percent.
■ The rate of potentially preventable treat-and-release ED visits increased by more than 10 percent for urinary tract infection, diabetes with short-term complications, and hypertension, while the rate of inpatient stays for these same conditions remained stable or increased.
  From 2008 through 2012, the rate of treat-and-release ED visits increased by 16.7 percent for urinary tract infection and by 23.3 percent for hypertension, whereas the rate of inpatient stays for these conditions remained relatively stable, changing by less than 10 percent. The rate of treat-and-release ED visits for diabetes with short-term complications increased by 20.2 percent, and the rate of inpatient stays for this condition also increased, by 21.7 percent.

Figure 4 Cumulative percentage change in the age-sex adjusted rate of potentially preventable inpatient stays and treat-and-release ED visits among adults aged 18 years and older, by specific condition, 2008–2012

Abbreviation: ED, emergency department

^a^ Includes adults aged 40 years or older.

^b^ Includes adults aged 18–39 years.

^c^ Percentage change was not calculated for ED visits for this condition because the rate was statistically unreliable.

Note: All measures are among adults aged 18 years and older, unless otherwise noted.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2008; State Inpatient Databases (SID), 2012, weighted to provide national estimates using the same methodology as the 2008 NIS; Nationwide Emergency Department Sample (NEDS), 2008 and 2012; and the AHRQ Quality Indicators, version 4.4

Figure 4 is a bar chart that shows the cumulative percentage change in the age-sex adjusted rate of potentially preventable inpatient stays and treat-and-release emergency department visits for adults aged 18 years and older by specific condition from 2008 through 2012. The first three conditions are acute conditions. For dehydration, the cumulative percentage change in the age-sex adjusted rate of potentially preventable inpatient stays was −30.5% and treat-and-release emergency department visits was +4.9%. For bacterial pneumonia, the cumulative percentage change in the age-sex adjusted rate of potentially preventable inpatient stays was −15.0% and treat-and-release emergency department visits was +2.1%. For urinary tract infection, the cumulative percentage change in the age-sex adjusted rate of potentially preventable inpatient stays was −3.9% and treat-and-release emergency department visits was +16.7%. The remaining eight conditions are chronic conditions. For diabetes, short-term complications, the cumulative percentage change in the age-sex adjusted rate of potentially preventable inpatient stays was +21.7% and treat-and-release emergency department visits was +20.2%. For diabetes, long-term complications, the cumulative percentage change in the age-sex adjusted rate of potentially preventable inpatient stays was −9.7% and treat-and-release emergency department visits was −6.3%. For uncontrolled diabetes, the cumulative percentage change in the age-sex adjusted rate of potentially preventable inpatient stays was −24.5% and treat-and-release emergency department visits was +32.3%. For lower extremity amputation for diabetes, the cumulative percentage change in the age-sex adjusted rate of potentially preventable inpatient stays was −1.1% and the percentage change was not calculated for treat-and-release emergency department visits because the rate was statistically unreliable. For chronic obstructive pulmonary disease, including adults aged 40 years and older, the cumulative percentage change in the age-sex adjusted rate of potentially preventable inpatient stays was −12.0% and treat-and-release emergency department visits was +11.8%. For asthma, including adults aged 18–39 years, the cumulative percentage change in the age-sex adjusted rate of potentially preventable inpatient stays was −15.3% and treat-and-release emergency department visits was +8.6%. For hypertension, the cumulative percentage change in the age-sex adjusted rate of potentially preventable inpatient stays was −1.9% and treat-and-release emergency department visits was +23.3%. For congestive heart failure, the cumulative percentage change in the age-sex adjusted rate of potentially preventable inpatient stays was −14.2% and treat-and-release emergency department visits was −3.0%.

## Data Source

The estimates in this Statistical Brief are based upon an analysis done for the National Healthcare Quality and Disparities Reports (QDR). Inpatient data came from the Healthcare Cost and Utilization Project (HCUP) 2005–2011 Nationwide Inpatient Sample (NIS). For data year 2012, we used an analysis file derived from the HCUP State Inpatient Databases (SID) that was designed to provide national estimates with weighted records from a sample of hospitals from 44 States via the same methodology employed for the 2003–2011 NIS. We did not use the 2012 National Inpatient Sample (NIS) because the sampling design and universe definition was revised. At the time of this analysis, NIS trend weights to make national estimates compatible between 2003–2011 and 2012 were unavailable. Treat-and-release emergency department (ED) data came from the HCUP 2008–2012 Nationwide Emergency Department Sample (NEDS). Although the NEDS is available starting in 2006, this Statistical Brief uses data from 2008 that were compiled for the 2008–2012 QDR. Supplemental sources included population denominator data from Nielsen, a vendor that compiles and adds value to the U.S. Bureau of Census data.^9^ If a patient received observation services (OS) prior to being admitted to the hospital or after being seen in the ED, he or she would be included in the inpatient or ED treat-and-release data used in this analysis. OS were not examined in this Statistical Brief because of variation in how these data are collected across States.

## Definitions

### Prevention Quality Indicators

The Prevention Quality Indicators (PQIs; version 4.4), a component of the AHRQ Quality Indicators (QIs), are a set of measures that can be used with hospital inpatient discharge data to identify access to and quality of care for “ambulatory care-sensitive conditions.” These are conditions for which good outpatient care can potentially prevent the need for hospitalization or for which early intervention can prevent complications or more severe disease. PQI rates can also be affected by other factors such as disease prevalence. The PQIs are adjusted for age and sex using the total U.S. resident population for 2010 as the standard population. Although the PQI software was developed to be used with inpatient data, it was applied to ED data in this Statistical Brief to look at utilization across settings. Several other studies have examined ambulatory care-sensitive conditions across acute care settings.^10,11,12^

Note that the PQI for angina is scheduled to be retired in the next version of the PQI software. A review of angina-related hospitalization using Medicare data found that declines were associated with shifts in coding practices, namely, the increased use of codes specific to coronary artery disease (the underlying disease) rather than angina (the manifestation of that disease).

Further information on the AHRQ QIs, including documentation and free software downloads, is available at http://www.qualityindicators.ahrq.gov/. This Web site also includes information on the Pediatric Quality Indicators (PDIs, formerly known as PedQIs). The PDIs contain measures of potentially preventable hospitalizations for children with asthma, gastroenteritis, diabetes with short-term complications, and perforated appendix. Additional information on how the QI software was applied to the HCUP data for the statistics reported in this Statistical Brief is available in Coffey et al., 2012.^13^

### Case definition

Coding criteria for the five hospital service lines are provided in Table 4 and are based on International Classification of Diseases, Ninth Revision, Clinical Modification (ICD-9-CM) codes, Clinical Classifications Software (CCS) categories, and diagnosis-related groups (DRGs) (see definitions below). Each discharge or visit was assigned to a single hospital service line hierarchically, based on the following order: maternal and neonatal (which were excluded from this Statistical Brief because the PQIs are calculated for nonmaternal stays), mental health, injury, surgical, and medical. Because the surgical and medical groups are defined using DRGs, which are not available in the NEDS, ED visits not classified as maternal/neonatal, mental health, or injury were grouped into an “general medical” category.

Table 4 Coding criteria for the five hospital service lines analyzed in this research

Maternal and neonatal service line
Maternal and neonatal stays are defined using the following CCS [underlined: principal] diagnosis categories: Maternal; - 176: Contraceptive and procreative management; - 177: Spontaneous abortion; - 178: Induced abortion; - 179: Postabortion complications; - 180: Ectopic pregnancy; - 181: Other complications of pregnancy; - 182: Hemorrhage during pregnancy; abruptio placenta; placenta previa; - 183: Hypertension complicating pregnancy; childbirth and the puerperium; - 184: Early or threatened labor; - 185: Prolonged pregnancy; - 186: Diabetes or abnormal glucose tolerance complicating pregnancy; childbirth; or the puerperium; - 187: Malposition; malpresentation; - 188: Fetopelvic disproportion; obstruction; - 189: Previous C-section; - 190: Fetal distress and abnormal forces of labor; - 191: Polyhydramnios and other problems of amniotic cavity; - 192: Umbilical cord complication; - 193: OB-related trauma to perineum and vulva; - 194: Forceps delivery; - 195: Other complications of birth; puerperium affecting management of mother; - 196: Normal pregnancy and/or delivery; Neonatal; - 218: Liveborn; - 219: Short gestation; low birth weight; and fetal growth retardation; - 220: Intrauterine hypoxia and birth asphyxia; - 221: Respiratory distress syndrome; - 222: Hemolytic jaundice and perinatal jaundice; - 223: Birth trauma; - 224: Other perinatal conditions
Mental health service line
Mental health visits are defined using the following CCS [underlined: principal] diagnosis categories: Starting in 2007; - 650: Adjustment disorders; - 651: Anxiety disorders; - 652: Attention-deficit, conduct, and disruptive behavior disorders; - 653: Delirium, dementia, and amnestic and other cognitive disorders; - 654: Developmental disorders; - 655: Disorders usually diagnosed in infancy, childhood, or adolescence; - 656: Impulse control disorders, NEC; - 657: Mood disorders; - 658: Personality disorders; - 659: Schizophrenia and other psychotic disorders; - 660: Alcohol-related disorders; - 661: Substance-related disorders; - 662: Suicide and intentional self-inflicted injury; - 663: Screening and history of mental health and substance abuse codes; - 670: Miscellaneous disorders; 2003 through 2006; - 65: Mental retardation; - 66: Alcohol-related mental disorders; - 67: Substance-related mental disorders; - 68: Senility and organic mental disorders; - 69: Affective disorders; - 70: Schizophrenia and related disorders; - 71: Other psychoses; - 72: Anxiety; somatoform; dissociative; and personality disorders; - 73: Pre-adult disorders; - 74: Other mental conditions; - 75: Personal history of mental disorder; mental and behavioral problems; observation and screening for mental condition
Injury service line
Injuries are identified using the [underlined: principal] diagnosis and a scheme recommended by Safe States Alliance, which was previously known as the State and Territorial Injury Prevention Directors Association (STIPDA). The diagnosis codes in the range 800–999 listed below are used to identify injuries. Included; - 800–909.2, 909.4, 909.9: Fractures; dislocations; sprains and strains; intracranial injury; internal injury of thorax, abdomen, and pelvis; open wound of the head, neck, trunk, upper limb, and lower limb; injury to blood vessels; late effects of injury, poisoning, toxic effects, and other external causes, excluding those of complications of surgical and medical care and drugs, medicinal or biological substances; - 910–994.9: Superficial injury; contusion; crushing injury; effects of foreign body entering through orifice; burns; injury to nerves and spinal cord; traumatic complications and unspecified injuries; poisoning and toxic effects of substances; other and unspecified effects of external causes; - 995.5–995.59: Child maltreatment syndrome; - 995.80–995.85: Adult maltreatment, unspecified; adult physical abuse; adult emotional/psychological abuse; adult sexual abuse; adult neglect (nutritional); other adult abuse and neglect; Excluded; - 909.3, 909.5: Late effect of complications of surgical and medical care and late effects of adverse effects of drug, medicinal, or biological substance; - 995.0–995.4, 995.6–995.7, 995.86, 995.89: Other anaphylactic shock; angioneurotic edema; unspecified adverse effect of drug, medicinal and biological substance; allergy, unspecified; shock due to anesthesia; anaphylactic shock due to adverse food reaction; malignant hyperpyrexia or hypothermia due to anesthesia; - 996–999: Complications of surgical and medical care, not elsewhere classified; It should be noted that the above definition of injury includes five diagnosis codes that also are included under two CCS diagnosis categories used for the definition of the mental health service line:; - CCS = 660 (Alcohol-related disorders): Diagnosis 9800 (toxic effect of ethyl alcohol); - CCS = 661 (Substance-related disorders): Diagnoses 96500 (poisoning by opium), 96501 (poisoning by heroin), 96502 (poisoning by methadone), 96509 (poisoning by other opiate); Because of the hierarchical ordering used to assign discharges to service lines, discharges with one of these five principal diagnosis codes were assigned to the mental health service line and not the injury service line.
Surgical service line
Surgical stays are identified by a surgical DRG. The DRG grouper first assigns the discharge to a major diagnostic category (MDC) based on the principal diagnosis. For each MDC, there is a list of procedure codes that qualify as operating room procedures. If the discharge involves an operating room procedure, it is assigned to one of the surgical DRGs within the MDC category; otherwise, it is assigned to a medical DRG.
Medical service line
Medical stays are identified by a medical DRG. The DRG grouper first assigns the discharge to an MDC, based on the principal diagnosis. For each MDC, there is a list of procedure codes that qualify as operating room procedures. If the discharge involves an operating room procedure, it is assigned to one of the surgical DRGs within the MDC category; otherwise, it is assigned to a medical DRG.

Abbreviations: CCS, Clinical Classifications Software; DRG, diagnosis-related group; NEC, necrotizing enterocolitis; OB, obstetrics

### Diagnoses, ICD-9-CM, Clinical Classifications Software (CCS), and diagnosis-related groups (DRGs)

The principal diagnosis is that condition established after study to be chiefly responsible for the patient’s admission to the hospital. Secondary diagnoses are concomitant conditions that coexist at the time of admission or develop during the stay. All-listed diagnoses include the principal diagnosis plus these additional secondary conditions.

ICD-9-CM is the International Classification of Diseases, Ninth Revision, Clinical Modification, which assigns numeric codes to diagnoses. There are approximately 14,000 ICD-9-CM diagnosis codes.

CCS categorizes ICD-9-CM diagnosis codes into a manageable number of clinically meaningful categories.^14^ This clinical grouper makes it easier to quickly understand patterns of diagnoses. CCS categories identified as Other typically are not reported; these categories include miscellaneous, otherwise unclassifiable diagnoses that may be difficult to interpret as a group.

DRGs comprise a patient classification system that categorizes patients into groups that are clinically coherent and homogeneous with respect to resource use. DRGs group patients according to diagnosis, type of treatment (procedures), age, and other relevant criteria. Each hospital stay has one assigned DRG.

### Types of hospitals included in the HCUP National (Nationwide) Inpatient Sample

The National (Nationwide) Inpatient Sample (NIS) is based on data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). The NIS includes obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded are long-term care facilities such as rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. Beginning in 2012, long-term acute care hospitals are also excluded. However, if a patient received long-term care, rehabilitation, or treatment for psychiatric or chemical dependency conditions in a community hospital, the discharge record for that stay will be included in the NIS.

### Types of hospitals included in the HCUP Nationwide Emergency Department Sample

The Nationwide Emergency Department Sample (NEDS) is based on data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). The NEDS includes specialty, pediatric, public, and academic medical hospitals. Excluded are long-term care facilities such as rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. Hospitals included in the NEDS have hospital-owned emergency departments and no more than 90 percent of their ED visits resulting in admission.

### Types of hospitals included in HCUP State Inpatient Databases

This analysis used State Inpatient Databases (SID) limited to data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). Community hospitals include obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded for this analysis are long-term care facilities such as rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. However, if a patient received long-term care, rehabilitation, or treatment for psychiatric or chemical dependency conditions in a community hospital, the discharge record for that stay was included in the analysis.

### Unit of analysis

The unit of analysis is the hospital discharge (i.e., the hospital stay) or the ED encounter, not a person or patient. This means that a person who is admitted to the hospital or seen in the ED multiple times in 1 year will be counted each time as a separate discharge from the hospital or encounter in the ED.

## For More Information

For more information about HCUP, visit http://www.hcup-us.ahrq.gov/.

For additional HCUP statistics, visit HCUPnet, our interactive query system, at http://hcupnet.ahrq.gov/.

For information on other hospitalizations in the United States, refer to the following HCUP Statistical Briefs located at http://www.hcup-us.ahrq.gov/reports/statbriefs/statbriefs.jsp:

- Statistical Brief #180, Overview of Hospital Stays in the United States, 2012
- Statistical Brief #181, Costs for Hospital Stays in the United States, 2012
- Statistical Brief #186, Most Frequent Operating Room Procedures Performed in U.S. Hospitals, 2012
- Statistical Brief #162, Most Frequent Conditions in U.S. Hospitals, 2011

For a detailed description of HCUP, more information on the design of the National (Nationwide) Inpatient Sample (NIS), the Nationwide Emergency Department Sample (NEDS), and the State Inpatient Databases (SID) and methods to calculate estimates, please refer to the following database documentation:

Agency for Healthcare Research and Quality. Overview of the National (Nationwide) Inpatient Sample (NIS). Healthcare Cost and Utilization Project (HCUP). Rockville, MD: Agency for Healthcare Research and Quality. Updated November 2014. http://www.hcup-us.ahrq.gov/nisoverview.jsp. Accessed January 7, 2015.

Agency for Healthcare Research and Quality. Overview of the Nationwide Emergency Department Sample (NEDS). Healthcare Cost and Utilization Project (HCUP). Rockville, MD: Agency for Healthcare Research and Quality. Updated December 2014. http://www.hcup-us.ahrq.gov/nedsoverview.jsp. Accessed January 7, 2015.

Agency for Healthcare Research and Quality. Overview of the State Inpatient Databases (SID). Healthcare Cost and Utilization Project (HCUP). Rockville, MD: Agency for Healthcare Research and Quality. Updated November 2014. http://www.hcup-us.ahrq.gov/sidoverview.jsp. Accessed January 7, 2015.

1 U.S. Department of Health & Human Services, Health System Measurement Project. (2012). Rate of Hospitalization for Ambulatory Care-Sensitive Conditions per 100,000 People as Defined by the Prevention Quality Indicator Composite for Adults (18+).

2 Weiss AJ, Elixhauser A. (2014). Overview of Hospital Stays in the United States, 2012. HCUP Statistical Brief #180.

3 Sussman JB, Halasyamani LK, Davis MM. (2010). Hospitals during recession and recovery: vulnerable institutions and quality at risk. Journal of Hospital Medicine.

4 Frontstin P. (2010). The Impact of the Recession on Employment-Based Health Coverage. EBRI Issue Brief #342.

5 Minott J. (2008). Reducing Hospital Readmissions.

6 Morganti-Gonzalez K, Baufman S, Blanchard J, Abir M, Iyer N, Smith A, et al. (2013). The Evolving Role of Emergency Departments in the United States. RAND Corporation Research Report Series RR-280-ACEP.

7 Venkatesh AK, Geisler BP, Gibson Chambers JJ, Baugh CW, Bohan JS, et al. (2011). Use of Observation Care in US Emergency Departments, 2001 to 2008. PLoS ONE.

8 Skinner H, Blanchard J, Elixhauser A. (2014). Trends in Emergency Department Visits, 2006–2011. HCUP Statistical Brief #179.

9 Barrett M, Lopez-Gonzalez L, Coffey R, Levit K. (2014). Population Denominator Data for Use With the HCUP Databases (Updated With 2013 Population Data). HCUP Methods Series Report #2014-02.

10 Blecker S, Ladapo JA, Doran KM, Goldfeld KS, Katz S. (2014). Emergency department visits for heart failure and subsequent hospitalization or observation unit admission. American Heart Journal.

11 Galarraga JE, Mutter R, Pines JM. (2015). Costs associated with ambulatory care sensitive conditions across hospital-based settings. Academic Emergency Medicine.

12 Morganti-Gonzalez K, Baufman S, Blanchard J, Abir M, Iyer N, Smith A, et al. (2013). The Evolving Role of Emergency Departments in the United States. RAND Corporation Research Report RR-280-ACEP.

13 Coffey R, Barrett M, Houchens R, Moy E, Andrews R, Coenen N. (2012). Methods Applying AHRQ Quality Indicators to Healthcare Cost and Utilization Project (HCUP) Data for the Eleventh (2013) National Healthcare Quality Report (NHQR) and National Healthcare Disparities Report (NHDR). HCUP Methods Series Report #2012-03.

14 HCUP Clinical Classifications Software (CCS). Healthcare Cost and Utilization Project (HCUP).