# Statistical Brief #194 Trends in Observed Adult Inpatient Mortality for High-Volume Conditions, 2002–2012

## Introduction

Monitoring and improving health care quality in the United States is a key priority for health policymakers, payers, providers, and patient advocates. Hospital inpatient mortality is one quality measure that can reflect both improvements in health care and shifts in where end-of-life care takes place over time.

Previous trends in inpatient mortality suggest that rates have been decreasing for high-volume conditions, such as acute myocardial infarction (AMI), congestive heart failure (CHF), stroke, and pneumonia.^1,2^ These declines in mortality vary not only by condition but also by patient and hospital characteristics. Continued study of these trends can help researchers and policymakers assess the impact of health care quality efforts. Further, examining trends across patient and hospital subgroups may inform strategies for addressing disparities in health care quality by identifying groups that are leading and lagging in improvement.

This Healthcare Cost and Utilization Project (HCUP) Statistical Brief examines trends in observed inpatient mortality rates for AMI, CHF, stroke, and pneumonia for adults aged 18 years and older, as well as changes in these rates for select patient subgroups. Death following discharge from a hospital is not reflected in these data. Observed trends in inpatient mortality from 2002 to 2012 are presented. Percentage changes between 2002 and 2012 are compared by age, sex, expected primary payer, community income level, urban or rural location of patient residence, and hospital region. All differences between estimates noted in the text are statistically significant at the .01 level or better.

## Findings

Highlights

■ Observed inpatient mortality rates among adults declined between 2002 and 2012 for four high-volume conditions: 45 percent decrease for pneumonia, 41 percent decrease for acute myocardial infarction (AMI), 29 percent decrease for congestive heart failure (CHF), and 27 percent decrease for stroke.
■ Inpatient mortality for pneumonia demonstrated the largest decrease of the four conditions across subgroups.
  ▪ Decreases in the inpatient mortality rate for pneumonia were largest for Medicaid and uninsured patients (56 and 55 percent, respectively).
  ▪ Pneumonia mortality decreased by nearly half for patients in all community income groups.
■ Decreases in mortality for CHF and stroke were largest among patients from the poorest communities (34 percent decrease for CHF and 30 percent decrease for stroke).
■ Uninsured patients had the largest decrease in inpatient mortality for stroke (42 percent) compared with Medicare, Medicaid, and privately insured patients.
■ Inpatient mortality for AMI decreased by approximately 40 percent in rural (42 percent), metropolitan (41 percent), and micropolitan (40 percent) areas.

### Inpatient mortality rate trends for four high-volume conditions, 2002–2012

Figure 1 presents observed inpatient mortality rates among adults aged 18 years and older for AMI, CHF, stroke, and pneumonia from 2002 through 2012. The average annual percentage decrease displayed is that by which the rate decreased per year on average during this period.

Figure 1 Trends in observed inpatient mortality rate per 1,000 hospital admissions for four high-volume conditions, 2002–2012

Abbreviations: AMI, acute myocardial infarction; CHF, congestive heart failure

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2002–2011; State Inpatient Databases (SID), 2012, weighted to provide national estimates using the same methodology as the 2002–2011 NIS; and the AHRQ Quality Indicators, version 4.4

Figure 1. Trends in observed inpatient mortality rate per 1,000 hospital admissions for four high-volume conditions, 2002–2012; Figure 1 is a line graph that shows the number of deaths per 1,000 hospital admissions for acute myocardial infarction, congestive heart failure, stroke, and pneumonia for 2002–2012. Deaths per 1,000 hospital admissions for stroke were 112.6 in 2002, 114.0 in 2003, 111.8 in 2004, 105.7 in 2005, 104.0 in 2006, 97.9 in 2007, 99.2 in 2008, 94.1 in 2009, 94.2 in 2010, 83.4 in 2011, and 82.6 in 2012, for an average annual percentage decrease of 3.1%. Deaths per 1,000 hospital admissions for acute myocardial infarction were 94.0 in 2002, 88.4 in 2003, 84.6 in 2004, 78.9 in 2005, 70.7 in 2006, 69.9 in 2007, 67.6 in 2008, 61.7 in 2009, 59.0 in 2010, 58.8 in 2011, and 55.9 in 2012, for an average annual percentage decrease of 5.1%. Deaths per 1,000 hospital admissions for pneumonia were 65.0 in 2002, 58.9 in 2003, 54.9 in 2004, 46.7 in 2005, 42.9 in 2006, 40.8 in 2007, 42.7 in 2008, 41.0 in 2009, 39.2 in 2010, 38.1 in 2011, and 35.8 in 2012, for an average annual percentage decrease of 5.8%. Deaths per 1,000 hospital admissions for congestive heart failure were 44.4 in 2002, 42.5 in 2003, 41.3 in 2004, 39.5 in 2005, 36.5 in 2006, 33.8 in 2007, 34.2 in 2008, 33.3 in 2009, 31.9 in 2010, 32.0 in 2011, and 31.4 in 2012, for an average annual percentage decrease of 3.4%.

■ Between 2002 and 2012, observed inpatient mortality rates decreased among patients admitted for all four high-volume conditions—AMI, CHF, stroke, and pneumonia.
  Across all years, inpatient mortality was highest among patients admitted for stroke and lowest among patients admitted for CHF. From 2002 to 2012, inpatient mortality decreased the most among patients admitted for pneumonia (45 percent decrease, from 65.0 to 35.8 deaths per 1,000 admissions), followed by AMI (41 percent decrease, from 94.0 to 55.9 deaths per 1,000 admissions), CHF (29 percent decrease, from 44.4 to 31.4 deaths per 1,000 admissions), and stroke (27 percent decrease, from 112.6 to 82.6 deaths per 1,000 admissions).
  The average annual percentage decrease in mortality ranged from 3.1 percent for stroke to 5.8 percent for pneumonia.

### Inpatient mortality rates for four high-volume conditions by patient and hospital characteristics, 2002 and 2012

Table 1 presents observed inpatient mortality rates among adults aged 18 years and older for AMI, CHF, stroke, and pneumonia by patient and hospital characteristics in 2002 and 2012.

Table 1 Observed inpatient mortality rate per 1,000 hospital admissions for four high-volume conditions by subgroup, 2002 and 2012

Subgroup | | Acute myocardial infarction | | Congestive heart failure | | Stroke | | Pneumonia
Subgroup | | 2002 | 2012 | 2002 | 2012 | 2002 | 2012 | 2002 | 2012
Overall total | | 94.0 | 55.9 | 44.4 | 31.4 | 112.6 | 82.6 | 65.0 | 35.8
Patient characteristics
Age group, years | 18–64 | 37.0 | 27.3 | 21.1 | 15.7 | 94.7 | 66.5 | 30.0 | 16.4
Age group, years | 65+ | 129.6 | 77.6 | 51.9 | 37.3 | 119.4 | 90.8 | 81.4 | 46.7
Sex | Male | 79.2 | 49.9 | 46.8 | 32.1 | 110.7 | 76.1 | 70.6 | 37.7
Sex | Female | 114.6 | 65.3 | 42.5 | 30.7 | 114.1 | 88.7 | 60.0 | 34.2
Hospital characteristics
Hospital region | Northeast | 98.6 | 61.8 | 51.1 | 35.0 | 118.7 | 87.4 | 77.2 | 37.1
Hospital region | Midwest | 95.4 | 51.1 | 40.4 | 27.4 | 107.7 | 79.8 | 55.4 | 31.7
Hospital region | South | 91.5 | 54.6 | 43.2 | 31.1 | 111.4 | 78.7 | 64.8 | 37.4
Hospital region | West | 91.9 | 59.0 | 44.6 | 33.4 | 115.0 | 89.3 | 66.0 | 36.5

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2002, and State Inpatient Databases (SID), 2012, weighted to provide national estimates using the same methodology as the 2002 NIS; and the AHRQ Quality Indicators, version 4.4

■ Between 2002 and 2012, observed inpatient mortality rates for patients admitted for AMI, CHF, stroke, and pneumonia decreased across patient characteristics; however, the magnitude of the decreases varied by condition and subgroup.
  The inpatient mortality rate for all four high-volume conditions decreased among younger and older patients. The largest declines in mortality were for patients aged 18–64 years with pneumonia (45 percent decrease, from 30.0 to 16.4 deaths per 1,000 admissions) and for patients aged 65 years and older with AMI and pneumonia (40 percent decrease, from 129.6 to 77.6 deaths per 1,000 admissions for AMI, and 43 percent decrease, from 81.4 to 46.7 deaths per 1,000 admissions, for pneumonia).
  Similar to trends by age, inpatient mortality decreased for both males and females during this time period, but in varying magnitude by condition and sex. The largest mortality declines were for males with pneumonia (47 percent decrease, from 70.6 to 37.7 deaths per 1,000 admissions) and for females with AMI and pneumonia (43 percent decrease each, from 114.6 to 65.3 and from 60.0 to 34.2 deaths per 1,000 admissions, respectively).
■ The inpatient mortality rate decreased for patients in all hospital regions; however, the magnitude of the decreases varied by condition and region.
  From 2002 to 2012, the inpatient mortality rate for pneumonia decreased among patients in all regions—decreases ranged from 42 percent in the South to 52 percent in the Northeast. For AMI, decreases in mortality rate ranged from 36 percent in the West to 46 percent in the Midwest. For CHF, decreases ranged from 25 percent in the West to 32 percent in the Northeast and Midwest. The smallest decreases were observed for stroke, ranging from 22 percent in the West to 29 percent in the South.
  Inpatient mortality also decreased by expected primary payer, community income level, and patients' location of residence. For each characteristic, percentage decreases in inpatient mortality between 2002 and 2012 are presented in Figures 2–4 and inpatient mortality rates for 2002 and 2012 are presented in Tables 2–4.

Figure 2 Percentage decrease in observed inpatient mortality rate per 1,000 hospital admissions for four high-volume conditions by expected primary payer, 2002–2012

Abbreviations: AMI, acute myocardial infarction; CHF, congestive heart failure

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2002, and State Inpatient Databases (SID), 2012, weighted to provide national estimates using the same methodology as the 2002 NIS; and the AHRQ Quality Indicators, version 4.4

Figure 2. Percentage decrease in observed inpatient mortality rate per 1,000 hospital admissions for four high-volume conditions by expected primary payer, 2002–2012; Figure 2 is a bar chart that shows the percentage decrease in observed inpatient mortality rate per 1,000 hospital admissions for acute myocardial infarction, congestive heart failure, stroke, and pneumonia between 2002 and 2012 by expected primary payer. The percentage decrease in observed inpatient mortality rate per 1,000 hospital admissions covered by Medicare was 41% for acute myocardial infarction, 31% for congestive heart failure, 27% for stroke, and 46% for pneumonia. The percentage decrease in observed inpatient mortality rate per 1,000 hospital admissions covered by Medicaid was 41% for acute myocardial infarction, 40% for congestive heart failure, 28% for stroke, and 56% for pneumonia. The percentage decrease in observed inpatient mortality rate per 1,000 hospital admissions covered by private insurance was 34% for acute myocardial infarction, 8% for congestive heart failure, 21% for stroke, and 29% for pneumonia. The percentage decrease in observed inpatient mortality rate per 1,000 hospital admissions that were uninsured was 33% for acute myocardial infarction, 35% for congestive heart failure, 42% for stroke, and 55% for pneumonia.

Figure 3 Percentage decrease in observed inpatient mortality rate per 1,000 hospital admissions for selected high-volume conditions by community-level income, 2002–2012

Abbreviations: AMI, acute myocardial infarction; CHF, congestive heart failure

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2002, and State Inpatient Databases (SID), 2012, weighted to provide national estimates using the same methodology as the 2002 NIS; and the AHRQ Quality Indicators, version 4.4

Figure 3. Percentage decrease in observed inpatient mortality rate per 1,000 hospital admissions for selected high-volume conditions by community-level income, 2002–2012; Figure 3 is a bar chart that shows the percentage decrease in observed inpatient mortality rate per 1,000 hospital admissions for acute myocardial infarction, congestive heart failure, stroke, and pneumonia by community-level income between 2002 and 2012. The percentage decrease in observed inpatient mortality rate per 1,000 hospital admissions for patients in the first, or poorest, quartile was 42% for acute myocardial infarction, 34% for congestive heart failure, 30% for stroke, and 43% for pneumonia. The percentage decrease in observed inpatient mortality rate per 1,000 hospital admissions for patients in the second quartile was 41% for acute myocardial infarction, 29% for congestive heart failure, 27% for stroke, and 45% for pneumonia. The percentage decrease in observed inpatient mortality rate per 1,000 hospital admissions for patients in the third quartile was 41% for acute myocardial infarction, 27% for congestive heart failure, 25% for stroke, and 45% for pneumonia. The percentage decrease in observed inpatient mortality rate per 1,000 hospital admissions for patients in the fourth, or wealthiest, quartile was 37% for acute myocardial infarction, 24% for congestive heart failure, 23% for stroke, and 48% for pneumonia.

Figure 4 Percentage decrease in observed inpatient mortality rate per 1,000 hospital admissions for four high-volume conditions by location of patient residence, 2002–2012

Abbreviations: AMI, acute myocardial infarction; CHF, congestive heart failure

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2002, and State Inpatient Databases (SID), 2012, weighted to provide national estimates using the same methodology as the 2002 NIS; and the AHRQ Quality Indicators, version 4.4

Figure 4. Percentage decrease in observed inpatient mortality rate per 1,000 hospital admissions for four high-volume conditions by location of patient residence, 2002–2012; Figure 4 is a bar chart that shows the percentage decrease in observed inpatient mortality rate per 1,000 hospital admissions for acute myocardial infarction, congestive heart failure, stroke, and pneumonia by location of patient residence between 2002 and 2012. The percentage decrease in observed inpatient mortality rate per 1,000 hospital admissions for patients residing in metropolitan areas was 41% for acute myocardial infarction, 31% for congestive heart failure, 26% for stroke, and 47% for pneumonia. The percentage decrease in observed inpatient mortality rate per 1,000 hospital admissions for patients residing in micropolitan areas was 40% for acute myocardial infarction, 24% for congestive heart failure, 29% for stroke, and 42% for pneumonia. The percentage decrease in observed inpatient mortality rate per 1,000 hospital admissions for patients residing in rural areas was 42% for acute myocardial infarction, 23% for congestive heart failure, 28% for stroke, and 34% for pneumonia.

Table 2 Observed inpatient mortality rate per 1,000 hospital admissions for four high-volume conditions by expected primary payer, 2002 and 2012

Expected primary payer | Acute myocardial infarction | | Congestive heart failure | | Stroke | | Pneumonia
Expected primary payer | 2002 | 2012 | 2002 | 2012 | 2002 | 2012 | 2002 | 2012
Medicare | 126.4 | 74.4 | 48.6 | 33.6 | 115.6 | 84.2 | 77.0 | 41.7
Medicaid | 68.1 | 39.8 | 25.1 | 15.0 | 109.7 | 79.1 | 37.0 | 16.1
Private insurance | 39.3 | 25.8 | 33.0 | 30.2 | 94.0 | 74.2 | 38.1 | 27.0
Uninsured | 52.8 | 35.3 | 20.9 | 13.6 | 144.4 | 83.4 | 27.9 | 12.5

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2002, and State Inpatient Databases (SID), 2012, weighted to provide national estimates using the same methodology as the 2002 NIS; and the AHRQ Quality Indicators, version 4.4

Table 3 Observed inpatient mortality rate per 1,000 hospital admissions for four high-volume conditions by community income level, 2002 and 2012

Community income level | Acute myocardial infarction | | Congestive heart failure | | Stroke | | Pneumonia
Community income level | 2002 | 2012 | 2002 | 2012 | 2002 | 2012 | 2002 | 2012
First quartile (poorest) | 99.4 | 57.7 | 41.6 | 27.3 | 114.3 | 80.0 | 61.6 | 35.3
Second quartile | 96.2 | 56.9 | 43.7 | 31.2 | 111.4 | 81.3 | 63.6 | 34.7
Third quartile | 91.6 | 53.7 | 46.5 | 34.0 | 112.7 | 84.3 | 65.7 | 36.4
Fourth quartile (wealthiest) | 86.5 | 54.0 | 48.3 | 36.7 | 111.3 | 86.2 | 73.0 | 37.9

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2002, and State Inpatient Databases (SID), 2012, weighted to provide national estimates using the same methodology as the 2002 NIS; and the AHRQ Quality Indicators, version 4.4

Table 4 Observed inpatient mortality rate per 1,000 hospital admissions for four high-volume conditions by location of patient residence, 2002 and 2012

Location of patient residence | Acute myocardial infarction | | Congestive heart failure | | Stroke | | Pneumonia
Location of patient residence | 2002 | 2012 | 2002 | 2012 | 2002 | 2012 | 2002 | 2012
Metropolitan | 93.2 | 55.4 | 44.3 | 30.8 | 110.9 | 81.8 | 66.5 | 35.4
Micropolitan | 96.2 | 57.7 | 44.3 | 33.5 | 118.2 | 84.4 | 63.7 | 36.7
Rural | 98.6 | 57.1 | 45.4 | 34.8 | 122.7 | 88.6 | 56.6 | 37.2

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2002, and State Inpatient Databases (SID), 2012, weighted to provide national estimates using the same methodology as the 2002 NIS; and the AHRQ Quality Indicators, version 4.4

■ Between 2002 and 2012, inpatient mortality decreased for AMI, stroke, and pneumonia across expected primary payers, but CHF mortality did not decrease significantly across all groups.
  The largest decreases in inpatient mortality were for pneumonia among Medicare patients (46 percent), Medicaid patients (56 percent), and uninsured patients (55 percent). Inpatient mortality decreased by 40 percent or more for four other groups: AMI among Medicare and Medicaid patients (41 percent), CHF among Medicaid patients (40 percent), and stroke among uninsured patients (42 percent). Notably, decreases in CHF mortality among privately insured and uninsured patients did not meet the <.01 standard for statistical significance.
■ Between 2002 and 2012, the inpatient mortality rate decreased for all four conditions among patients across community income levels. Compared with patients in higher-income communities, patients in the poorest communities demonstrated the largest decreases in mortality for AMI, CHF, and stroke.
  Rates of inpatient mortality for pneumonia decreased by nearly half for all community income levels: 43 percent among those in the poorest communities, 45 percent for those in the second and third quartiles, and 48 percent among patients in the wealthiest communities. Decreases in inpatient mortality for AMI represented the second largest decreases—ranging from 37 percent among patients in the wealthiest communities to 42 percent among those in the poorest communities. Decreases in CHF and stroke mortality were largest for patients in the poorest communities (34 and 30 percent, respectively) and smallest for those in the wealthiest communities (24 and 23 percent, respectively).
■ Between 2002 and 2012, the inpatient mortality rate decreased for all four conditions across locations of patient residence.
  The largest decrease in inpatient mortality across locations of patient residence was for patients with pneumonia in metropolitan areas (47 percent). There were also decreases in inpatient mortality of 40 percent or more for patients with AMI in metropolitan (41 percent), micropolitan (40 percent), and rural (42 percent) areas as well as patients with pneumonia in micropolitan areas (42 percent).

## Data Source

The estimates in this Statistical Brief are based upon data from the Healthcare Cost and Utilization Project (HCUP) 2002–2011 Nationwide Inpatient Sample (NIS). For data year 2012, we used an analysis file derived from the HCUP State Inpatient Databases (SID) that was designed to provide national estimates using weighted records from a sample of hospitals from 44 States using the same methodology employed for the 2002–2011 NIS. We did not use the 2012 NIS because the sampling design and universe definition was revised. At the time of this analysis, NIS trend weights for making national estimates compatible between 2002–2011 and 2012 were unavailable.

Numerous hypothesis tests were conducted for this Statistical Brief. Thus, to decrease the number of false-positive results, we reduced the significance to .01 for individual tests.

## Definitions

### Case definition

The study population of adults aged 18 years and older who were hospitalized for AMI, CHF, stroke, and pneumonia was defined using the AHRQ Inpatient Quality Indicator definitions for these conditions (http://www.qualityindicators.ahrq.gov/Modules/iqi_resources.aspx). Mortality rates for these conditions reflect deaths that occurred while a patient was in a hospital and do not reflect any postdischarge deaths.

### Types of hospitals included in the HCUP Nationwide (National) Inpatient Sample

The National (Nationwide) Inpatient Sample (NIS) is based on data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). The NIS includes obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded are long-term care facilities such as rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. Beginning in 2012, long-term acute care hospitals are also excluded. However, if a patient received long-term care, rehabilitation, or treatment for psychiatric or chemical dependency conditions in a community hospital, the discharge record for that stay will be included in the NIS.

### Types of hospitals included in HCUP State Inpatient Databases

This analysis used State Inpatient Databases (SID) limited to data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). Community hospitals include obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded for this analysis are long-term care facilities such as rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. However, if a patient received long-term care, rehabilitation, or treatment for psychiatric or chemical dependency conditions in a community hospital, the discharge record for that stay was included in the analysis.

### Unit of analysis

The unit of analysis is the hospital discharge (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the hospital multiple times in 1 year will be counted each time as a separate discharge from the hospital.

### Average annual percentage change

Average annual percentage change was calculated using the following formula:

Average annual percentage change = [ ( (End value)/(Beginning value) )^(1)/(change in years)^ - 1 ] × 100

### Location of patients' residences

Place of residence is based on the urban-rural classification scheme for U.S. counties developed by the National Center for Health Statistics (NCHS):

- Metropolitan: Central counties of metropolitan areas with 1 million or more residents; fringe counties of metropolitan areas with 1 million or more residents; counties in metropolitan areas of 250,000–999,999 residents; and counties in metropolitan areas of 50,000–249,999 residents
- Micropolitan: Nonmetropolitan counties areas of 10,000 or more residents
- Rural: Nonmetropolitan and nonmicropolitan counties.

### Median community-level income

Median community-level income is the median household income of the patient's ZIP Code of residence. The cut-offs for the quartile designation are determined using ZIP Code demographic data obtained from the Nielsen Company. The income quartile is missing for patients who are homeless or foreign.

### Payer

Payer is the expected primary payer for the hospital stay. To make coding uniform across all HCUP data sources, payer combines detailed categories into general groups:

- Medicare: includes patients covered by fee-for-service and managed care Medicare
- Medicaid: includes patients covered by fee-for-service and managed care Medicaid
- Private Insurance: includes Blue Cross, commercial carriers, and private health maintenance organizations (HMOs) and preferred provider organizations (PPOs)
- Uninsured: includes an insurance status of self-pay and no charge

When more than one payer is listed for a hospital discharge, the first-listed payer is used.

### Region

Region is one of the four regions defined by the U.S. Census Bureau:

- Northeast: Maine, New Hampshire, Vermont, Massachusetts, Rhode Island, Connecticut, New York, New Jersey, and Pennsylvania
- Midwest: Ohio, Indiana, Illinois, Michigan, Wisconsin, Minnesota, Iowa, Missouri, North Dakota, South Dakota, Nebraska, and Kansas
- South: Delaware, Maryland, District of Columbia, Virginia, West Virginia, North Carolina, South Carolina, Georgia, Florida, Kentucky, Tennessee, Alabama, Mississippi, Arkansas, Louisiana, Oklahoma, and Texas
- West: Montana, Idaho, Wyoming, Colorado, New Mexico, Arizona, Utah, Nevada, Washington, Oregon, California, Alaska, and Hawaii

## For More Information

For more information about HCUP, visit http://www.hcup-us.ahrq.gov/.

For additional HCUP statistics, visit HCUPnet, our interactive query system, at http://hcupnet.ahrq.gov/.

For information on other hospitalizations in the United States, refer to the following HCUP Statistical Briefs located at http://www.hcup-us.ahrq.gov/reports/statbriefs/statbriefs.jsp:

- Statistical Brief #180, Overview of Hospital Stays in the United States, 2012
- Statistical Brief #181, Costs for Hospital Stays in the United States, 2012
- Statistical Brief #186, Most Frequent Operating Room Procedures Performed in U.S. Hospitals, 2003–2012
- Statistical Brief #162, Most Frequent Conditions in U.S. Hospitals, 2011

For a detailed description of HCUP and more information on the design of the National (Nationwide) Inpatient Sample (NIS) and State Inpatient Databases (SID), please refer to the following database documentation:

Agency for Healthcare Research and Quality. Overview of the National (Nationwide) Inpatient Sample (NIS). Healthcare Cost and Utilization Project (HCUP). .

Agency for Healthcare Research and Quality. Overview of the State Inpatient Databases (SID). Healthcare Cost and Utilization Project (HCUP). .

1 Hines A, Stranges E, Andrews RM. (2010). Trends in Hospital Risk-Adjusted Mortality for Select Diagnoses by Patient Subgroups, 2000-2007. HCUP Statistical Brief #98. .

2 Stepanova M, Venkatesan C, Altaweel L, Mishra A, Younossi ZM. (2013). Recent trends in inpatient mortality and resource utilization for patients with stroke in the United States: 2005-2009. Journal of Stroke and Cerebrovascular Disease. .