# Statistical Brief #19 Common Injuries That Result in Hospitalization, 2004

## Introduction

In 2004, nearly 5 percent of all hospital stays—about 1.9 million hospitalizations—were for treatment of an injury.^1^ These stays totaled $19.5 billion dollars in hospital costs, accounting for 6.6 percent of the total cost of hospital care in the United States.^2^ In order to reduce the substantial burden of injury on patients, their families, and the hospital care system, it is important to understand the types and causes of common injuries.

This Statistical Brief presents data from the Healthcare Cost and Utilization Project (HCUP) on the most common injuries resulting in hospitalization in 2004. Hospital stays for injury are described by condition, and cause of injury. All differences between estimates noted in the text are statistically significant at the 0.05 level or better.

## Findings

Highlights

- Fractures were the most frequent reason for injury hospitalization in 2004, accounting for over one in two injury stays (52.4 percent). Specifically, hip fractures and leg fractures were the most common fractures, comprising 16.0 percent and 15.0 percent, respectively, of all injury stays.
- Intracranial (brain) injuries had the highest in-hospital death rate (10.2 percent) of all injury hospitalizations. Spinal cord injury was the most expensive injury ($36,900) and required the longest hospital stay (13.5 days).
- Leg fractures were the most common injury across all age groups, except for patients 65 years and older who were hospitalized most frequently for hip fractures (38.1 percent of injury stays among the elderly).
- The second most common injury for patients 18–44 and 45–64 was poisoning by medications other than psychiatric medications (12.7 percent and 9.8 percent, respectively). This condition was also among the top five injuries for patients younger than 18 years.
- By far, the most frequent cause of injury was falls. Over 38 percent of injury stays were the result of falls. Falls resulted in nearly 474,400 injury hospitalizations (67.9 percent) among patients age 65 and older.
- Nearly 15 percent of injury-related stays resulted from motor vehicle traffic accidents and 11.8 percent resulted from poisonings.

### Common injuries that result in hospitalization

Table 1 highlights specific injuries that resulted in hospitalization. Fractures were the most frequent reason for injury hospitalization in 2004, accounting for over one in two injury stays (52.4 percent). Hip fractures and leg fractures were the most common fractures, comprising 16.0 percent and 15.0 percent of all injury stays, respectively. Other fractures included spine, rib, and pelvis fractures (9.9 percent), arm fractures (8.6 percent), and skull and face fractures (2.9 percent).

Table 1 Common injuries resulting in hospitalization, 2004^*^

| Principal diagnosis | Total number of stays | Percentage of injury stays | Mean hospital cost | Mean length of stay (days) | In-hospital death rate
1 | Hip fracture | 304,300 | 16.0% | $12,000 | 6.3 | 2.9%
2 | Leg fracture | 284,900 | 15.0% | $10,700 | 4.7 | 0.6%
3 | Spine, rib and pelvis fractures | 187,500 | 9.9% | $10,200 | 5.5 | 1.4%
4 | Intracranial (brain) injury | 186,100 | 9.8% | $16,300 | 6.8 | 10.2%
5 | Arm fracture | 162,300 | 8.6% | $7,700 | 3.3 | 0.4%
6 | Poisoning by medications other than psychiatric medications | 148,000 | 7.8% | $5,000 | 2.8 | 1.3%
7 | Crushing injury or internal injury | 119,000 | 6.3% | $16,200 | 6.9 | 4.0%
8 | Poisoning by psychiatric drugs | 78,600 | 4.2% | $4,500 | 2.4 | 0.7%
9 | Other injuries | 69,100 | 3.6% | $6,600 | 3.5 | 2.7%
10 | Superficial injury, bruise | 58,100 | 3.1% | $4,300 | 3.0 | 0.5%
11 | Open wounds of arms and legs | 57,500 | 3.0% | $7,100 | 3.6 | 0.2%
12 | Skull and face fractures | 54,900 | 2.9% | $9,700 | 3.6 | 0.6%
13 | Sprains and strains | 53,200 | 2.8% | $4,600 | 2.3 | *
14 | Open wounds of head, neck, and trunk | 43,000 | 2.3% | $6,300 | 2.7 | 0.7%
15 | Burns | 32,500 | 1.7% | $17,600 | 8.9 | 4.1%
16 | Poisoning by substances other than medicine | 24,900 | 1.3% | $5,700 | 2.8 | 1.2%
17 | Joint disorders and dislocations due to trauma | 17,200 | 0.9% | $8,200 | 3.5 | 0.8%
18 | Spinal cord injury | 15,600 | 0.8% | $36,900 | 13.5 | 5.7%
| All injuries | 1,896,587 | 100.0% | $10,300 | 4.8 | 2.4%

* Based on principal diagnosis.

Note: Statistics based on estimates with a relative standard error (standard error/weighted estimate) greater than 0.30 or with standard error = 0 are not reliable. These statistics are suppressed and are designated with an asterisk (*).

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2004.

Other common injury hospitalizations resulted from intracranial (brain) injuries (9.8 percent of injury stays), poisoning by medications other than psychiatric medications (7.8 percent), and crushing or internal injuries (6.3 percent).

Intracranial (brain) injuries had the highest in-hospital death rate (10.2 percent) of all injury hospitalizations. The in-hospital death rates for spinal cord injuries (5.7 percent), burns (4.1 percent), crushing or internal injuries (4.0 percent), and hip fracture (2.9 percent) were also relatively high compared with an overall in-hospital death rate of 2.1 percent. In addition, these injuries (intracranial injuries, spinal cord injuries, burns, internal injuries, and hip fracture) were more expensive and required longer lengths of stay than all other injuries. Spinal cord injury was the most expensive injury ($36,900) and required the longest hospital stay (13.5 days).

### Common injuries, by age

Table 2 provides the 10 most common injuries by age. Hip fractures were the most common injury among patients 65 and older (38.1 percent of injury stays among the elderly) while leg fractures were the most common injury across all other age groups.

Table 2 Top 10 injuries resulting in hospitalization, by age, 2004^*^

Principal diagnosis | Age Group (in years)
Principal diagnosis | 0–17 | | 18–44 | | 45–64 | | 65+
Principal diagnosis | Rank (R), Number of injuries (N) (Percentage of age-specific injury stays)
Principal diagnosis | R | N (%) | R | N (%) | R | N (%) | R | N (%)
Hip fracture | | | | | 6 | 27,800 (7.2%) | 1 | 266,000 (38.1%)
Leg fracture | 1 | 31,700 (15.0%) | 1 | 95,500 (16.1%) | 1 | 80,300 (20.7%) | 3 | 75,800 (10.9%)
Spine, rib and pelvis fractures | | | 6 | 41,500 (7.0%) | 3 | 36,500 (9.4%) | 2 | 102,400 (14.7%)
Intracranial (brain) injury | 3 | 29,200 (13.8%) | 3 | 62,200 (10.5%) | 4 | 35,200 (9.1%) | 4 | 59,100 (8.5%)
Arm fracture | 2 | 30,800 (14.6%) | 7 | 39,300 (6.6%) | 5 | 33,300 (8.6%) | 5 | 57,500 (8.2%)
Poisoning by medications other than psychiatric medications | 4 | 17,500 (8.3%) | 2 | 75,500 (12.7%) | 2 | 37,900 (9.8%) | 10 | 16,900 (2.4%)
Crushing injury or internal injury | 6 | 16,600 (7.9%) | 4 | 59,200 (10.0%) | 7 | 25,700 (6.6%) | 9 | 17,200 (2.5%)
Poisoning by psychiatric drugs | | | 5 | 45,700 (7.7%) | 8 | 21,000 (5.4%)
Other injuries | 5 | 16,700 (7.9%) | | | 10 | 13,300 (3.4%) | 7 | 18,400 (2.6%)
Superficial injury, bruise | | | | | | | 6 | 27,800 (4.0%)
Open wounds of arms and legs | 10 | 7,300 (3.4%) | 8 | 30,500 (5.1%)
Skull and face fractures | 7 | 12,000 (5.7%) | 9 | 27,300 (4.6%)
Sprains and strains | | | | | 9 | 15,500 (4.0%) | 8 | 17,900 (2.6%)
Open wounds of head, neck, and trunk | 9 | 7,600 (3.6%) | 10 | 21,700 (3.7%)
Burns | 8 | 8,700 (4.1%)
Total top 10 | | 178,100 (80.5%) | | 597,500 (85.4%) | | 326,700 (84.4%) | | 659,100 (94.4%)

* Based on principal diagnosis.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2004.

The second most common injury for patients 18–44 and 45–64 was poisoning by medications other than psychiatric medications (12.7 percent and 9.8 percent, respectively). This condition was among the top five injuries for patients younger than 18 years.

Intracranial injury was also in the top five for all age groups, accounting for 13.8 percent of injuries among patients younger than 18, 10.5 percent of injuries among 18–44 year olds, 9.1 percent of injuries among 45–64 year olds, and 8.5 percent of injuries among patients 65 and older.

The fifth most common injury among 18–44 year olds in the hospital was poisoning by psychiatric drugs, accounting for 45,700 hospital stays. For 45–64 year olds and patients 65 and older, arm fracture was the fifth most common injury.

### Causes of injury resulting in hospitalization

Table 3 illustrates causes of injuries that resulted in hospitalization in 2004. By far, the most frequent cause of injury was falls. Over 38 percent of injury stays were the result of falls, while 14.9 percent of injury stays resulted from motor vehicle traffic accidents and 11.8 percent resulted from poisonings.

Table 3 Causes of injuries that result in hospitalization, 2004

Mechanism of injury | Total number of stays | Percentage of injury stays
Fall | 729,100 | 38.4%
Motor vehicle traffic (MVT) | 282,900 | 14.9%
Poisoning | 224,100 | 11.8%
Struck by, against | 75,500 | 4.0%
Cut/pierce | 51,800 | 2.7%
Transportation (not MVT) | 50,000 | 2.6%
Other specified causes of injury | 38,100 | 2.0%
Firearm | 32,100 | 1.7%
Adverse effects of medical drugs | 29,300 | 1.5%
Natural/environment | 27,000 | 1.4%
Overexertion | 26,400 | 1.4%
Fire/burn | 26,000 | 1.4%
Adverse effects of medical care | 17,500 | 0.9%
Pedal cyclist (not MVT) | 17,500 | 0.9%
Machinery | 16,900 | 0.9%
Suffocation | 6,400 | 0.3%
Pedestrian (not MVT) | 3,500 | 0.2%
Drowning/submersion | 3,100 | 0.2%

* Based on all-listed external cause of injury codes; Not all injury discharges have an associated external cause of injury code. “Unspecified” causes of injury codes are omitted from this list.

Source: AHRQ, Center for Delivery, Organization and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2004.

Four percent of all injuries were caused by being struck by or against an object. About 2.7 percent of all injuries were caused by being cut or pierced. About 2.6 percent of injury stays were caused by transportation other than motor vehicles, such as animals, off-road vehicles, trains, aircraft, and boats. Other causes of injury (such as firearms, burns, adverse effects of medical drugs or care, environment, and overexertion including lifting, pulling, pushing or strenuous movements during recreational activities) were implicated in less than 2 percent of all injury hospitalizations each.

### Causes of injury resulting in hospitalization, by age

Figure 1 shows that the major causes of injury stays varied by age. For all age groups except patients age 18–44, falls were the most common cause of injury stays. Falls resulted in nearly 474,400 injury hospitalizations among patients age 65 and older, or 67.9 percent of all injury-related hospitalizations in this age group.

Figure 1 Top three causes of injuries that result in hospitalization, by age, 2004*

*Based on all-listed external cause of injury codes

Source: AHRQ, Center for Delivery, Organization and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2004.

Motor vehicle traffic accidents were the most common cause of injury stays among patients age 18–44 and contributed to nearly 144,800 injury admissions, or 24.4 percent of all injury stays in this age group. Motor vehicle traffic accidents were the second most common cause of injury stays among all other age groups.

Poisonings were commonly noted during injury stays among patients age 18–44 (accounting for 20.1 percent of all injury stays in this age group). Poisoning was also a top cause of injury for patients under 18 years (accounting for 12.3 percent of injury stays) and patients age 45–64 (15.0 percent of injury stays).

## Data Source

The estimates in this Statistical Brief are based on data from the HCUP 2004 Nationwide Inpatient Sample (NIS).

## Definitions

### Types of hospitals included in HCUP

HCUP is based on data from community hospitals, defined as short-term, non-Federal, general and other hospitals, excluding hospital units of other institutions (e.g., prisons). HCUP data include OB-GYN, ENT, orthopedic, cancer, pediatric, public, and academic medical hospitals. They exclude long-term care, rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals, but these types of discharges are included if they are from community hospitals.

### Unit of analysis

The unit of analysis is the hospital discharge (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the hospital multiple times in one year will be counted each time as a separate “discharge” from the hospital.

### Principal diagnosis, ICD-9-CM, and Clinical Classifications Software (CCS)

The principal diagnosis is that condition established after study to be chiefly responsible for the patient’s admission to the hospital.

ICD-9-CM is the International Classification of Diseases, Ninth Revision, Clinical Modification, which assigns numeric codes to diagnoses. There are about 12,000 ICD-9-CM diagnosis codes.

For this Statistical Brief, injuries were defined in a manner consistent with the State and Territorial Injury Prevention Directors Association’s (STIPDA) Consensus Recommendations for Using Hospital Discharge Data for Injury Surveillance.^3^ Records with a principal ICD-9-CM diagnosis code in the range of 800–909.2, 909.4, 909.9, 910–994.9, 995.5–995.59, and 995.80–995.85 were identified as injury hospitalizations. Although not used in this brief, there are other common definitions of injury developed by various sources, such as the American College of Surgeons’ National Trauma Data Bank (http://www.facs.org/trauma/ntdb.html) and the National Center for Health Statistics’ Web report from the National Hospital Discharge Survey (http://www.cdc.gov/nchs/data/ad/ad371.pdf).

CCS categorizes ICD-9-CM diagnoses into 260 clinically meaningful categories. This “clinical grouper” makes it easier to quickly understand patterns of diagnoses and procedures.

For this Statistical Brief, the CCS was used to categorize specific injury diagnoses.

### Cause of injury

The cause of injury is determined by the External Cause of Injury Codes (commonly referred to as E-codes), which supplement the ICD-9-CM diagnosis codes. These codes designate the cause of injury. Multiple E-codes may be present on a single hospital record.

### Costs and charges

Total hospital charges were converted to costs using cost-to-charge ratios based on hospital accounting reports from the Centers for Medicare and Medicaid Services (CMS).^4^ Costs will tend to reflect the actual costs of production, while charges represent what the hospital billed for the case. For each hospital, a hospital-wide cost-to-charge ratio is used because detailed charges are not available across all HCUP States. Hospital charges reflect the amount the hospital charged for the entire hospital stay and does not include professional (physician) fees. For the purposes of this Statistical Brief, costs are reported to the nearest hundreds.

## References

For a detailed description of HCUP and more information on the design of the NIS and methods to calculate estimates, please refer to the following publications:

Steiner, C., Elixhauser, A., Schnaier, J. The Healthcare Cost and Utilization Project: An Overview. Effective Clinical Practice 5(3):143–51, 2002.

Design of the HCUP Nationwide Inpatient Sample, 2004. Online. August 8, 2006. U.S. Agency for Healthcare Research and Quality. http://www.hcup-us.ahrq.gov/db/nation/nis/reports/NIS_2004_Design_Report.pdf

Houchens, R., Elixhauser, A. Final Report on Calculating Nationwide Inpatient Sample (NIS) Variances, 2001. HCUP Methods Series Report #2003-2. Online. June 2005 (revised June 6, 2005). U.S. Agency for Healthcare Research and Quality. http://www.hcup-us.ahrq.gov/reports/CalculatingNISVariances200106092005.pdf

1 The definition of injury used in this statistical brief is consistent with the State and Territorial Injury Prevention Directors Association’s (STIPDA) Consensus Recommendations for Using Hospital Discharge Data for Injury Surveillance. http://stipda.org/associations/5805/files/hdd.pdf (Accessed October 31, 2006)

2 Owens PL, Russo CA, Stocks C. Frequency and Costs of Hospital Admissions for Injury, 2004. HCUP Statistical Brief #18. November 2006, Agency for Healthcare Research and Quality, Rockville, MD. http://www.hcup-us.ahrq.gov/reports/statbriefs/sb18.pdf

3 Injury Surveillance Workgroup. Consensus Recommendations for Using Hospital Discharge Data for Injury Surveillance. Online. 2003. State and Territorial Injury Prevention Directors Association. http://stipda.org/associations/5805/files/hdd.pdf (Accessed October 31, 2006)

4 HCUP Cost-to-Charge Ratio Files (CCR). Healthcare Cost and Utilization Project (HCUP). 2001–2003. U.S. Agency for Healthcare Research and Quality, Rockville, MD. www.hcup-us.ahrq.gov/db/state/costtocharge.jsp