# Statistical Brief #186 Most Frequent Operating Room Procedures Performed in U.S. Hospitals, 2003–2012

## Introduction

Nearly two-thirds of all hospitalizations involve some type of procedure.^1^ Many procedures that occur in the hospital setting, such as blood transfusions and vaccinations, are performed outside the operating room (OR). Other procedures, such as hip replacement and spinal fusion, are surgical in nature and are performed in the OR. In 2011, nearly 29 percent of hospital stays involved OR procedures and 48 percent of hospital costs were for stays that involved OR procedures.^2^ Mean hospital costs for stays with OR procedures were more than double the mean costs for stays without OR procedures.^3^

This Healthcare Cost and Utilization Project (HCUP) Statistical Brief presents data on OR procedures that were performed most frequently in U.S. hospitals in 2012 among all nonmaternal and nonneonatal stays. Only data on OR procedures associated with an inpatient hospital stay are included. The OR procedures with the greatest change in occurrence (either increasing or decreasing) from 2003 to 2012 are provided. Finally, the OR procedures that were performed most frequently and underwent the greatest change in occurrence are presented by patient age group, patient sex, and expected primary payer.

## Findings

Highlights

■ Among hospitalizations for nonmaternal and nonneonatal conditions in 2012, more than one-fourth of stays and half of hospital costs involved stays that included operating room (OR) procedures.
■ The most common inpatient OR procedures in 2012 involved the musculoskeletal system: knee arthroplasty, laminectomy, hip replacement, and spinal fusion.
■ Between 2003 and 2012, the inpatient OR procedures with the greatest change in rate of occurrence overall were gastrectomy (+10.9 percent) and transurethral prostatectomy (TURP) (–10.4 percent).
■ Comparing age groups—Spine and joint procedures were common among all age groups except infants. Brachytherapy (internal radiation therapy) among adults aged 45–84 years had the greatest change in rate of any inpatient OR procedure in any age group, decreasing by about 26 percent annually between 2003 and 2012.
■ Comparing men and women—Musculoskeletal procedures were common among both men and women. The OR procedure with the greatest change in rate among men was brachytherapy (–30.2 percent) and among women was gastrectomy (+14.9 percent).
■ Comparing payer groups—Knee arthroplasty was the most common OR procedure for stays paid by Medicare and by private insurance. Cholecystectomy was most common for stays paid by Medicaid and for uninsured stays.

### Proportion of hospital stays and costs that involved OR procedures, 2012

Figure 1 presents information on hospital stays and costs with and without OR procedures among nonmaternal and nonneonatal hospitalizations.

Figure 1 Hospital stays and hospital costs with and without operating room procedures, 2012

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS), 2012

Figure 1. Hospital stays and hospital costs with and without operating room procedures, 2012; Figure 1 is a bar chart that shows the distribution of hospital stays between those with and those without operating room procedures in 2012 and the distribution of aggregate hospital costs between those two types of hospital stays. Of the 28.4 million hospital stays in 2012, 72.0 million did not include operating procedures and 28.0 million did include operating room procedures. Of the $342.8 billion in aggregate hospital costs in 2012, $50.9 billion was for hospital stays without operating room procedures and $49.1 billion was for hospital stays with operating room procedures.

■ OR procedures were performed during nearly 30 percent of hospital stays in 2012, and these stays accounted for about half of hospital costs.
  In 2012, there were more than 28 million nonmaternal and nonneonatal hospital stays, which cost more than $342 billion. OR procedures were performed during 28.0 percent of these stays, and stays with OR procedures accounted for nearly half (49.1 percent) of total hospital costs.

### OR procedures performed most frequently, 2012

Table 1 presents the all-listed OR procedures that were performed most frequently during hospital stays in 2012.

Table 1 Operating room procedures performed most frequently during hospital stays, 2012

Rank | Procedure | Stays with OR procedure, n | Rate per 100,000 population
Total stays | | 7,958,700 | 2,535.7
1 | Arthroplasty knee | 700,100 | 223.0
2 | Percutaneous coronary angioplasty (PTCA) | 534,600 | 170.3
3 | Laminectomy, excision intervertebral disc | 468,200 | 149.1
4 | Hip replacement, total and partial | 468,000 | 149.1
5 | Spinal fusion | 450,900 | 143.6
6 | Cholecystectomy and common duct exploration | 406,300 | 129.4
7 | Partial excision bone | 338,000 | 107.7
8 | Hysterectomy, abdominal and vaginal | 312,100 | 99.4
9 | Colorectal resection | 305,900 | 97.4
10 | Excision, lysis peritoneal adhesions | 305,800 | 97.4
11 | Appendectomy | 293,000 | 93.3
12 | Treatment, fracture or dislocation of hip and femur | 276,400 | 88.0
13 | Oophorectomy, unilateral and bilateral | 223,800 | 71.3
14 | Coronary artery bypass graft (CABG) | 202,900 | 64.6
15 | Treatment, fracture or dislocation of lower extremity (other than hip or femur) | 188,900 | 60.2

Notes: Includes only nonmaternal and nonneonatal stays. All-listed operating room procedures were identified using Clinical Classifications Software (CCS) procedure categories. Procedures designated as Other are not reported.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS), 2012

■ The most common OR procedures involved the musculoskeletal system.
  Of the 8 million total nonmaternal and nonneonatal hospital stays with an OR procedure, five of the seven most common procedures involved the musculoskeletal system—these were knee arthroplasty (700,100 stays), laminectomy (removal of part of a spinal vertebra, 468,200 stays), hip replacement (468,000 stays), spinal fusion (450,900 stays), and partial excision bone (338,000 stays). Two other common musculoskeletal procedures were trauma-related (treatment of hip fracture and treatment of other lower extremity fracture).
  Another 4 of the 15 most common OR procedures involved the digestive system: cholecystectomy (removal of the gall bladder, 406,300 stays); colorectal resection (305,900 stays); excision, lysis peritoneal adhesions (305,800 stays); and appendectomy (removal of the appendix, 293,000 stays).
  The remaining stays involved OR procedures related to the cardiovascular system—including the second most common procedure, percutaneous coronary angioplasty (PTCA, 534,600 stays), and coronary artery bypass graft (CABG, 202,900 stays)—and procedures involving female genital organs (hysterectomy and oophorectomy).

### OR procedures with the greatest change in occurrence, 2003–2012

Table 2 presents the OR procedures with the greatest change in rate per 100,000 population between 2003 and 2012. The 10 procedures with the greatest increase in rate and the 10 procedures with greatest decrease in rate are presented. Only procedures with a minimum of 50,000 stays in either 2003 or 2012 are reported. Changes in procedure rates may be due to a number of factors, including changes in the prevalence of underlying health conditions treated in ORs and changes in hospital practices, such as a shift in certain procedures to outpatient settings.

Table 2 Operating room procedures with the greatest change in rate, 2003–2012

Rank | Operating room procedure | Stays, n | | Rate per 100,000 population | | Average annual % change in rate, 2003–2012
Rank | Operating room procedure | 2003 | 2012 | 2003 | 2012 | Average annual % change in rate, 2003–2012
Procedure with the greatest increase in rate
1 | Gastrectomy, partial and total | 26,900 | 74,100 | 9.3 | 23.6 | 10.9
2 | Arthroplasty knee | 421,700 | 700,100 | 145.4 | 223.0 | 4.9
3 | Arthroplasty other than hip or knee | 55,900 | 90,000 | 19.3 | 28.7 | 4.5
4 | Partial excision bone | 232,500 | 338,000 | 80.1 | 107.7 | 3.3
5 | Spinal fusion | 316,00 | 450,900 | 108.9 | 143.6 | 3.1
6 | Hip replacement, total and partial | 333,200 | 468,000 | 114.8 | 149.1 | 2.9
7 | Nephrotomy and nephrostomy | 37,200 | 50,200 | 12.8 | 16.0 | 2.5
8 | Nephrectomy, partial or complete | 54,300 | 68,900 | 18.7 | 22.0 | 1.8
9 | Lobectomy or pneumonectomy | 69,100 | 86,700 | 23.8 | 27.6 | 1.7
10 | Heart valve procedures | 98,900 | 123,000 | 34.1 | 39.2 | 1.6
Procedure with the greatest decrease in rate
1 | Transurethral prostatectomy (TURP) | 103,800 | 42,000 | 35.8 | 13.4 | −10.4
2 | Genitourinary incontinence procedures | 116,000 | 47,200 | 40.0 | 15.0 | −10.3
3 | Repair of cystocele and rectocele, obliteration of vaginal vault | 134,500 | 59,600 | 46.4 | 19.0 | −9.4
4 | Oophorectomy, unilateral and bilateral | 451,000 | 223,800 | 155.4 | 71.3 | −8.3
5 | Hysterectomy, abdominal and vaginal | 587,700 | 312,100 | 202.6 | 99.4 | −7.6
6 | Debridement of wound, infection or burn | 276,400 | 148,700 | 95.3 | 47.4 | −7.5
7 | Coronary artery bypass graft (CABG) | 337,400 | 202,900 | 116.3 | 64.6 | −6.3
8 | Laparoscopy | 85,500 | 55,400 | 29.5 | 17.6 | −5.5
9 | Peripheral vascular bypass | 102,700 | 66,600 | 35.4 | 21.2 | −5.5
10 | Creation, revision and removal of arteriovenous fistula or vessel-to-vessel cannula for dialysis | 68,000 | 44,700 | 23.4 | 14.2 | −5.4

Notes: Includes only nonmaternal and nonneonatal stays. All-listed operating room procedures were identified using Clinical Classifications Software (CCS) procedure categories. Procedures designated as Other are not reported.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National (Nationwide) Inpatient Sample (NIS), 2003, 2012

■ The OR procedure with the greatest increase in rate was gastrectomy.
  Between 2003 and 2012, gastrectomy (partial or total removal of the stomach) had the largest increase in rate of occurrence of any OR procedure, increasing by more than 150 percent over 10 years, from 9.3 to 23.6 stays per 100,000 population (10.9 percent average annual increase).
  Procedures to remove other major organs (kidneys and lungs) also were among those with high increases in rate:
  - Nephrectomy (removal of a kidney) was the procedure with the eighth highest increase in rate (1.8 percent average annual increase).
  - Lobectomy (removal of a lung lobe) was the procedure with the ninth highest increase in rate (1.7 percent average annual increase).
■ Five of the six OR procedures with the greatest increase in rate were related to the musculoskeletal system.
  Hospital stays involving knee arthroplasty increased from 421,700 in 2003 to 700,100 in 2012. This procedure underwent the second highest increase in rate, growing by more than 50 percent during the 10-year period, from 145.4 to 223.0 per 100,000 population (4.9 percent average annual increase).
  The OR procedures with third through sixth greatest increase in rate also involved the musculoskeletal system:
  - Arthroplasty, other than the hip or knee (4.5 percent average annual increase)
  - Partial excision bone (3.3 percent average annual increase)
  - Spinal fusion (3.1 percent average annual increase)
  - Partial or total hip replacement (2.9 percent average annual increase)
■ OR procedures involving female or male genital organs or the urinary system had the greatest decrease in rate.
  The OR procedure with the greatest decrease in rate was transurethral prostatectomy (TURP), which decreased by 62.6 percent between 2003 and 2012, from 35.8 to 13.4 per 100,000 population (10.4 percent average annual decrease).
  Genitourinary incontinence OR procedures had the second greatest decrease in rate, decreasing by 62.5 percent from 40.0 to 15.0 per 100,000 population (10.3 percent average annual decrease).
  The OR procedures with the third through fifth greatest decrease in rate involved the female genital system:
  - Repair of cystocele and rectocele (9.4 percent average annual decrease)
  - Oophrectomy (removal of an ovary, 8.3 percent average annual decrease)
  - Hysterectomy (removal of the uterus, 7.6 percent average annual decrease)

### OR procedures with the highest frequency and greatest change in occurrence by patient characteristics, 2012

Tables 3–5 present the OR procedures with the highest frequency and the greatest change in occurrence by patient age group (Table 3), patient sex (Table 4), and expected primary payer (Table 5). Only procedures with a minimum number of stays in either 2003 or 2012 are reported (see table footnotes for the number of minimum stays required for reporting in the three categories—patient age, sex, and payer).

Table 3 Operating room procedures performed most frequently, 2012, and operating room procedures with the greatest change in rate, 2003–2012, by patient age group

Rank | Procedures performed most frequently, 2012 | | Procedures with the greatest change in rate, 2003–2012
Rank | Procedure | n | Procedure | AAPC in rate
Age <1 (nonneonatal), total stays with an OR procedure | | 55,800
1 | Circumcision (on infants other than neonates) | 3,300 | Heart valve procedures | 7.6
2 | Insertion, replacement, or removal of extracranial ventricular shunt | 2,800 | Laparoscopy | 3.8
3 | Inguinal and femoral hernia repair | 2,500 | Circumcision (on infants other than neonates) | 2.7
4 | Colorectal resection | 2,100 | Colorectal resection | 2.6
5 | Heart valve procedures | 1,800 | Appendectomy | −2.5
Age 1–17 years, total stays with an OR procedure | | 290,600
1 | Appendectomy | 68,800 | Debridement of wound, infection or burn | −9.1
2 | Partial excision bone | 14,100 | Treatment, fracture or dislocation of radius and ulna | −4.0
3 | Treatment, fracture or dislocation of hip and femur | 13,400 | Partial excision bone | 3.9
4 | Tonsillectomy and/or adenoidectomy | 13,300 | Spinal fusion | 3.8
5 | Spinal fusion | 11,600 | Treatment, fracture or dislocation of lower extremity (not hip/femur) | −2.1
Age 18–44 years, total stays with an OR procedure | | 1,353,800
1 | Cholecystectomy and common duct exploration | 134,800 | Gastrectomy, partial and total | 24.0
2 | Hysterectomy, abdominal and vaginal | 121,300 | Genitourinary incontinence procedures | −11.9
3 | Appendectomy | 116,900 | Repair of cystocele and rectocele, obliteration of vaginal vault | −11.0
4 | Laminectomy, excision intervertebral disc | 95,700 | Oophorectomy, unilateral and bilateral | −10.8
5 | Spinal fusion | 82,300 | Laparoscopy | −9.6
Age 45–64 years, total stays with an OR procedure | | 2,935,600
1 | Arthroplasty knee | 292,300 | Brachytherapy (internal radiation therapy) | −24.4
2 | Percutaneous coronary angioplasty (PTCA) | 235,500 | Genitourinary incontinence procedures | −11.8
3 | Spinal fusion | 216,200 | Gastrectomy, partial and total | 11.0
4 | Laminectomy, excision intervertebral disc | 214,700 | Transurethral prostatectomy (TURP) | −10.8
5 | Hip replacement, total and partial | 162,800 | Repair of cystocele and rectocele, obliteration of vaginal vault | −10.7
Age 65–84 years, total stays with an OR procedure | | 2,869,500
1 | Arthroplasty knee | 371,300 | Brachytherapy (internal radiation therapy) | −27.3
2 | Percutaneous coronary angioplasty (PTCA) | 240,900 | Transurethral prostatectomy (TURP) | −11.9
3 | Hip replacement, total and partial | 227,500 | Debridement of wound, infection or burn | −9.6
4 | Laminectomy, excision intervertebral disc | 145,800 | Repair of cystocele and rectocele, obliteration of vaginal vault | −9.4
5 | Spinal fusion | 136,200 | Genitourinary incontinence procedures | −8.9
Age 85+ years with an OR procedure | | 451,700
1 | Treatment, fracture or dislocation of hip and femur | 82,800 | Lumpectomy, quadrantectomy of breast | −14.5
2 | Hip replacement, total and partial | 59,100 | Debridement of wound, infection or burn | −10.8
3 | Percutaneous coronary angioplasty (PTCA) | 29,500 | Transurethral prostatectomy (TURP) | −9.9
4 | Colorectal resection | 20,200 | Heart valve procedures | 9.3
5 | Arthroplasty knee | 18,300 | Mastectomy | −9.2

Abbreviation: AAPC, average annual percentage change in the rate of stays per 100,000 population, 2003–2012

Notes: Includes only nonmaternal and nonneonatal stays. All-listed operating room (OR) procedures were identified using Clinical Classifications Software (CCS) procedure categories. Procedures designated as Other are not reported. Procedures with the greatest change in rate include those with a minimum of 1,000 stays (ages <1 years, 85+ years), 5,000 stays (age 1–17 years), or 10,000 stays (ages 18–44, 45–64, 65–84 years) in either 2003 or 2012. CCS 211 (therapeutic radiology) included only one OR procedure: ICD-9 CM procedure code 92.27, implantation or insertion of radioactive elements; this is listed in the table as Brachytherapy (internal radiation therapy).

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National (Nationwide) Inpatient Sample (NIS), 2003, 2012

Table 4 Operating room procedures performed most frequently, 2012, and operating room procedures with the greatest change in rate, 2003–2012, by patient sex

Rank | Procedures performed most frequently, 2012 | | Procedures with the greatest change in rate, 2003–2012
Rank | Procedure | n | Procedure | AAPC in rate
Males, total stays with an OR procedure | | 3,782,600
1 | Percutaneous coronary angioplasty (PTCA) | 357,100 | Brachytherapy (internal radiation therapy) | −30.2
2 | Arthroplasty knee | 267,200 | Transurethral prostatectomy (TURP) | −10.3
3 | Laminectomy, excision intervertebral disc | 235,000 | Debridement of wound, infection or burn | −7.3
4 | Spinal fusion | 209,000 | Coronary artery bypass graft (CABG) | −6.0
5 | Hip replacement, total and partial | 193,600 | Arthroplasty knee | 5.5
Females, total stays with an OR procedure | | 4,175,600
1 | Arthroplasty knee | 432,800 | Gastrectomy, partial and total | 14.9
2 | Hysterectomy, abdominal and vaginal | 312,000 | Genitourinary incontinence procedures | −10.6
3 | Hip replacement, total and partial | 274,400 | Repair of cystocele and rectocele, obliteration of vaginal vault | −9.4
4 | Cholecystectomy and common duct exploration | 253,600 | Oophorectomy, unilateral and bilateral | −8.2
5 | Spinal fusion | 242,000 | Laparoscopy | −8.0

Abbreviation: AAPC, average annual percentage change in the rate of stays per 100,000 population, 2003–2012

Notes: Includes only nonmaternal and nonneonatal stays. All-listed operating room (OR) procedures were identified using Clinical Classifications Software (CCS) procedure categories. Procedures designated as Other are not reported. Procedures with the greatest change in rate include those with a minimum of 25,000 stays in either 2003 or 2012. CCS 211 (therapeutic radiology) included only one OR procedure: ICD-9 CM procedure code 92.27, implantation or insertion of radioactive elements; this is listed in the table as Brachytherapy (internal radiation therapy).

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National (Nationwide) Inpatient Sample (NIS), 2003, 2012

Table 5 Operating room procedures performed most frequently, 2012, and operating room procedures with the greatest change in frequency, 2003–2012, by payer

Rank | Procedures performed most frequently, 2012 | | Procedures with the greatest change in number, 2003–2012
Rank | Procedure | n | Procedure | AAPC in number
Medicare, total stays with an OR procedure | | 3,551,300
1 | Arthroplasty knee | 383,600 | Brachytherapy (internal radiation therapy) | −25.4
2 | Hip replacement, total and partial | 283,200 | Transurethral prostatectomy (TURP) | −9.8
3 | Percutaneous coronary angioplasty (PTCA) | 281,600 | Spinal fusion | 9.4
4 | Treatment, fracture or dislocation of hip and femur | 192,400 | Arthroplasty other than hip or knee | 8.4
5 | Laminectomy, excision intervertebral disc | 173,700 | Repair of cystocele and rectocele, obliteration of vaginal vault | −7.5
Medicaid, total stays with an OR procedure | | 778,000
1 | Cholecystectomy and common duct exploration | 57,800 | Arthroplasty knee | 7.3
2 | Appendectomy | 57,400 | Spinal fusion | 7.1
3 | Hysterectomy, abdominal and vaginal | 38,600 | Partial excision bone | 6.9
4 | Percutaneous coronary angioplasty (PTCA) | 35,900 | Hip replacement, total and partial | 6.0
5 | Spinal fusion | 32,300 | Treatment, fracture or dislocation of lower extremity (not hip/femur) | −4.6
Private, total stays with an OR procedure | | 2,866,700
1 | Arthroplasty knee | 261,300 | Brachytherapy (internal radiation therapy) | −24.1
2 | Laminectomy, excision intervertebral disc | 208,600 | Gastrectomy, partial and total | 18.0
3 | Spinal fusion | 200,000 | Genitourinary incontinence procedures | −11.0
4 | Hysterectomy, abdominal and vaginal | 194,900 | Transurethral prostatectomy (TURP) | −10.0
5 | Percutaneous coronary angioplasty (PTCA) | 160,500 | Repair of cystocele and rectocele, obliteration of vaginal vault | −9.9
Uninsured, total stays with an OR procedure | | 396,700
1 | Cholecystectomy and common duct exploration | 44,400 | Amputation of lower extremity | 9.4
2 | Percutaneous coronary angioplasty (PTCA) | 38,600 | Partial excision bone | 6.9
3 | Appendectomy | 33,400 | Transurethral excision, drainage, or removal urinary obstruction | 6.3
4 | Treatment, fracture or dislocation of lower extremity (other than hip or femur) | 20,500 | Cholecystectomy and common duct exploration | 5.8
5 | Hysterectomy, abdominal and vaginal | 14,400 | Skin graft | 5.5

Abbreviation: AAPC: Average annual percentage change in the number of stays (rate is unavailable by payer), 2003–2012

Notes: Includes only nonmaternal and nonneonatal stays. All-listed operating room (OR) procedures were identified using Clinical Classifications Software (CCS) procedure categories. Procedures designated as Other are not reported. Procedures with the greatest change in number include procedures with a minimum 20,000 stays (Medicare), 10,000 stays (Medicaid), 15,000 stays (private), or 5,000 stays (uninsured) in either 2003 or 2012. CCS 211 (therapeutic radiology) included only one OR procedure: ICD-9 CM procedure code 92.27, implantation or insertion of radioactive elements; this is listed in the table as Brachytherapy (internal radiation therapy).

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National (Nationwide) Inpatient Sample (NIS), 2003, 2012

■ Spine and joint OR procedures were common among all age groups except infants.
  Spinal fusion was one of the five most common OR procedures performed in every age group except infants younger than 1 year and adults 85 years and older.
  Laminectomy was common among adults aged 18–84 years.
  Knee arthroplasty and hip replacement were in the top five OR procedures for adults aged 45 years and older.
■ Brachytherapy performed among adults aged 45–84 years had the greatest change in rate (a decrease) of any OR procedure for any age group between 2003 and 2012.
  Between 2003 and 2012, the rate of hospital stays with brachytherapy (internal radiation therapy) had a 24.4 percent average annual decrease among adults aged 45–64 years and a 27.3 percent average annual decrease among adults aged 65–84 years.
  The OR procedure with the greatest increase in rate was partial or total gastrectomy among adults aged 18–44 years, with an average annual increase of 24.0 percent.
■ Musculoskeletal OR procedures were common among both men and women.
  Knee arthroplasty, spinal fusion, and hip replacement were among the top five most frequently performed OR procedures for both men and women.
  Percutaneous coronary angioplasty (PTCA) and laminectomy were among the most frequently performed procedures for men, and hysterectomy and cholecystectomy were among the most frequently performed procedures for women.
■ Brachytherapy was the OR procedure with the greatest change in rate among men (decreasing), and gastrectomy was the OR procedure with the greatest change in rate among women (increasing).
  From 2003 to 2012, men experienced a 30.2 percent average annual decrease in the rate of brachytherapy and a 10.3 percent average annual decrease in the rate of transurethral prostatectomy (TURP). During the same time period, women experienced a 14.9 percent average annual increase in the rate of partial or total gastrectomy and a 10.6 percent average annual decrease in the rate of genitourinary incontinence procedures.
■ Knee arthroplasty was the most common OR procedure for hospital stays paid by Medicare and by private insurance.
  Among hospitalizations that involved an OR procedure, knee arthroplasty was the OR procedure performed most frequently during hospital stays paid by Medicare (10.8 percent of stays) and by private insurance (9.1 percent). Knee arthroplasty was not among the top five most frequently performed OR procedures for stays paid by Medicaid or for uninsured stays.
■ Cholecystectomy was the most common OR procedure for hospital stays paid by Medicaid and for uninsured stays.
  Cholecystectomy was the most frequently performed OR procedure during hospital stays paid by Medicaid (7.4 percent of stays involving an OR procedure) and during uninsured stays (11.2 percent). Cholecystectomy was not among the top five most frequently performed OR procedures for stays paid by Medicare or private insurance.
■ Percutaneous coronary angioplasty (PTCA) was among the most common procedures for hospital stays across all payers.
  PTCA was among the five procedures that were performed most frequently during hospital stays that involved an OR procedure for all types of payers: Medicare (7.9 percent of stays), Medicaid (4.6 percent), private insurance (5.6 percent), and uninsured (9.7 percent)
■ Brachytherapy was the OR procedure with the greatest change in occurrence among hospital stays paid by Medicare and private insurance.
  The number of hospital stays involving brachytherapy decreased by an average of approximately 25 percent annually among stays paid by Medicare and private insurance.
■ OR procedures related to the musculoskeletal system were among those with the greatest change in occurrence for stays paid by Medicaid and for uninsured stays.
  The five OR procedures with the greatest change in occurrence for stays paid by Medicaid involved the musculoskeletal system, including knee arthroplasty (7.3 percent average annual increase), spinal fusion (7.1 percent average annual increase), and partial excision bone (6.9 percent average annual increase).
  Among uninsured hospital stays, the two OR procedures with the greatest change in occurrence also involved the musculoskeletal system: amputation of lower extremity (9.4 percent average annual increase) and partial excision bone (6.9 percent average annual increase).

## Data Source

The estimates in this Statistical Brief are based upon data from the Healthcare Cost and Utilization Project (HCUP) 2012 National Inpatient Sample (NIS). Historical data were drawn from the 2003 Nationwide Inpatient Sample (NIS). The statistics were generated from HCUPnet, a free, online query system that provides users with immediate access to the largest set of publicly available, all-payer national, regional, and State-level hospital care databases from HCUP.^4^

## Definitions

### Procedures, ICD-9-CM, Clinical Classifications Software (CCS), major diagnostic categories (MDCs), and diagnosis-related groups (DRGs)

All-listed procedures include all procedures performed during the hospital stay, whether for definitive treatment or for diagnostic or exploratory purposes.

ICD-9-CM is the International Classification of Diseases, Ninth Revision, Clinical Modification, which assigns numeric codes to procedures. There are approximately 4,000 ICD-9-CM procedure codes.

CCS categorizes ICD-9-CM procedure codes into a manageable number of clinically meaningful categories.^5^ This clinical grouper makes it easier to quickly understand patterns of procedure use. CCS categories identified as Other typically are not reported; these categories include miscellaneous, otherwise unclassifiable procedures that may be difficult to interpret as a group.

MDCs assign ICD-9-CM principal diagnosis codes to one of 25 general diagnosis categories. For this report, maternal and neonatal discharges were excluded from the analysis. Maternal hospital stays were identified using MDC 14 (pregnancy, childbirth, and the puerperium), and neonatal hospital stays were identified using MDC 15 (newborns and other neonates with conditions originating during the perinatal period).

DRGs comprise a patient classification system that categorizes patients into groups that are clinically coherent and homogeneous with respect to resource use. DRGs group patients according to diagnosis, type of treatment (procedure), age, and other relevant criteria. Each hospital stay has one assigned DRG. For this report, major operating room (OR) procedures were defined using procedure classes that categorize each ICD-9-CM procedure code as major therapeutic, major diagnostic, minor therapeutic, or minor diagnostic.^6^ Major OR procedures are considered to be valid OR procedures based on DRGs. This classification scheme relies on physician panels that classify ICD-9-CM procedure codes according to whether the procedure would be performed in a hospital OR in most hospitals. Major OR procedures were identified using all procedure fields (first-listed and secondary) that were available on the discharge record.

### Types of hospitals included in the HCUP National (Nationwide) Inpatient Sample

The National (Nationwide) Inpatient Sample is based on data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). The NIS includes obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded are long-term care facilities such as rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. Beginning in 2012, long-term acute care hospitals are also excluded. However, if a patient received long-term care, rehabilitation, or treatment for psychiatric or chemical dependency conditions in a community hospital, the discharge record for that stay will be included in the NIS.

### Costs and charges

Total hospital charges were converted to costs using HCUP Cost-to-Charge Ratios based on hospital accounting reports from the Centers for Medicare & Medicaid Services (CMS).^7^ Costs reflect the actual expenses incurred in the production of hospital services, such as wages, supplies, and utility costs; charges represent the amount a hospital billed for the case. For each hospital, a hospital-wide cost-to-charge ratio is used. Hospital charges reflect the amount the hospital billed for the entire hospital stay and do not include professional (physician) fees.

### How HCUP estimates of costs differ from National Health Expenditure Accounts

There are a number of differences between the costs cited in this Statistical Brief and spending as measured in the National Health Expenditure Accounts (NHEA), which are produced annually by the Centers for Medicare & Medicaid Services (CMS).^8^ The largest source of difference comes from the HCUP coverage of inpatient treatment only in contrast to the NHEA inclusion of outpatient costs associated with emergency departments and other hospital-based outpatient clinics and departments as well. The outpatient portion of hospitals' activities has been growing steadily and may exceed half of all hospital revenue in recent years. On the basis of the American Hospital Association Annual Survey, 2012 outpatient gross revenues (or charges) were about 44 percent of total hospital gross revenues.^9^

Smaller sources of differences come from the inclusion in the NHEA of hospitals that are excluded from HCUP. These include Federal hospitals (Department of Defense, Veterans Administration, Indian Health Services, and Department of Justice [prison] hospitals) as well as psychiatric, substance abuse, and long-term care hospitals. A third source of difference lies in the HCUP reliance on billed charges from hospitals to payers, adjusted to provide estimates of costs using hospital-wide cost-to-charge ratios, in contrast to the NHEA measurement of spending or revenue. HCUP costs estimate the amount of money required to produce hospital services, including expenses for wages, salaries, and benefits paid to staff as well as utilities, maintenance, and other similar expenses required to run a hospital. NHEA spending or revenue measures the amount of income received by the hospital for treatment and other services provided, including payments by insurers, patients, or government programs. The difference between revenues and costs include profit for for-profit hospitals or surpluses for nonprofit hospitals.

### Unit of analysis

The unit of analysis is the hospital discharge (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the hospital multiple times in 1 year will be counted each time as a separate discharge from the hospital.

### Average annual percentage change

Average annual percentage change is calculated using the following formula:

Average annual percentage change = [ ( (End value)/(Beginning value) )^(1)/(change in years)^ − 1 ] × 100

### Payer

Payer is the expected primary payer for the hospital stay. To make coding uniform across all HCUP data sources, payer combines detailed categories into general groups:

- Medicare: includes patients covered by fee-for-service and managed care Medicare
- Medicaid: includes patients covered by fee-for-service and managed care Medicaid
- Private Insurance: includes Blue Cross, commercial carriers, and private health maintenance organizations (HMOs) and preferred provider organizations (PPOs)
- Uninsured: includes an insurance status of self-pay and no charge
- Other: includes Worker's Compensation, TRICARE/CHAMPUS, CHAMPVA, Title V, and other government programs.

Hospital stays billed to the State Children's Health Insurance Program (SCHIP) may be classified as Medicaid, Private Insurance, or Other, depending on the structure of the State program. Because most State data do not identify patients in SCHIP specifically, it is not possible to present this information separately.

When more than one payer is listed for a hospital discharge, the first-listed payer is used.

## For More Information

For more information about HCUP, visit http://www.hcup-us.ahrq.gov/.

For additional HCUP statistics, visit HCUPnet, our interactive query system, at http://hcupnet.ahrq.gov/.

For information on other hospitalizations in the United States, refer to the following HCUP Statistical Briefs located at http://www.hcup-us.ahrq.gov/reports/statbriefs/statbriefs.jsp:

- Statistical Brief #180, Overview of Hospitalizations in the United States, 2012
- Statistical Brief #181, Costs for Hospital Stays in the United States, 2012
- Statistical Brief #170, Characteristics of Operating Room Procedures in U.S. Hospitals, 2011
- Statistical Brief #162, Most Frequent Conditions in U.S. Hospitals, 2011

For a detailed description of HCUP and more information on the design of the National (Nationwide) Inpatient Sample (NIS), please refer to the following database documentation:

Agency for Healthcare Research and Quality. Overview of the National (Nationwide) Inpatient Sample (NIS). Healthcare Cost and Utilization Project (HCUP). .

1 Pfuntner A, Wier LM, Stocks C. (2013). Most Frequent Procedures Performed in U.S. Hospitals, 2011. HCUP Statistical Brief #165. .

2 Weiss AJ, Elixhauser A, Andrews RM. (2014). Characteristics of Operating Room Procedures in U.S. Hospitals, 2011. HCUP Statistical Brief #170. .

3 Ibid.

4 Agency for Healthcare Research and Quality. HCUPnet Web site. .

5 Agency for Healthcare Research and Quality. HCUP Clinical Classifications Software (CCS). Healthcare Cost and Utilization Project (HCUP). .

6 Agency for Healthcare Research and Quality. HCUP Procedure Classes. Healthcare Cost and Utilization Project (HCUP). .

7 Agency for Healthcare Research and Quality. (2001–2011). HCUP Cost-to-Charge Ratio (CCR) Files. Healthcare Cost and Utilization Project (HCUP). .

8 For additional information about the NHEA, see Centers for Medicare & Medicaid Services (CMS). (2014). National Health Expenditure Data. CMS Web site. .

9 American Hospital Association. Trend Watch Chartbook, 2014. Table 4.2. Distribution of Inpatient vs. Outpatient Revenues, 1992–2012. .