# Statistical Brief #181 Costs for Hospital Stays in the United States, 2012

## Introduction

In 2012, health care expenditures in the United States accounted for more than 17 percent of the Gross Domestic Product (GDP).^1^ Importantly, although only 7 percent of the civilian noninstitutionalized population in the United States had an inpatient hospital stay in 2011, the spending associated with those stays accounted for 29 percent of all health care expenses, making hospitalization one of the most expensive types of health care treatments.^2^

This Healthcare Cost and Utilization Project (HCUP) Statistical Brief presents data on the costs of hospital stays in the United States in 2012.^3^ First, the distribution of hospital inpatient costs in 2012 by expected primary payer and type of hospital stay is provided. Second, growth in mean hospital costs between 2003 and 2012 is presented by type of hospital stay, patient age group, and expected primary payer. Finally, components of growth in aggregate annual hospital costs between 2003 and 2012 are provided. All differences between mean hospital costs noted in the text are statistically significant at the .001 level or better. Differences between proportions noted in the text differ by at least 10 percent.

## Findings

#### Highlights

■ Of the $377.5 billion aggregate hospital inpatient costs in 2012, 46 percent was for Medicare-covered stays and 16 percent was for Medicaid-covered stays. Thus, patients covered by government payers accounted for at least 62 percent of all hospital costs.
■ More than half of Medicare-covered and uninsured stays were medical (55 percent and 54 percent, respectively). More than half of stays covered by private insurance were surgical (52 percent).
■ Maternal and neonatal stays constituted 27 percent of costs for Medicaid, 15 percent of costs for private insurers, and 4 percent of costs for uninsured patients.
■ Mean hospital costs in 2012 were highest for surgical stays ($21,200)—2.5 times the mean costs for medical stays ($8,500) and nearly five times the mean costs for maternal and neonatal stays ($4,300).
■ Patients aged 45–64 and 65–84 years had the highest mean hospital costs in 2012 ($12,900 and $13,000, respectively), but patients under age 18 had the highest growth in mean costs between 2008 and 2012 (more than 6 percent annually).
■ Among payers of hospital stays, Medicare had the highest mean hospital costs in 2012 ($12,200), but between 2008 and 2012 mean Medicare costs grew at the lowest annual rate (0.9 percent).
■ Average annual growth in aggregate hospital costs slowed from 5.2 percent in the 2003–2008 time period to 2.1 percent in the 2008–2012 time period.

### Aggregate hospital inpatient costs by payer and type of hospital stay, 2012

Figure 1 presents the aggregate hospital costs and total hospital stays by expected primary payer in 2012.

Figure 1 Aggregate hospital costs and hospital stays by payer, 2012

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS), 2012

Figure 1. Aggregate hospital costs and hospital stays by payer, 2012. Figure 1 is a bar chart that shows the percentage of aggregate hospital costs and total hospital stays in 2012 that were covered by Medicare, Medicaid, or private insurance, or were uninsured. Aggregate hospital costs totaled $377.5 billion. 46% was covered by Medicare, 16% by Medicaid, and 29% by private insurance; 5% were uninsured, and 4% were Other. Of the 36.5 million hospital stays, 39% were covered by Medicare, 21% by Medicaid, and 31% by private insurance; 6% were uninsured, and 4% were Other. Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS), 2012

■ In 2012, Medicare accounted for the largest proportion of hospital costs (46 percent) and hospital stays (39 percent).
  Patients with primary Medicare coverage accounted for 46 percent of the $377.5 billion in aggregate hospital costs in 2012. Private insurance was the second most common payer, accounting for 29 percent of total costs, followed by Medicaid with 16 percent of costs. Stays of uninsured patients represented 5 percent of total hospital costs. In total, government payers (Medicare and Medicaid) accounted for at least 62 percent of all hospital costs.
  Patients covered by Medicare accounted for a larger proportion of aggregate hospital costs (46 percent) than of hospital stays (39 percent). In contrast, patients covered by Medicaid accounted for only 16 percent of hospital costs but 21 percent of hospital stays.

Figure 2 presents the distribution of costs by primary payer and type of hospital stay—surgical, medical, and maternal and neonatal—in 2012.

Figure 2 Aggregate costs by payer and type of stay, 2012

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS), 2012

Figure 2. Aggregate costs by payer and type of stay, 2012. Figure 2 is a bar chart that shows the costs of hospital stays paid by Medicare, Medicaid, and private insurance and those that were uninsured. For each payer, the distribution of those costs among surgical stays, medical stays, and maternal and neonatal stays is presented. Of the $174.6 billion in Medicare costs, 45% were for surgical stays and 55% were for medical stays. Of the $61.7 billion in Medicaid costs, 30% were for surgical stays, 43% for medical stays, and 27% for maternal and neonatal stays. Of the $107.8 billion paid by private insurance, 52% were for surgical stays, 34% were for medical stays, and 15% were for maternal and neonatal stays. Of the $18.1 billion in costs for uninsured stays, 42% were for surgical stays, 54% were for medical stays, and 4% were for maternal and neonatal stays. Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS), 2012

■ In 2012, medical stays constituted the largest proportion of hospital costs for all payers except private insurance.
  Medical hospitalizations accounted for 55 percent of aggregate Medicare hospital costs, 54 percent of aggregate hospital costs for uninsured patients, and 43 percent of aggregate Medicaid hospital costs. Among privately insured patients, the highest proportion of aggregate hospital costs was for surgical stays (52 percent).
  Maternal and neonatal stays accounted for 27 percent of aggregate hospital costs for patients covered by Medicaid compared with 15 percent of aggregate hospital costs for privately insured patients and 4 percent of aggregate costs for uninsured patients.

### Growth in mean hospital costs by type of hospital stay, patient age, and primary payer, 2003–2012

Table 1 presents mean hospital costs per stay in 2003, 2008, and 2012 by type of hospital stay, patient age group, and expected primary payer. The average annual percentage change from 2003 to 2008 and from 2008 to 2012 also is provided. All costs are inflation adjusted and expressed in 2012 dollars.

Table 1 Inflation-adjusted mean hospital costs per stay, 2003, 2008, and 2012

Characteristic | Mean hospital costs per stay (inflation-adjusted), $ | | | Average annual change, %
Characteristic | 2003 | 2008 | 2012 | 2003–2008 | 2008–2012
All stays | 8,800 | 9,600 | 10,400 | 1.8 | 1.8
Type of stay
Surgical | 17,300 | 19,100 | 21,200 | 2.0 | 2.6
Medical | 7,500 | 8,100 | 8,500 | 1.7 | 1.2
Maternal and neonatal | 3,500 | 3,700 | 4,300 | 1.0 | 3.8
Patient age group, years
<1 | 3,600 | 3,800 | 5,000 | 1.3 | 6.7
1–17 | 6,500 | 7,700 | 9,900 | 3.6 | 6.4
18–44 | 6,700 | 7,100 | 7,600 | 1.3 | 1.8
45–64 | 11,300 | 12,300 | 12,900 | 1.7 | 1.2
65–84 | 11,500 | 12,400 | 13,000 | 1.6 | 1.1
85+ | 9,200 | 9,900 | 10,200 | 1.5 | 0.8
Primary payer
Medicare | 11,000 | 11,800 | 12,200 | 1.4 | 0.9
Medicaid | 6,900 | 7,300 | 8,100 | 1.3 | 2.5
Private insurance | 7,600 | 8,800 | 9,700 | 2.9 | 2.4
Uninsured | 7,500 | 7,700 | 8,800 | 0.5 | 3.5

Note: Data from 2008 were used as end points in both the 2003–2008 and 2008–2012 analyses.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National (Nationwide) Inpatient Sample (NIS), 2003, 2008, and 2012

■ Mean hospital costs were highest for surgical stays and lowest for maternal and neonatal stays.
  In 2012, mean hospital costs per stay for surgical stays ($21,200) were 2.5 times the mean costs for medical stays ($8,500) and approximately five times the mean costs for maternal and neonatal stays ($4,300).
  Between 2003 and 2012, inflation-adjusted mean hospital costs increased for all types of stays. Between 2003 and 2008, annual cost growth ranged from 1.0 percent for maternal and neonatal stays to 2.0 percent for surgical stays. Between 2008 and 2012, annual cost growth was 3.8 percent for maternal and neonatal stays compared with 2.6 percent for surgical stays and 1.2 percent for medical stays.
■ Between 2008 and 2012, growth in mean hospital costs per stay was highest for patients aged 17 years and younger.
  Mean hospital costs in 2012 were highest for patients aged 45–64 and 65–84 years ($12,900 and $13,000, respectively) and lowest for infants younger than 1 year ($5,000). Between 2003 and 2008, growth in inflation-adjusted mean hospital costs was relatively similar across patient age groups, ranging from 1.3 to 3.6 percent per year. From 2008 to 2012, average annual cost growth was more than 6 percent in the two youngest age groups and less than 2 percent in all adult age groups.
■ Medicare-covered stays had high mean hospital costs but slow growth between 2008 and 2012.
  Mean hospital costs in 2012 were highest for hospital stays billed to Medicare: $12,200 compared with $8,100 for Medicaid-covered stays, $8,800 for stays for uninsured patients, and $9,700 for privately insured stays. Between 2003 and 2008, average annual growth in inflation-adjusted mean costs varied from 0.5 percent for stays for uninsured patients to 2.9 percent for stays for privately insured patients. Between 2008 and 2012, average annual cost growth exceeded 2 percent for patients covered by Medicaid (2.5 percent) and private insurance (2.4 percent) and for patients who were uninsured (3.5 percent); it was less than 1 percent for patients covered by Medicare (0.9 percent).

### Components of growth in aggregate hospital costs by type of hospital stay, 2003–2012

Figure 3 presents the components of growth in aggregate hospital costs by type of stay for the 2003–2008 and 2008–2012 time periods. It differs from Table 1 in that it takes into account additional factors (inflation, changes in the number of stays per population, and population growth) that contribute to the increase in aggregate costs. In addition, Figure 3 decomposes the mean hospital costs per stay in Table 1 into mean costs per day and length of stay (LOS).^4^ Thus, growth in aggregate hospital costs was deconstructed into five components: population growth, change in number of stays per population, change in average LOS, growth in inflation-adjusted mean hospital costs per day, and inflation.

Figure 3 Factors accounting for growth in aggregate annual hospital costs by type of stay, 2003–2008 and 2008–2012

LOS: Length of stay

Notes: Average annual growth in length of stay was 0.1% for medical stays and for maternal and neonatal stays during the 2003–2008 time period. Data from 2008 were used as end points in both the 2003–2008 and the 2008–2012 analyses.

Sources: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National (Nationwide) Inpatient Sample (NIS), 2003, 2008, and 2012, and HCUP Methods Series Report #2014-02, Population Denominator Data for Use with the HCUP Databases.

Figure 3. Factors accounting for growth in aggregate hospital costs by type of stay, 2003–2008 and 2008–2012. Figure 3 is a bar chart that shows the extent to which population growth, the change in number of stays per population, the change in average length of stay, growth in inflation-adjusted mean hospital costs per day, and inflation accounted for growth in aggregate hospital costs for all stays, for surgical stays, for medical stays, and for maternal and neonatal stays, for the 2003–2008 and 2008–2012 time periods. For 2003–2008, factors accounting for growth in aggregate hospital costs for all stays: length of stay, −0.2%; number of stays per population, −0.3%; population growth, 0.9%; inflation, 2.7%; inflation-adjusted mean hospital costs per day, 2.0%, for a total growth in aggregate costs for all stays of 5.2%. Factors accounting for growth in aggregate hospital costs for surgical stays: length of stay, −0.8%, number of stays per population, −0.2%; population growth, 0.9%; inflation, 2.7%; inflation-adjusted mean hospital costs per day, 2.8%, for a total growth in aggregate costs for surgical stays of 5.4%. Factors accounting for growth in aggregate costs for medical stays: number of stays per population, −0.3%; population growth, 0.9%; inflation, 2.7%; length of stay, 0.1%; inflation-adjusted mean hospital costs per day, 1.6%, for a total growth in aggregate costs for medical stays of 5.1%. Factors accounting for growth in aggregate costs for maternal and neonatal stays: number of stays per population, −0.5%; population growth, 0.9%; inflation, 2.7%; length of stay, 0.1%; inflation-adjusted mean hospital costs, 0.9%, for a total growth in aggregate costs for maternal and neonatal stays of 4.2%. For 2008–2012, factors accounting for growth aggregate hospital costs for all stays: length of stay, −0.2%; number of stays per population −1.9%; population growth, 0.8%; inflation, 1.4%; inflation-adjusted mean hospital costs per day, 2.0%, for a total growth in aggregate costs for all stays of 2.1%. Factors accounting for growth in aggregate costs for surgical stays: length of stay, −0.1%, number of stays, −3.0%; population growth, 0.8%; inflation 1.4%; inflation-adjusted mean hospital costs per day, 2.8%, for a total growth in aggregate costs for surgical stays of 1.7%. Factors accounting for growth in aggregate costs for medical stays: length of stay, −0.7%; number of stays per population, −1.2%; population growth, 0.8%; inflation, 1.4%; inflation-adjusted mean hospital costs per day, 1.9%, for a total growth in aggregate costs for surgical stays of 2.3%. Factors accounting for growth in aggregate hospital costs for maternal and neonatal stays: number of stays per population, −2.7%; population growth, 0.8%; inflation, 1.4%; length of stay, 1.2%; inflation-adjusted mean hospital costs, 2.6%, for a total growth in aggregate costs for maternal and neonatal stays of 3.3%. Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National (Nationwide) Inpatient Sample (NIS), 2003, 2008, and 2012

Component-specific cost reductions are shown to the left of the center line (which denotes zero average annual growth), and component-specific cost increases are shown to the right of the center line. Overall growth in aggregate hospital costs (combining all five components) for each type of stay is shown in bold to the right of the bars.

■ A decrease in inflation and in the number of hospital stays per population drove a reduction in the rate of growth in aggregate hospital costs between the 2003–2008 and 2008–2012 time periods.
  Aggregate unadjusted (i.e., nominal) hospital costs for all stays grew from $269.5 billion in 2003 to $347.1 billion in 2008 (5.2 percent average annual growth). This growth was driven primarily by economy-wide inflation (2.7 percent per year), growth in inflation-adjusted mean hospital costs per day (2.0 percent per year), and population growth (0.9 percent per year).
  Aggregate unadjusted hospital costs increased to $377.5 billion in 2012, but between 2008 and 2012 the average annual growth of hospital costs slowed to 2.1 percent. This slowdown in overall cost growth was driven by a combination of lower inflation (1.4 percent annual rate) and a decrease in the number of hospital stays per population (–1.9 percent average annual change).
■ Between 2008 and 2012, growth in aggregate hospital costs slowed the most for surgical stays and the least for maternal and neonatal stays.
  For surgical stays, the average annual growth in aggregate hospital costs slowed from 5.4 percent during the 2003–2008 time period to only 1.7 percent during the 2008–2012 time period. This decrease in cost growth was driven primarily by a 3.0 percent average annual decrease in the number of surgical stays per population as well as a more modest 1.4 percent inflation rate. The decline in cost growth of surgical stays may be due in part to the movement of simpler procedures to ambulatory settings.
  For maternal and neonatal stays, the average annual growth in aggregate hospital costs slowed somewhat (from 4.2 percent in the 2003–2008 time period to 3.3 percent in the 2008–2012 time period). Although the inflation rate declined and there was a 2.7 percent average annual decrease in the number of maternal and neonatal stays per population, growth in the average length of stay increased dramatically—from 0.1 percent during the 2003–2008 time period to 1.2 percent during the 2008–2012 time period. In addition, between 2008 and 2012 average inflation-adjusted mean hospital costs per day grew at nearly three times the rate experienced between 2003 and 2008 (2.6 percent vs. 0.9 percent).

## Data Source

The estimates in this Statistical Brief are based upon data from the Healthcare Cost and Utilization Project (HCUP) 2012 National Inpatient Sample (NIS). Historical data were drawn from the 2003 and 2008 Nationwide Inpatient Sample (NIS). The statistics were generated from HCUPnet, a free, online query system that provides users with immediate access to the largest set of publicly available, all-payer national, regional, and State-level hospital care databases from HCUP.^5^ Supplemental sources included population denominator data for use with HCUP databases, derived from information available from the Bureau of the Census.^6^

The 2012 NIS was redesigned to optimize national estimates. The redesign incorporates two critical changes:

- Revisions to the sample design—the NIS is now a sample of discharge records from all HCUP-participating hospitals, rather than a sample of hospitals from which all discharges were retained.
- Revisions to how hospitals are defined—the NIS now uses the definition of hospitals and discharges supplied by the statewide data organizations that contribute to HCUP, rather than the definitions used by the American Hospital Association (AHA) Annual Survey of Hospitals.

The new sampling strategy is expected to result in more precise estimates than those that resulted from the previous NIS design by reducing sampling error: for many estimates, confidence intervals under the new design are about half the length of confidence intervals under the previous design. The change in sample design for 2012 necessitates recomputation of prior years' NIS data to enable analysis of trends that uses the same definitions of discharges and hospitals.

Many hypothesis tests were conducted for this Statistical Brief. Thus, to decrease the number of false-positive results, we reduced the significance level to .001 for individual tests.

## Definitions

### Diagnosis-related groups (DRGs) and major diagnostic categories (MDCs)

DRGs comprise a patient classification system that categorizes patients into groups that are clinically coherent and homogeneous with respect to resource use. DRGs group patients according to diagnosis, type of treatment (procedure), age, and other relevant criteria. Each hospital stay has one assigned DRG.

MDCs assign ICD-9-CM principal diagnosis codes to one of 25 general diagnosis categories.

For this report, maternal hospital stays were identified using MDC 14 (pregnancy, childbirth, and the puerperium) and neonatal hospital stays were identified using MDC 15 (newborns and other neonates with conditions originating during the perinatal period). Surgical stays were defined as valid O.R. procedures on the basis of DRG coding principles. Stays other than maternal/neonatal stays or surgical stays were considered medical stays.

### Types of hospitals included in the HCUP National (Nationwide) Inpatient Sample

The National (Nationwide) Inpatient Sample (NIS) is based on data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). The NIS includes obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded are long-term care facilities such as rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. Beginning in 2012, long-term acute care hospitals are also excluded. However, if a patient received long-term care, rehabilitation, or treatment for psychiatric or chemical dependency conditions in a community hospital, the discharge record for that stay will be included in the NIS.

### Unit of analysis

The unit of analysis is the hospital discharge (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the hospital multiple times in 1 year will be counted each time as a separate discharge from the hospital.

### Costs and charges

Total hospital charges were converted to costs using HCUP Cost-to-Charge Ratios based on hospital accounting reports from the Centers for Medicare & Medicaid Services (CMS).^7^ Costs reflect the actual expenses incurred in the production of hospital services, such as wages, supplies, and utility costs; charges represent the amount a hospital billed for the case. For each hospital, a hospital-wide cost-to-charge ratio is used. Hospital charges reflect the amount the hospital billed for the entire hospital stay and do not include professional (physician) fees. For the purposes of this Statistical Brief, costs are reported to the nearest hundred.

Annual costs were inflation adjusted using the Gross Domestic Product (GDP) Price Index from the U.S. Department of Commerce, Bureau of Economic Analysis (BEA), with 2012 as the index base.^8^ That is, all costs are expressed in 2012 dollars.

In general, costs for cases with a high proportion of ancillary charges (e.g., major surgery) tend to be overestimated using these cost-to-charge ratios, whereas costs for cases with a high proportion of room and board charges (e.g., tracheostomy, mental illness, premature newborns) tend to be underestimated.^9^

### How HCUP estimates of costs differ from National Health Expenditure Accounts

There are a number of differences between the costs cited in this Statistical Brief and spending as measured in the National Health Expenditure Accounts (NHEA), which are produced annually by the Centers for Medicare & Medicaid Services (CMS).^10^ The largest source of difference comes from the HCUP coverage of inpatient treatment only in contrast to the NHEA inclusion of outpatient costs associated with emergency departments and other hospital-based outpatient clinics and departments as well. The outpatient portion of hospitals' activities has been growing steadily and may exceed half of all hospital revenue in recent years. On the basis of the American Hospital Association Annual Survey, 2012 outpatient gross revenues (or charges) were about 44 percent of total hospital gross revenues.^11^

Smaller sources of differences come from the inclusion in the NHEA of hospitals that are excluded from HCUP. These include Federal hospitals (Department of Defense, Veterans Administration, Indian Health Services, and Department of Justice [prison] hospitals) as well as psychiatric, substance abuse, and long-term care hospitals. A third source of difference lies in the HCUP reliance on billed charges from hospitals to payers, adjusted to provide estimates of costs using hospital-wide cost-to-charge ratios, in contrast to the NHEA measurement of spending or revenue. HCUP costs estimate the amount of money required to produce hospital services, including expenses for wages, salaries, and benefits paid to staff as well as utilities, maintenance, and other similar expenses required to run a hospital. NHEA spending or revenue measures the amount of income received by the hospital for treatment and other services provided, including payments by insurers, patients, or government programs. The difference between revenues and costs include profit for for-profit hospitals or surpluses for nonprofit hospitals.

### Average annual percentage change

Average annual percentage change is calculated using the following formula:

Average annual percentage change = [ ( (End value)/(Beginning value) )^(1)/(change in years)^ - 1 ] × 100

### Payer

Payer is the expected primary payer for the hospital stay. To make coding uniform across all HCUP data sources, payer combines detailed categories into general groups:

- Medicare: includes patients covered by fee-for-service and managed care Medicare
- Medicaid: includes patients covered by fee-for-service and managed care Medicaid
- Private Insurance: includes Blue Cross, commercial carriers, and private health maintenance organizations (HMOs) and preferred provider organizations (PPOs)
- Uninsured: includes an insurance status of self-pay and no charge
- Other: includes Worker's Compensation, TRICARE/CHAMPUS, CHAMPVA, Title V, and other government programs

Hospital stays billed to the State Children's Health Insurance Program (SCHIP) may be classified as Medicaid, Private Insurance, or Other, depending on the structure of the State program. Because most State data do not identify patients in SCHIP specifically, it is not possible to present this information separately.

When more than one payer is listed for a hospital discharge, the first-listed payer is used.

The Other group was dropped from results displaying differences by payer, with the exception of Figure 1, because of the difficulty interpreting results for such a heterogeneous group.

## For More Information

For more information about HCUP, visit http://www.hcup-us.ahrq.gov/.

For additional HCUP statistics, visit HCUPnet, our interactive query system, at http://hcupnet.ahrq.gov/.

For information on other hospitalizations in the United States, refer to the following HCUP Statistical Briefs located at http://www.hcup-us.ahrq.gov/reports/statbriefs/statbriefs.jsp:

- Statistical Brief #180, Overview of Hospital Stays in the United States, 2012
- Statistical Brief #162, Most Frequent Conditions in U.S. Hospitals, 2011
- Statistical Brief #165, Most Frequent Procedures Performed in U.S. Hospitals, 2011

For a detailed description of HCUP and more information on the design of the National (Nationwide) Inpatient Sample (NIS), please refer to the following database documentation:

Agency for Healthcare Research and Quality. Overview of the National (Nationwide) Inpatient Sample (NIS). Healthcare Cost and Utilization Project (HCUP). .

1 Centers for Medicare & Medicaid Services. National Health Expenditures 2012 Highlights. .

2 Gonzalez JM. (2013). National Health Care Expenses in the U.S. Civilian Noninstitutionalized Population, 2011. Statistical Brief #425. .

3 Estimates of cost in this Statistical Brief differ from the National Health Expenditure Accounts (NHEA) produced annually by the Centers for Medicare & Medicaid Services (CMS). These differences include the following: (1) HCUP covers only hospital inpatient treatment, whereas the NHEA include hospital outpatient treatment as well (emergency departments, outpatient clinics, and other outpatient departments); (2) HCUP excludes Federal, psychiatric, substance abuse, and long-term care hospitals, whereas the NHEA include those hospitals; and (3) HCUP is based on billed charges, which are converted to estimates of the costs of producing hospital services using hospital-wide cost-to-charge ratios, whereas the NHEA reports revenue or income. For more details, see How HCUP estimates of costs differ from National Health Expenditure Accounts in the Definitions section.

4 Average annual growth in inflation-adjusted mean hospital costs per day in Figure 3 was 2.0 percent for both time periods. The average annual change in length of stay for both time periods was -0.2 percent, a slight decline. These two numbers combined reflect the average annual change in inflation-adjusted mean hospital costs shown in Table 1 (1.8 percent).

5 Agency for Healthcare Research and Quality. HCUPnet Web site. .

6 Barrett M, Lopez-Gonzalez L, Coffey R, Levit K. (2014). Population Denominator Data for Use with the HCUP Databases (Updated with 2013 Population Data). HCUP Methods Series Report #2014-02. .

7 Agency for Healthcare Research and Quality. (2001–2011). HCUP Cost-to-Charge Ratio (CCR) Files. Healthcare Cost and Utilization Project (HCUP). .

8 U.S. Bureau of Economic Analysis. National Income and Product Account Tables, Table 1.1.4 Price Indexes for Gross Domestic Product. .

9 Sun Y, Friedman B. (2012). Tools for More Accurate Inpatient Cost Estimates With HCUP Databases, 2009. HCUP Methods Series Report # 2011-04. .

10 For additional information about the NHEA, see Centers for Medicare & Medicaid Services (CMS). (2014). National Health Expenditure Data. CMS Web site. .

11 American Hospital Association. Trend Watch Chartbook, 2014. Table 4.2. Distribution of Inpatient vs. Outpatient Revenues, 1992–2012. .