# Statistical Brief #180 Overview of Hospital Stays in the United States, 2012

## Introduction

Hospital inpatient care constitutes almost one-third of all health care expenditures in the United States.^1^ Overall, hospitalizations affect a large proportion of Americans directly and represent a significant impact to the U.S economy. Although general population growth and a higher prevalence of chronic health conditions suggest that hospital utilization may increase over time, particularly among some groups, greater use of chronic disease management programs and emphasis on outpatient treatment may result in a declining trend in hospital stays.

This Statistical Brief presents data from the Healthcare Cost and Utilization Project (HCUP) on characteristics of inpatient stays in U.S. community hospitals in 2012. The distribution of type of hospital stay (surgical, medical, and maternal or neonatal) is presented for different characteristics (patient age, primary payer, and hospital region). Changes in hospital utilization and costs from 2003 to 2012 are provided, along with changes in hospital utilization by primary payer and patient age. All differences between mean estimates noted in the text are statistically significant at the 0.0005 level or better. Differences between proportions noted in the text differ by at least 10 percent.

## Findings

#### Highlights

■ In 2012, there were 36.5 million hospital stays in the United States, with an average length of stay of 4.5 days and an average cost of $10,400 per stay.
■ The rate of hospitalization decreased by an average of 0.3 percent per year from 2003 to 2008 and by an average of 1.9 percent per year from 2008 to 2012. Between 2003 and 2012, average inflation-adjusted hospital costs increased by 1.8 percent per year.
■ About 56 percent of hospital stays in 2012 were medical, 21.8 percent were surgical, and 22.2 percent were maternal or neonatal.
■ Females had a higher rate of hospitalization in 2012 than did males, but males had a longer average length of stay and higher average cost per stay.
■ In 2012, patients residing in low income communities had a higher rate of hospitalization, a longer length of stay, and lower average hospital costs compared with patients in higher income communities.
■ The rate of hospital stays in 2012 was lower in the Pacific and Mountain divisions than in the other Census divisions. Patients hospitalized in the Northeast had the longest length of stay and patients in the West had the highest average hospital costs.
■ From 2003 to 2012, the share of hospital stays billed to private insurance decreased from 36.6 to 30.6 percent.

### Characteristics of hospital stays, 2012

Table 1 presents utilization and cost data for hospital inpatient stays in 2012 by selected patient and hospital characteristics.

Table 1 Number and rate of hospital stays, length of stay, and costs by patient, payer, community income, and hospital characteristics, 2012

Characteristic | Hospital stays | | | Mean length of stay, days | Costs
Characteristic | Number, thousands | Percent | Rate per 1,000 population | Mean length of stay, days | Mean cost per stay, $ | Aggregate, millions $
All hospital stays | 36,500 | 100 | 116.2 | 4.5 | 10,400 | 377,455
Patient age, years
< 1 | 4,300 | 11.7 | 1,070.9 | 3.8 | 5,000 | 21,101
1–17 | 1,500 | 4.0 | 21.1 | 3.9 | 9,900 | 14,635
18–44 | 9,000 | 24.7 | 78.9 | 3.6 | 7,600 | 68,425
45–64 | 9,000 | 24.7 | 108.8 | 4.9 | 12,900 | 116,075
65–84 | 9,700 | 26.7 | 260.9 | 5.2 | 13,000 | 126,573
85 + | 3,000 | 8.2 | 502.0 | 5.2 | 10,200 | 30,512
Patient sex
Male | 15,400 | 42.3 | 99.9 | 4.8 | 11,700 | 180,587
Female | 21,000 | 57.7 | 132.0 | 4.3 | 9,400 | 196,833
Primary payer^a^
Medicare | 14,300 | 39.1 | n/a | 5.2 | 12,200 | 174,609
Medicaid | 7,600 | 20.9 | n/a | 4.3 | 8,100 | 61,679
Private insurance | 11,200 | 30.6 | n/a | 3.8 | 9,700 | 107,807
Uninsured | 2,000 | 5.6 | n/a | 4.0 | 8,800 | 18,056
Community income^b^
Low | 10,900 | 30.0 | 136.8 | 4.6 | 9,700 | 105,981
Not low | 24,700 | 67.8 | 106.1 | 4.4 | 10,600 | 262,789
Hospital region
Northeast | 7,000 | 19.1 | 125.2 | 4.9 | 10,800 | 75,146
Midwest | 8,200 | 22.6 | 122.4 | 4.3 | 10,200 | 84,140
South | 14,100 | 38.7 | 120.4 | 4.5 | 9,300 | 131,635
West | 7,200 | 19.6 | 97.2 | 4.2 | 12,300 | 86,533

a Population rates are not available by primary payer.

b Patients in the first quartile are designated as low income, and patients in the upper three quartiles are designated as not low income.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS), 2012

■ In 2012, there were about 36.5 million hospital stays with an average length of stay of 4.5 days and an average cost of $10,400 per stay.
  In 2012, there were approximately 36.5 million hospital stays in the United States, representing a hospitalization rate of 116.2 stays per 1,000 population. Across all types of stays, the average length of a hospital stay was 4.5 days. Aggregate hospital costs were $377.5 billion, and the average cost per stay was $10,400.
■ Hospital utilization and costs varied substantially in relationship to patient and hospital characteristics.
  The rate of hospitalization was highest among infants, which included hospital births (newborns), at 1,070.9 stays per 1,000 population. With the exception of infants, the hospitalization rate increased with age from 21.1 stays per 1,000 population among 1–17 year olds to 502.0 stays per 1,000 population among those aged 85 years and older.
  Adults aged 18–44 years had the shortest average length of stay (3.6 days), followed by infants and children up to 17 years of age (3.8 to 3.9 days). Among adults, lengths of stay were longer as patient age increased, with adults aged 65 years and older having the longest average length of stay (5.2 days). Average cost per stay was lowest for infants ($5,000) and highest for adults aged 45–84 years ($12,900 to $13,000).
  Females had a higher rate of hospitalization (132.0 stays per 1,000 population) than males (99.9 stays per 1,000 population). The average length of a hospital stay was shorter for females than for males (4.3 vs. 4.8 days), and the average cost of a hospital stay was lower for females than for males ($9,400 vs. $11,700). It is important to note that maternal stays for females admitted for pregnancy and delivery were included in this analysis. Analyses excluding maternal and neonatal (newborn) stays showed the same relative differences between males and females (data not shown). Excluding maternal and neonatal conditions and compared with males, females had a higher rate of hospitalization (93.9 vs. 86.9 stays per 1,000 population), a shorter average length of stay (4.8 vs. 5.0 days), and lower average cost per stay ($11,400 vs. $12,800).
  Medicare paid for the largest number of hospitalizations (14.3 million stays), followed by private insurance (11.2 million stays) and Medicaid (7.6 million stays). About 2 million hospital stays were for patients without insurance. Patients covered by Medicare experienced the longest average length of stay (5.2 days), and privately insured patients had the shortest average length of stay (3.8 days). Average cost per stay was highest for Medicare hospitalizations ($12,200) and lowest for Medicaid hospital stays ($8,100).
  Communities with low income levels had a higher rate of hospitalization than did communities with higher income levels (136.8 vs. 106.1 stays per 1,000 population). Compared with patients from higher income communities, patients from low income communities had a longer average length of stay (4.6 vs. 4.4 days) and lower average hospital costs ($9,700 vs. $10,600).
  The West had a lower rate of hospitalization (97.2 stays per 1,000 population) compared with the other regions (range: 120.4 to 125.2 stays per 1,000 population). The Northeast had the longest average length of stay at 4.9 days, and the West and Midwest had the shortest average lengths of stay (4.2 and 4.3 days, respectively). The West had the highest average hospital cost ($12,300) and the South had the lowest average hospital cost ($9,300).

Figure 1 provides the distribution of hospital stays by patient age, primary payer, and hospital region, comparing each subgroup by type of stay—surgical, medical, and maternal or neonatal.

Figure 1 Distribution of inpatient stays by patient age group, primary payer, hospital region, and type of stay, 2012

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS), 2012

Distribution of inpatient stays by patient age group, primary payer, hospital region, and type of stay, 2012. Figure 1 is a bar chart that shows how hospital stays are distributed among surgical, medical, and material or neonatal stays. This distribution is split out by age group, by insurance payer, and by hospital region. Of all stays, 21.8% were surgical, 56.0% were medical, and 22.2% were maternal or neonatal. For patients that were younger than 1 year, 1.3% were surgical stays, 6.8% were medical stays, and 91.9% were maternal or neonatal stays. For patients that were between 1 and 17 years old, 19.7% were surgical stays, 73.6% were medical stays, and 6.7% were maternal or neonatal stays. For patients that were between 18 and 44 years old, 15.0% were surgical stays, 39.9% were medical stays, and 45.1% were maternal or neonatal stays. For patients who were between 45 and 64 years old, 32.6% were surgical stays, 67.3% were medical stays, and 0.1% were maternal or neonatal stays. For those who were between 65 and 84 years old, 29.5% were surgical stays, 70.5% were medical stays, and 0.0% were maternal or neonatal stays. For patients who were older than 85 years, 15.2% were surgical stays, 84.8% were medical stays, and 0.0% were maternal or neonatal stays. For stays that were paid for by Medicare, 24.9% were surgical stays, 74.8% were medical stays, and 0.3% were maternal or neonatal stays. For those that were paid for by Medicaid, 0.2% were surgical stays, 41.3% were medical stays, and 48.5% were maternal or neonatal stays. For stays that were covered by primary insurance, 25.7% were surgical stays, 40.1% were medical stays, and 34.1% were maternal or neonatal stays. For stays of patients who were uninsured, 19.4% were surgical stays, 67.6% were medical stays, and 13.0% were maternal or neonatal stays. For hospitals in the Northeast, 21.4% were surgical stays, 59.6% were medical stays, and 19.0% were maternal or neonatal stays. For hospitals that were in the Midwest, 22.1% were surgical stays, 57.1% were medical stays, and 20.8% were maternal or neonatal stays. For hospitals that were in the South, 21.4% were surgical stays, 56.7% were medical stays, and 21.9% were maternal or neonatal stays, For hospitals that were in the West, 22.6% were surgical stays, 50.0% were medical stays, and 27.4% were maternal or neonatal stays. Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS), 2012.

■ Medical stays constituted the largest proportion of hospitalizations.
  Overall, medical stays constituted the largest proportion of hospital stays, representing 56.0 percent of all hospitalizations. Maternal/neonatal stays and surgical stays each constituted approximately 22 percent of hospitalizations. More than two-thirds of hospitalizations were medical stays for the second youngest and three oldest age groups: 1–17 years (73.6 percent), 45–64 years (67.3 percent), 65–84 years (70.5 percent), and 85+ years (84.8 percent). Medical stays also constituted a high proportion of stays among patients covered by Medicare (74.8 percent) and among the uninsured (67.6 percent).
■ Maternal or neonatal stays constituted the largest proportion of hospitalizations among infants, younger adults, and patients covered by Medicaid.
  Neonatal stays constituted 91.9 percent of hospital stays among infants aged < 1 year. Nearly half of stays among patients aged 18–44 years (45.1 percent) and those covered by Medicaid (48.5 percent) were for maternal conditions.
■ In the West, the proportion of maternal or neonatal stays was higher and the proportion of medical stays lower relative to the distribution within other U.S. regions.
  In the West maternal or neonatal stays accounted for more than one-quarter of all hospitalizations (27.4 percent) versus around 20 percent for the other regions (range: 19.0–21.9 percent). In addition, the West had a lower proportion of medical stays (50.0 percent) compared with the other regions (range: 56.7–59.6 percent).

Figure 2 presents the distribution of hospital stays by primary payer for 2012 and for 2 prior years (2003 and 2008), covering a 10-year time period.

Figure 2 Distribution of inpatient stays by primary payer, 2003, 2008, and 2012

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National (Nationwide) Inpatient Sample (NIS), 2003, 2008, 2012

Distribution of inpatient stays by primary payer, 2003, 2008, and 2012. Figure 2 is a bar chart that shows the distribution of hospital stays by insurance payer, for 2003, 2008, and 2012. In 2003, 37.1% of hospital stays were covered by Medicare, 18.4% of stays were covered by Medicaid, 36.6% of stays were covered by private insurance, 4.6% of stays were for uninsured individuals, and insurance records for the remaining 3.3% were marked as Other or Missing. In 2008, 37.3% of hospital stays were covered by Medicare, 18.5% of stays were covered by Medicaid, 35.4% of stays were covered by private insurance, 5.3% of stays were for uninsured individuals, and insurance records for the remaining 3.5% were marked as Other or Missing. In 2012, 39.1% of hospital stays were covered by Medicare, 20.9% of stays were covered by Medicaid, 30.6% of stays were covered by private insurance, 5.6% of stays were for uninsured individuals, and insurance records for the remaining 3.8% wre marked as Other or Missing. Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National (Nationwide) Inpatient Sample (NIS), 2003, 2008, 2012.

■ The share of hospital costs billed to private insurance decreased between 2003 and 2012.
  Between 2003 and 2012, the number of hospital stays billed to private insurance decreased from 13.6 to 11.2 million stays, representing a decrease from 36.6 to 30.6 percent of all hospitalizations. During this same time period, the share of stays billed to Medicaid increased from 6.8 to 7.6 million stays (an increase from 18.4 percent to 20.9 percent of all hospitalizations).

Figure 3 presents the rate of hospital inpatient stays across the nine U.S. Census divisions in 2012.

Figure 3 Rate of inpatient stays per 1,000 population by U.S. Census division, 2012

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS), 2012

Rate of inpatient stays per 1,000 population by U.S. Census division, 2012. Figure 3 is a map of the United States split into nine color-coded Census divisions. Idaho, Mississippi, and Alabama are not in the National Inpatient Sample and were excluded from the analysis. The rate of inpatient stays (which is the number of hospital stays for each 1,000 people residing in that region) is shown for each Census region. For the East North Central Census division, there were 123.1 hospital stays per 1,000 population. For the East South Central Census division, there were 135.4 hospital stays per 1,000 population. For the Pacific Census division, there were 96.6 hospital stays per 1,000 population. For the New England Census division, there were 117.6 hospital stays per 1,000 population. For the West North Central Census division, there were 120.7 hospital stays per 1,000. For the West South Central Census division, there were 114.2 hospital stays per 1,000. For the Middle Atlantic Census division, there were 127.9 hospital stays per 1,000. For the South Atlantic Census division, there were 119.5 hospital stays per 1,000. For the Mountain Census division, there were 98.6 hospital stays per 1,000. Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National Inpatient Sample (NIS), 2012.

■ The Pacific and Mountain divisions had the lowest rates of inpatient stays.
  The lowest hospitalization rates were in the Pacific and Mountain divisions (96.6 and 98.6 stays per 1,000 population, respectively). The West South Central division had a lower hospitalization rate (114.2 stays per 1,000 population) than did the East South Central and Middle Atlantic divisions (135.4 and 127.9 stays per 1,000 population, respectively).

### Changes in utilization and costs of hospital stays, 2003–2012

Figure 4 presents overall changes in utilization and costs associated with hospital inpatient stays.

Figure 4 Average annual percentage change in hospital inpatient utilization and inflation-adjusted costs, 2003–2008 and 2008–2012

* Growth in mean and aggregate hospital costs was calculated using inflation-adjusted costs.

Note: Data from 2008 were used as end points in both the 2003–2008 and the 2008–2012 analyses.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National (Nationwide) Inpatient Sample (NIS), 2003, 2008, 2012

Average annual percent changes in hospital inpatient utilization and inflation-adjusted costs, 2003–2008 and 2008–2012. Figure 4 is a bar chart that shows the percentage change in number of hospital stays, rate of hospital stays (that is, number of stays per 1,000 population), average length of stay, average cost per stay, and aggregate cost, for both the 2003 to 2008 and the 2008 to 2012 time periods. For 2003 to 2008, the change in number of hospital stays was 0.6%, the change in rate of hospital stays was −0.3%, the change in average length of hospital stay was −0.2%, the change in average cost per stay was 1.8%, and the change in aggregate costs of hospital stays was 2.4%. For 2008 to 2012, the change in number of hospital stays was −1.1%, the change in rate of hospital stays was 1.9%, the change in average length of hospital stay was −0.2%, the change in average cost per stay was 1.8%, and the change in aggregate costs of hospital stays was 0.7%. Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National (Nationwide) Inpatient Sample (NIS), 2003, 2008, 2012.

■ Hospital costs increased while the rate of hospitalization and mean length of stay decreased over the decade from 2003 to 2012.
  The number of hospital stays [underlined: increased] 0.6 percent annually from 2003 to 2008, whereas the number of stays [underlined: decreased] an average of 1.1 percent annually between 2008 and 2012.
  The overall rate of hospitalization decreased over time, with an average annual decrease of 0.3 percent between 2003 and 2008 and an average annual decrease of 1.9 percent between 2008 and 2012.
  The length of a hospital stay decreased on average 0.2 percent per year between 2003 and 2012.
  Finally, mean inflation-adjusted hospital costs grew at a relatively steady rate, averaging 1.8 percent per year during both time periods. Aggregate inflation-adjusted hospital costs grew an average of 2.4 percent per year between 2003 and 2008 but slowed to a 0.7 percent average increase per year between 2008 and 2012.

Figure 5 presents the rate of stays by patient age for 2003, 2008, and 2012, along with the average annual percentage change for two consecutive 5-year time periods (2003–2008 and 2008–2012).

Figure 5 Rate of inpatient stays and change over time by patient age, 2003–2012

Note: Data from 2008 were used as end points in both the 2003–2008 and the 2008–2012 analyses.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National (Nationwide) Inpatient Sample (NIS), 2003, 2008, 2012

Rate of inpatient stays per 1,000 population by patient age for 2003, 2008, and 2012. Figure 5 is a bar chart that shows the average annual percentage change in the rate of hospital stays by age group for the 2003 to 2008 and the 2008 to 2012 time periods. It also shows the number of hospital stays per 1,000 population by age group in 2003, 2008, and 2012. The average annual percentage change for all stays was −0.3% for 2003 to 2008 and −1.9% for 2008 to 2012. Broken down by age group, average annual percentage change for patients younger than 1 year was −0.7% for 2003 to 2008 and −0.9% for 2008 to 2012, for patients between 1 and 17 years old it was −3.3% for 2003 to 2008 and −0.6% for 2008 to 2012, for patients between 18 and 44 years old it was −0.4% for 2003 to 2008 and −2.0% for 2008 to 2012, for patients between 45 and 64 years old it was −0.3% for 2003 to 2008 and −1.5% for 2008 to 2012, for patients between 65 and 84 years old it was −1.1% for 2003 to 2008 and −3.9% for 2008 to 2012, and for patients older than 85 years it was −0.3% for 2003 to 2008 and −3.8% for 2008 to 2012. The rate of inpatient stays for 2003, 2008, and 2012 broken down by age group as follows: for all stays, 128 for 2003, 126 for 2008, and 116 for 2012; for patients younger than 1 year, 1,152 for 2003, 1,111 for 2008, and 1,071 for 2012; for patients between 1 and 17 years old, 25 for 2003, 22, for 2008, and 21 for 2009; for patients between 18 and 44 years old, 87 for 2003, 85 for 2008, and 79 for 2012; for patients between 45 and 64 years old, 117 for 2003, 116 for 2008, and 109 for 2012; for patients between 65 and 84 years old, 323 for 2003, 306 for 2008, and 261 for 2012; and for patients older than 85 years, 597 for 2003, 587 for 2008, and 502 for 2012. Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), National (Nationwide) Inpatient Sample (NIS), 2003, 2008, 2012.

■ The rate of hospitalization decreased between 2003 and 2012 overall and across patient subgroups.
  Between 2003 and 2012 the rate of hospitalization decreased from 128 stays per 1,000 population in 2003 to 116 stays per population in 2012. This decrease in the hospitalization rate occurred for all age groups. The rate of decrease was generally greater from 2008 to 2012 than from 2003 to 2008, with the exception of patients aged 1–17 years, who experienced a faster decline in hospitalization rate from 2003 to 2008.
  From 2008 through 2012, the rate of hospitalization decreased at the highest rate—almost 4 percent per year—for those aged 65 years and older.

## Data Source

The estimates in this Statistical Brief are based upon data from the Healthcare Cost and Utilization Project (HCUP) 2012 National Inpatient Sample (NIS). Historical data were drawn from the 2003 and 2008 Nationwide Inpatient Sample (NIS). The statistics were generated from HCUPnet, a free, online query system that provides users with immediate access to the largest set of publicly available, all-payer national, regional, and State-level hospital care databases from HCUP.^2^

The 2012 NIS was redesigned to optimize national estimates. The redesign incorporates two critical changes:

- Revisions to the sample design—the NIS is now a sample of discharge records from all HCUP-participating hospitals, rather than a sample of hospitals from which all discharges were retained.
- Revisions to how hospitals are defined—the NIS now uses the definition of hospitals and discharges supplied by the statewide data organizations that contribute to HCUP, rather than the definitions used by the American Hospital Association (AHA) Annual Survey of Hospitals.

The new sampling strategy is expected to result in more precise estimates than did the previous NIS design by reducing sampling error: for many estimates, confidence intervals under the new design are about half the length of confidence intervals under the previous design. The change in sample design for 2012 necessitates recomputation of prior years' NIS data to enable analysis of trends that uses the same definitions of discharges and hospitals.

This is the first Statistical Brief that reports data from the 2012 NIS.

Many hypothesis tests were conducted for this Statistical Brief. Thus, to decrease the number of false-positive results, we reduced the significance level to 0.0005 for individual tests.

## Definitions

### Diagnoses, ICD-9-CM, major diagnostic categories (MDCs), and diagnosis-related groups (DRGs)

The principal diagnosis is that condition established after study to be chiefly responsible for the patient's admission to the hospital. Secondary diagnoses are concomitant conditions that coexist at the time of admission or develop during the stay.

ICD-9-CM is the International Classification of Diseases, Ninth Revision, Clinical Modification, which assigns numeric codes to diagnoses and procedures. There are approximately 14,000 ICD-9-CM diagnosis codes and approximately 4,000 ICD-9-CM procedure codes.

MDCs assign ICD-9-CM principal diagnosis codes to one of 25 general diagnosis categories. For this report, maternal hospital stays were identified using MDC 14 (pregnancy, childbirth, and the puerperium) and neonatal hospital stays were identified using MDC 15 (newborns and other neonates with conditions originating during the perinatal period).

DRGs comprise a patient classification system that categorizes patients into groups that are clinically coherent and homogeneous with respect to resource use. DRGs group patients according to diagnosis, type of treatment (procedure), age, and other relevant criteria. Each hospital stay has one assigned DRG. For this report, surgical stays were defined as valid O.R. procedures on the basis of DRG coding principles. Stays other than maternal/neonatal stays or surgical stays were considered medical stays.

### Types of hospitals included in the HCUP National (Nationwide) Inpatient Sample

The National (Nationwide) Inpatient Sample (NIS) is based on data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). The NIS includes obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded are long-term care facilities such as rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. Beginning in 2012, long-term acute care hospitals are also excluded. However, if a patient received long-term care, rehabilitation, or treatment for psychiatric or chemical dependency conditions in a community hospital, the discharge record for that stay will be included in the NIS.

### Unit of analysis

The unit of analysis is the hospital discharge (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the hospital multiple times in 1 year will be counted each time as a separate discharge from the hospital.

### Costs and charges

Total hospital charges were converted to costs using HCUP Cost-to-Charge Ratios based on hospital accounting reports from the Centers for Medicare & Medicaid Services (CMS).^3^ Costs reflect the actual expenses incurred in the production of hospital services, such as wages, supplies, and utility costs; charges represent the amount a hospital billed for the case. For each hospital, a hospital-wide cost-to-charge ratio is used. Hospital charges reflect the amount the hospital billed for the entire hospital stay and do not include professional (physician) fees. For the purposes of this Statistical Brief, costs are reported to the nearest hundred.

Annual costs were inflation adjusted using the Gross Domestic Product (GDP) from the U.S. Department of Commerce, Bureau of Economic Analysis (BEA), with 2012 as the index base.^4^ That is, all costs are expressed in 2012 dollars.

### Average annual percentage change

Average annual percentage change is calculated using the following formula:

Average annual percentage change = [ ( (End value)/(Beginning value) )^(1)/(change in year)^ − 1 ] × 100 .

### Median community-level income

Median community-level income is the median household income of the patient's ZIP Code of residence. Income levels are separated into quartiles with cut-offs determined using ZIP Code demographic data obtained from the Nielsen Company. Patients in the first quartile are designated as having low income, and patients in the upper three quartiles are designated as having not low income. The income quartile is missing for patients who are homeless or foreign.

### Payer

Payer is the expected primary payer for the hospital stay. To make coding uniform across all HCUP data sources, payer combines detailed categories into general groups:

- Medicare: includes patients covered by fee-for-service and managed care Medicare
- Medicaid: includes patients covered by fee-for-service and managed care Medicaid
- Private Insurance: includes Blue Cross, commercial carriers, and private health maintenance organizations (HMOs) and preferred provider organizations (PPOs)
- Uninsured: includes an insurance status of self-pay and no charge
- Other: includes Worker's Compensation, TRICARE/CHAMPUS, CHAMPVA, Title V, and other government programs

Hospital stays billed to the State Children's Health Insurance Program (SCHIP) may be classified as Medicaid, Private Insurance, or Other, depending on the structure of the State program. Because most State data do not identify patients in SCHIP specifically, it is not possible to present this information separately.

When more than one payer is listed for a hospital discharge, the first-listed payer is used.

### Region

Region is one of the four regions defined by the U.S. Census Bureau:

- Northeast: Maine, New Hampshire, Vermont, Massachusetts, Rhode Island, Connecticut, New York, New Jersey, and Pennsylvania
- Midwest: Ohio, Indiana, Illinois, Michigan, Wisconsin, Minnesota, Iowa, Missouri, North Dakota, South Dakota, Nebraska, and Kansas
- South: Delaware, Maryland, District of Columbia, Virginia, West Virginia, North Carolina, South Carolina, Georgia, Florida, Kentucky, Tennessee, Alabama, Mississippi, Arkansas, Louisiana, Oklahoma, and Texas
- West: Montana, Idaho, Wyoming, Colorado, New Mexico, Arizona, Utah, Nevada, Washington, Oregon, California, Alaska, and Hawaii

## For More Information

For more information about HCUP, visit http://www.hcup-us.ahrq.gov/.

For additional HCUP statistics, visit HCUPnet, our interactive query system, at http://hcupnet.ahrq.gov/.

For information on other hospitalizations in the United States, refer to the following HCUP Statistical Briefs located at http://www.hcup-us.ahrq.gov/reports/statbriefs/statbriefs.jsp:

- Statistical Brief #168, Costs for Hospital Stays in the United States, 2011
- Statistical Brief #162, Most Frequent Conditions in U.S. Hospitals, 2011
- Statistical Brief #165, Most Frequent Procedures Performed in U.S. Hospitals, 2011

For a detailed description of HCUP and more information on the design of the National (Nationwide) Inpatient Sample (NIS), please refer to the following database documentation:

Agency for Healthcare Research and Quality. Overview of the National (Nationwide) Inpatient Sample (NIS). Healthcare Cost and Utilization Project (HCUP). .

1 Gonzalez JM. (2013). National Health Care Expenses in the U.S. Civilian Noninstitutionalized Population, 2011. MEPS Statistical Brief No. 425. .

2 Agency for Healthcare Research and Quality. HCUPnet Web site. .

3 Agency for Healthcare Research and Quality. (2001–2011). HCUP Cost-to-Charge Ratio (CCR) Files. Healthcare Cost and Utilization Project (HCUP). .

4 U.S. Bureau of Economic Analysis. National Income and Product Account Tables, Table 1.1.4 Price Indexes for Gross Domestic Product. .