# Statistical Brief #173 Complicating Conditions Associated With Childbirth, by Delivery Method and Payer, 2011

## Introduction

Childbirth is the most prevalent reason for hospitalization in the United States.^1,2^ Of the 4.1 million hospital stays in 2009 involving childbirth, 91.3 percent of vaginal and 99.9 percent of cesarean section deliveries had at least one complicating condition.^3^ These conditions range in severity and may include those that are preexisting, such as mental health disorders; those that create risk factors, such as multiple gestation; and those that may lead to complications of care, such as an abnormality of fetal heart rate or rhythm.

In the United States, childbirth accounts for about 10 percent of all maternal hospital stays and $12.4 billion in hospitalization costs for live births; it represents, in the aggregate, one of the most costly conditions for inpatient hospital care.^4,5^ The average cost of a vaginal birth in 2008 was $2,900 without complications and $3,800 with complications.^2^ The average cost of a cesarean section was $4,700 without complications and $6,500 with complications.

A recent report from the Centers for Disease Control and Prevention analyzed and compared 2010 payment source data from U.S. birth certificates and the National Hospital Discharge Survey. Results showed that the most common payment source for deliveries was private insurance. However, in the past decade, privately insured deliveries have declined by 16 percent, while Medicaid-covered deliveries have increased by 40 percent.^6^ Type of insurance may influence the prevalence of interventions (e.g., induction of labor, cesarean section) associated with a complicating condition and mode of delivery.^6,7^

This Statistical Brief presents data from the Healthcare Cost and Utilization Project (HCUP) Nationwide Inpatient Sample (NIS) on the source of payment for pregnancy and childbirth hospitalizations with complicating conditions versus without complicating conditions by mode of delivery in 2011. We examine stays for vaginal and cesarean section deliveries and compare rates of complicating conditions by expected payer type (Medicaid versus private insurance). All data are reported from the maternal perspective (i.e., reflecting the experience of the mother, not the newborn) among women who had a hospital delivery in 2011.

Patient characteristics, hospital utilization, and source of payment for hospital stays are presented for hospital stays involving complicated and uncomplicated vaginal and cesarean section deliveries. Differences between women who were primiparous (giving birth for the first time) and multiparous (giving birth for the second or more times) were not analyzed because the data do not provide this level of detail. During an individual stay, multiple complicating conditions may be identified through the principal diagnosis or through secondary diagnoses that may influence the course of care. Because of limitations in the data, this Statistical Brief does not explicitly distinguish between preexisting conditions and complications of care. Furthermore, we acknowledge that there are known limitations in the accuracy of capturing perinatal conditions and complications through hospital coding.^8,9^

All differences between estimates noted in the text and tables are statistically significant at the 0.05 level or better. Clinical significance was also considered for reporting and presentation.

## Findings

Highlights

■ Among the 3.6 million hospital stays involving childbirth in 2011, cesarean section deliveries were 11 percent more likely among women who were covered by private insurance than among women covered by Medicaid. Mean length of stay and mean hospital costs were similar by payer type.
■ Among women who delivered by cesarean section and were covered by Medicaid, 94.6 percent of discharges included a complicating condition.
■ Overall, for discharges among women with vaginal deliveries covered by private insurance, the rate of cases with complications increased with age (75.5 per 100 for adolescents younger than 15 years versus 83.3 per 100 for women aged 40–44 years).
■ For vaginal deliveries, second-degree perineal laceration rates were higher among women with private insurance than Medicaid.
■ Compared with women covered by Medicaid, women with private insurance were more likely to have a cesarean section delivery when complicating conditions that may impede vaginal delivery were present.

### Characteristics of childbirth hospital stays, 2011

Table 1 reports select characteristics of vaginal and cesarean section deliveries for Medicaid versus private insurance in 2011.

Table 1 Selected characteristics of childbirth hospital stays by payer and delivery method, 2011^*^

Characteristic | Medicaid | | Private insurance
Characteristic | Vaginal | Cesarean section | Vaginal | Cesarean section
Total number of discharges | 1,129,100 | 520,400 | 1,256,800 | 677,500
Childbirth stays, % | 29.6 | 13.6 | 33.0 | 17.8
Delivery type by payer, % | 68.5 | 31.5 | 65.0 | 35.0
Mean length of stay, days | 2.2 | 3.4 | 2.2 | 3.6
Mean hospital costs, $ | 3,400 | 5,900 | 3,400 | 5,900
Aggregate costs, billion $ | 3.8 | 3.1 | 4.3 | 4.0
Mean patient age, years | 25 | 27 | 29 | 31
Multiple gestation, n | 4,900 | 15,000 | 8,100 | 28,800
Multiple gestation stays, % | 8.1 | 25.0 | 13.6 | 48.0
Multiple gestation delivery type by payer, % | 24.6 | 75.4 | 22.0 | 78.0

* Approximately 6 percent of childbirth stays were among women who were uninsured or covered by Medicare. Percentages do not total 100 because these data were not included.

Source: Agency for Healthcare Research and Quality (AHRQ). (2011). Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS).

■ Cesarean section deliveries were more common among women with private insurance than among those covered by Medicaid.
  There were 3.6 million hospital stays involving childbirth among all ages of females who were covered by Medicaid or private insurance in 2011. More childbirth stays occurred among women with private insurance than among those covered by Medicaid (1.9 million versus 1.6 million stays). Cesarean section deliveries were 11 percent more likely among women with private insurance compared with women covered by Medicaid (35.0 percent versus 31.5 percent).
■ Mean length of stay and mean hospital costs were similar by payer type.
  For both payer types, maternal stays for cesarean section deliveries were more than 1 day longer than stays for vaginal births. Mean costs were also higher for women with cesarean section deliveries, regardless of payer type. In aggregate, maternal stays for childbirth cost $15.1 billion among women who were covered by Medicaid and private insurance: $6.9 billion for Medicaid-covered stays and $8.3 billion for privately insured stays.
■ Pregnant women with private insurance were older and more likely to have multiple gestation than women covered by Medicaid.
  On average, women with private insurance were 4 years older than those covered by Medicaid for both delivery types (29 years versus 25 years for vaginal births; 31 years versus 27 years for cesarean section deliveries). For both payer types, women with a cesarean section delivery were, on average, 2 years older than women with a vaginal birth. Women with private insurance were more likely to have multiple gestation than those covered by Medicaid (13.6 percent of women with private insurance versus 8.1 percent of women covered by Medicaid for vaginal births; 48.0 percent of women with private insurance versus 25.0 percent of women covered by Medicaid for cesarean section deliveries).

### Complicating conditions by payer and delivery method, 2011

Figure 1 presents the distribution of discharges with complicating conditions by payer type and delivery method.

Figure 1 Percentage of stays with presence of complicating conditions, by payer and delivery method, 2011

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2011

Figure 1 is a bar chart showing the percentage of hospital stays involving childbirth with complicating conditions by delivery method for women covered by Medicaid versus private insurance. Vaginal delivery; Medicaid: 72.1; Private Insurance: 79.7; Cesarean section delivery; Medicaid: 94.6; Private Insurance: 93.6; Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2011

■ Complicating conditions were more commonly associated with cesarean section deliveries than vaginal births.
  Among patients covered by Medicaid, women with a cesarean section delivery were 31 percent more likely to have a complicating condition than those with a vaginal delivery (94.6 percent versus 72.1 percent). Among patients with private insurance, women with a cesarean section delivery were 17 percent more likely to have a complicating condition than those with a vaginal delivery (93.6 percent versus 79.9 percent).
■ Complicating conditions differed by delivery type and payer.
  For vaginal deliveries, women with private insurance were more likely to have complicating conditions (79.7 percent) than those covered by Medicaid (72.1 percent). There were no meaningful differences in overall complication rates by payer for cesarean section deliveries.

### Rates of complicating conditions by maternal age and payer, 2011

Table 2 shows the number and rate of complications among hospital childbirth stays by maternal age, payer, and delivery method.

Table 2 Number and rate (per 100 discharges) of hospital childbirth stays with complicating conditions by maternal age, payer, and delivery method, 2011

Maternal age, years | Discharges with complications
Maternal age, years | Medicaid | | | | Private insurance
Maternal age, years | Vaginal | | Cesarean section | | Vaginal | | Cesarean section
Maternal age, years | n | Rate | n | Rate | n | Rate | n | Rate
All ages | 814,600 | 72.1 | 492,200 | 94.6 | 1,001,600 | 79.7 | 634,200 | 93.6
<15 | 1,700 | 72.6 | 600 | 88.0 | 500 | 75.5 | 100 | 94.1
15–17 | 41,100 | 75.6 | 12,500 | 90.5 | 13,100 | 76.8 | 3,800 | 89.5
18–24 | 381,300 | 72.0 | 190,900 | 93.3 | 171,200 | 76.7 | 74,700 | 91.6
25–29 | 210,600 | 70.6 | 139,600 | 95.5 | 309,200 | 78.7 | 170,100 | 93.2
30–34 | 119,700 | 73.0 | 91,500 | 96.1 | 331,000 | 81.0 | 222,700 | 94.3
35–39 | 48,300 | 74.5 | 45,000 | 95.7 | 146,200 | 82.2 | 126,700 | 94.4
40–44 | 11,200 | 75.9 | 11,300 | 94.4 | 28,700 | 83.3 | 33,200 | 93.4
>44 | 500 | 72.3 | 700 | 97.3 | 1,400 | 81.8 | 2,800 | 91.7

Note: Principal and secondary diagnoses were examined.

Source: Agency for Healthcare Research and Quality (AHRQ). (2011). Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS).

■ Complicating conditions for vaginal births were more common among privately insured than Medicaid-covered deliveries, regardless of maternal age.
  Women in every age category who had vaginal births covered by private insurance experienced higher rates of complicating conditions than women covered by Medicaid. For example, among women aged 25–29 years with private insurance, 78.7 per 100 discharges had complications versus 70.6 per 100 discharges among those covered by Medicaid.
  For women with private insurance who had vaginal deliveries, the rate of complicating conditions generally increased with age (e.g., 75.5 complications per 100 for adolescents younger than 15 years to 83.3 per 100 for women aged 40–44 years).

### Common complicating conditions by delivery method and payer, 2011

Table 3 provides the rate per 1,000 deliveries for the 10 most common complicating conditions associated with childbirth stays by payer and delivery method. Conditions are sorted by frequency for patients covered by Medicaid. (Detailed tables on complicating conditions by payer and delivery type are provided in the Appendix.)

Table 3 Rates of the 10 most common complicating conditions by delivery method and payer, 2011

Medicaid | | | Private insurance
Rank | Complicating condition | Rate per 1,000 discharges | Rank | Complicating condition | Rate per 1,000 discharges
Vaginal deliveries
1 | First-degree perineal laceration | 232 | 2 | First-degree perineal laceration | 241
2 | Second-degree perineal laceration | 178 | 1 | Second-degree perineal laceration | 314
3 | Anemia | 127 | 5 | Anemia | 73
4 | Post-term pregnancy | 127 | 3 | Post-term pregnancy | 130
5 | Abnormality in fetal heart rate or rhythm | 122 | 4 | Abnormality in fetal heart rate or rhythm | 120
6 | Preeclampsia | 58 | 6 | Preeclampsia | 57
7 | Mental disorders | 51 | 10 | Mental disorders | 31
8 | Premature rupture of membranes | 39 | 7 | Premature rupture of membranes | 43
9 | Precipitate labor | 33
10 | Other immediate postpartum hemorrhage | 27
| | | 8 | Thyroid dysfunction | 34
| | | 9 | Third-degree perineal laceration | 32
Cesarean section deliveries
1 | Previous cesarean section | 488 | 1 | Previous cesarean section | 434
2 | Abnormality in fetal heart rate or rhythm | 202 | 2 | Abnormality in fetal heart rate or rhythm | 180
3 | Anemia | 186 | 3 | Anemia | 128
4 | Preeclampsia | 100 | 4 | Preeclampsia | 105
5 | Post-term pregnancy | 93 | 7 | Post-term pregnancy | 91
6 | Other malposition and malpresentation | 89 | 5 | Other malposition and malpresentation | 104
7 | Breech | 76 | 6 | Breech | 94
8 | Mental disorders | 59
9 | Fetopelvic disproportion | 45 | 9 | Fetopelvic disproportion | 48
10 | Excessive fetal growth | 41 | 8 | Excessive fetal growth | 58
| | | 10 | Thyroid dysfunction | 48

Note: Principal and secondary diagnoses were examined.

Source: Agency for Healthcare Research and Quality (AHRQ). (2011). Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS).

■ Mental disorders were more common for childbirth stays covered by Medicaid than private insurance.
  Mental disorders were among the top 10 most common complicating conditions for women covered by Medicaid (51 per 1,000 for vaginal births and 59 per 1,000 for cesarean section deliveries). In contrast, the rates of mental disorders among women with private insurance were 31 and 38 per 1,000 for vaginal and cesarean section deliveries, respectively (shown in Appendix).
■ Anemia was more common for childbirth stays covered by Medicaid than private insurance.
  Rates of anemia were higher for women who were covered by Medicaid than for those with private insurance. Among vaginal delivery stays, anemia occurred in 127 per 1,000 Medicaid-covered discharges versus 73 per 1,000 privately insured discharges. Similarly, among stays for cesarean section deliveries, anemia occurred in 186 per 1,000 discharges covered by Medicaid versus 128 per 1,000 discharges covered by private insurance.
■ For vaginal deliveries, second-degree perineal laceration rates were higher among women with private insurance than among women covered by Medicaid.
  Second-degree perineal laceration occurred at a rate of 314 per 1,000 privately insured discharges versus 178 per 1,000 Medicaid-covered discharges. Moreover, first- and second-degree perineal lacerations were the most common complicating conditions for vaginal deliveries among both payer types.

We also examined differences in prevalence rates among less common complicating conditions (see Appendix). Overall, there were very few differences in the rate of these conditions between Medicaid and private insurance for vaginal or cesarean section deliveries. There were two exceptions: thyroid dysfunction and delayed delivery after artificial rupture of membranes were each three times more common among private-payer discharges than among Medicaid-covered discharges for both types of deliveries.

### Propensity for cesarean section delivery comparing payer, by complicating condition, 2011

Figure 2 presents the percent difference in the propensity for having a cesarean section delivery for privately insured versus Medicaid-covered stays by complicating condition.

Figure 2 Propensity for cesarean section delivery, comparing privately insured versus Medicaid-covered deliveries by complicating condition

Note: Principal and secondary diagnoses were examined. Conditions with a rate of at least 5 per 1000 for cesarean section delivery are shown.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2011

This is a tornado bar chart showing the type of complicating condition by the percent difference in propensity for cesarean section. Complicating condition; Fetopelvic disproportion: −29.43; Cardiovascular disorders: −20.97; Hemorrhage from placenta previa: −14.68; Previous cesarean section: −12.62; Other immediate postpartum hemorrhage: −11.79; Abnormality in fetal heart rate or rhythm: −10.12; Excessive fetal growth: −9.43; Premature rupture of membranes: −9.09; Obstruction caused by malposition of fetus: −8.12; Delayed delivery after rupture of membranes: −8.01; Diabetes mellitus: −5.75; Other malposition and malpresentation: −4.83; Post-term pregnancy: −3.83; Polyhydramnios: −2.63; Thyroid dysfunction: −1.95; Multiple gestation: −1.79; Oliogohydramnios: −0.25; Unspecified hypertension: 2.24; Unusually large fetus causing disproportion: 3.18; Mental disorders: 3.19; Infection of amniotic cavity: 5.29; Preeclampsia: 6.33; Poor fetal growth: 10.72; Cervical incompetence: 17.60; Anemia: 19.90; Placenta previa without hemorrhage: 21.78; Breech: 30.14; Failed mechanical induction: 59.12; Failed trial of labor, unspecified: 72.26

■ Privately insured women were more likely to have a cesarean section delivery than women covered by Medicaid when complicating conditions that may impede vaginal delivery were recorded. Compared with women covered by Medicaid, women with private insurance were:
  - 72 percent more likely to have a cesarean section delivery if they experienced a failed trial of labor
  - 59 percent more likely to have a cesarean section delivery if they experienced a failed mechanical induction
  - 30 percent more likely to receive a cesarean section delivery when breech presentation was noted on the record
■ Privately insured women were more likely to have a cesarean section delivery than women covered by Medicaid when the following conditions were recorded:
  - Placenta previa without hemorrhage (women who were privately insured were 22 percent more likely to receive a cesarean section than women who were covered by Medicaid)
  - Anemia (20 percent more likely)
  - Cervical incompetence (18 percent more likely)
  - Poor fetal growth (11 percent more likely)
■ Women with private insurance were less likely to receive a cesarean section delivery than women covered by Medicaid when the following conditions were recorded:
  - Fetopelvic disproportion (privately insured women were 29 percent less likely to receive a cesarean section)
  - Cardiovascular disease (21 percent less likely)
  - Hemorrhage from placenta previa (15 percent less likely)
  - Previous cesarean section (13 percent less likely)
  - Other postpartum hemorrhage (12 percent less likely)
  - Abnormality in fetal heart rate or rhythm (10 percent less likely)

## Data Source

The estimates in this Statistical Brief are based upon data from the HCUP 2011 Nationwide Inpatient Sample (NIS).

## Definitions

### Diagnoses, ICD-9-CM, Clinical Classifications Software (CCS), and Diagnosis-Related Groups (DRGs)

The principal diagnosis is that condition established after study to be chiefly responsible for the patient's admission to the hospital. Secondary diagnoses are concomitant conditions that coexist at the time of admission or develop during the stay.

ICD-9-CM is the International Classification of Diseases, Ninth Revision, Clinical Modification, which assigns numeric codes to diagnoses. There are approximately 14,000 ICD-9-CM diagnosis codes.

CCS categorizes ICD-9-CM diagnoses into a manageable number of clinically meaningful categories.^10^ This “clinical grouper” makes it easier to quickly understand patterns of diagnoses. CCS categories identified as “Other” typically are not reported; these categories include miscellaneous, otherwise unclassifiable diagnoses that may be difficult to interpret as a group.

DRGs comprise a patient classification system that categorizes patients into groups that are clinically coherent and homogeneous with respect to resource use. DRGs group patients according to diagnosis, type of treatment (procedures), age, and other relevant criteria. Each hospital stay has one assigned DRG.

For the purpose of this Brief, “complicating conditions” includes selected ICD-9-CM diagnosis codes that are in the ICD-9-CM code section titled “Complications of Pregnancy, Childbirth, and the Puerperium.”^11^ The specific ICD-9-CM diagnosis codes used to identify each type of complicating condition are provided in Table 4.

Table 4 ICD-9-CM codes used to define complicating conditions^12^

Complicating condition | ICD-9-CM diagnosis codes
Complications mainly related to pregnancy (640–649) | [underlined: Antepartum hemorrhage, abruptio placentae, and placenta previa (641)]; - 641.0 placenta previa without hemorrhag; - 641.1 hemorrhage from placenta previa; - 641.8 other antepartum hemorrhage; - 641.9 unspecified antepartum hemorrhage; [underlined: Hypertension complicating pregnancy, childbirth, and the puerperium]; - 642.2 other pre-existing hypertension complicating pregnancy, childbirth, and the puerperium; - 642.3, 642.4, and 642.5 preeclampsia; - 642.6 eclampsia; - 642.9 unspecified hypertension complicating pregnancy, childbirth, or puerperium; [underlined: Late pregnancy]; - 645.1 post-term pregnancy; - 645.2 prolonged pregnancy; [underlined: Other current conditions in the mother classifiable elsewhere, but complicating pregnancy, childbirth, or the puerperium]; - 648.0 diabetes mellitus; - 648.1 thyroid dysfunction; - 648.2 anemia; - 648.4 mental disorders; - 648.5 and 648.6 cardiovascular disorders
Normal delivery and other indications for care in pregnancy, labor, and delivery (650–659) | [underlined: Multiple gestation]; - 651.0, 651.1, and 651.2 multiple gestation; [underlined: Malposition and malpresentation of fetus]; - 652.1 and 652.2 breech; - 652.0, 652.3, 652.4, 652.5, 652.6, 652.7, 652.8, and 652.9 other malposition and malpresentation; [underlined: Disproportion]; - 653.4 fetopelvic disproportion; - 653.5 unusually large fetus causing disproportion; [underlined: Abnormality of organs and soft tissues of pelvis]; - 654.2 previous cesarean delivery; - 654.5 cervical incompetence; [underlined: Other known or suspected fetal and placental problems affecting management of mother]; - 656.3 fetal distress; - 656.4 intrauterine death; - 656.5 poor fetal growth; - 656.6 excessive fetal growth; [underlined: Polyhydramnios]; - 657 polyhydramnios; [underlined: Other problems associated with amniotic cavity and membranes]; - 658.0 oligohydramnios; - 658.1 premature rupture of membranes; - 658.2 delayed delivery after spontaneous or unspecified rupture of membranes; - 658.3 delayed delivery after artificial rupture of membranes; - 658.4 infection of amniotic cavity
Normal delivery and other indications for care in pregnancy, labor, and delivery (650–659) | [underlined: Other Indications for Care or Intervention Related to Labor and Delivery]; - 659.0 and 659.1 failed mechanical induction; - 659.7 abnormality in fetal heart rate or rhythm
Complications occurring mainly in the course of labor and delivery (660–669) | [underlined: Obstructed labor]; - 660.0 obstruction caused by malposition of fetus at onset of labor; - 660.4 shoulder dystocia; - 660.6 failed trial of labor, unspecified; - 660.8 other causes of obstructed labor; - 660.9 unspecified obstructed labor; [underlined: Abnormality of forces of labor]; - 661.3 precipitate labor; [underlined: Long labor]; - 662.0 prolonged first stage; - 662.1 prolonged labor, unspecified; - 662.2 prolonged second stage; [underlined: Trauma to perineum and vulva during delivery]; - 664.0 first-degree perineal laceration; - 664.1 second-degree perineal laceration; - 664.2 third-degree perineal laceration; - 664.3 fourth-degree perineal laceration; [underlined: Postpartum hemorrhage]; - 666.0 third-stage hemorrhage; - 666.1 other immediate postpartum hemorrhage; - 666.2 delayed and secondary postpartum hemorrhage
Complications of the puerperium (670–677) | [underlined: Obstetrical pulmonary embolism]; - 673.0 obstetrical air embolism; - 673.1 amniotic fluid embolism; - 673.2 obstetrical blood-clot embolism; - 673.8 other pulmonary embolism

### Case definition

Analyses presented in this Statistical Brief were limited to childbirth-related hospital discharges that resulted in a delivery. Mode of delivery was defined by DRG as follows:

- Vaginal birth: 767–768 and 774–775
- Cesarean section delivery: 765–766

### Types of hospitals included in HCUP

HCUP is based on data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). HCUP data include obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded are long-term care, rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. However, if a patient received long-term care, rehabilitation, or treatment for psychiatric or chemical dependency conditions in a community hospital, the discharge record for that stay will be included in the Nationwide Inpatient Sample (NIS).

### Unit of analysis

The unit of analysis is the hospital discharge (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the hospital multiple times in one year will be counted each time as a separate “discharge” from the hospital.

### Costs and charges

Total hospital charges were converted to costs using HCUP Cost-to-Charge Ratios based on hospital accounting reports from the Centers for Medicare & Medicaid Services (CMS).^13^ Costs will reflect the actual expenses incurred in the production of hospital services, such as wages, supplies, and utility costs; charges represent the amount a hospital billed for the case. For each hospital, a hospital-wide cost-to-charge ratio is used. Hospital charges reflect the amount the hospital billed for the entire hospital stay and do not include professional (physician) fees. For the purposes of this Statistical Brief, costs are reported to the nearest hundred.

### Payer

Payer is the expected primary payer for the hospital stay. To make coding uniform across all HCUP data sources, payer combines detailed categories into general groups:

- Medicare: includes patients covered by fee-for-service and managed care Medicare
- Medicaid: includes patients covered by fee-for-service and managed care Medicaid
- Private Insurance: includes Blue Cross, commercial carriers, and private health maintenance organizations (HMOs) and preferred provider organizations (PPOs)
- Uninsured: includes an insurance status of “self-pay” and “no charge”
- Other: includes Worker's Compensation, TRICARE/CHAMPUS, CHAMPVA, Title V, and other government programs.

Hospital stays billed to the State Children's Health Insurance Program (SCHIP) may be classified as Medicaid, Private Insurance, or Other, depending on the structure of the State program. Because most State data do not identify SCHIP patients specifically, it is not possible to present this information separately.

For this Statistical brief, approximately six percent of childbirth stays were from women who were uninsured or insured through Medicare or some other payer. These data were not included in the main sample (see additional information in Table 1).

When more than one payer is listed for a hospital discharge, the first-listed payer is used.

## For More Information

For more information about HCUP, visit http://www.hcup-us.ahrq.gov/.

For additional HCUP statistics, visit HCUPnet, our interactive query system, at http://hcupnet.ahrq.gov/.

For information on other hospitalizations in the United States, refer to the following HCUP Statistical Briefs located at http://www.hcup-us.ahrq.gov/reports/statbriefs/statbriefs.jsp:

- Statistical Brief #166, Overview of Hospital Stays in the United States, 2011
- Statistical Brief #168, Costs for Hospital Stays in the United States, 2011
- Statistical Brief #162, Most Frequent Conditions in U.S. Hospitals, 2011
- Statistical Brief #165, Most Frequent Procedures Performed in U.S. Hospitals, 2011

For a detailed description of HCUP, more information on the design of the Nationwide Inpatient Sample (NIS), and methods to calculate estimates, please refer to the following publications:

Introduction to the HCUP Nationwide Inpatient Sample, 2009. Online. May 2011. U.S. Agency for Healthcare Research and Quality. http://hcup-us.ahrq.gov/db/nation/nis/NIS_2009_INTRODUCTION.pdf. Accessed April 18, 2014.

Houchens R, Elixhauser A. Final Report on Calculating Nationwide Inpatient Sample (NIS) Variances, 2001. HCUP Methods Series Report #2003-2. Online. June 2005 (revised June 6, 2005). U.S. Agency for Healthcare Research and Quality. http://www.hcup-us.ahrq.gov/reports/CalculatingNISVariances200106092005.pdf. Accessed April 18, 2014.

1 Hall MJ, DeFrances CJ, Williams SN, Golosinskiy A, Schwartzman A. (2010). National Hospital Discharge Survey: 2007 Summary. National Health Statistics Report No. 29. .

2 Podulka J, Stranges E, Steiner C. (2011). Hospitalizations Related to Childbirth, 2008. HCUP Statistical Brief #110. .

3 Stranges E, Wier LM, Elixhauser A. (2012). Complicating Conditions of Vaginal Deliveries and Cesarean Sections, 2009. HCUP Statistical Brief #131. .

4 Torio CM, Andrews RM. (2013). National Inpatient Hospital Costs: The Most Expensive Conditions by Payer, 2011. HCUP Statistical Brief #160. .

5 Rank order of major diagnostic category by aggregate costs, 2011. HCUPnet. .

6 Curtin SC, Osterman MJ, Uddin SF, Sutton SR, Reed PR. (2013). Source of Payment for the Delivery: Births in a 33-State and District of Columbia Reporting Area, 2010. National Vital Statistics Reports. .

7 Kozhimannil KB, Shippee TP, Adegoke O, Vemig BA. (2013). Trends in hospital-based childbirth care: the role of health insurance. Am J Manag Care. .

8 Heisler CA, Melton LJ, Weaver AL, Gebhart JB. (2009). Determining perioperative complications associated with vaginal hysterectomy: code classification versus chart review. J Am Coll Surg. .

9 Yasmeen S, Romano PS, Schembri ME, Keyzer JM, Gilbert WM. (2006). Accuracy of obstetric diagnoses and procedures in hospital discharge data. Am J Obstet Gynecol. .

10 Rockville, MD. HCUP Clinical Classifications Software (CCS). Healthcare Cost and Utilization Project (HCUP). .

11 Complications Mainly Related To Pregnancy (640–649); Normal Delivery and Other Indications for Care in Pregnancy, Labor, and Delivery (650–659); Complications Occurring Mainly in the Course of Labor and Delivery (660–669); and Complications of the Puerperium (670–677). .

12 The American College of Obstetricians and Gynecologists. (2014). Clinical Management Guidelines for Obstetricians and Gynecologists. Practice Bulletin. .

13 (2001–2009). HCUP Cost-to-Charge Ratio Files (CCR). Healthcare Cost and Utilization Project (HCUP). .

## Appendix Rates of specific complicating conditions of childbirth by delivery method and payer, 2011

Complicating condition | Rate per 1,000 discharges
Complicating condition | Medicaid | | | | Private insurance
Complicating condition | Vaginal | | | Cesarean section | Vaginal | | Cesarean section
Complications mainly related to pregnancy
Antepartum hemorrhage, abruptio placentae, and placenta previa
Placenta previa without hemorrhage | 0.9 | | | 5.8 | 1.1 | | 8.4
Hemorrhage from placenta previa | 0.3 | | | 6.3 | 0.4 | | 7.1
Other antepartum hemorrhage | 0.3 | | | 0.7 | 0.3 | | 0.7
Unspecified antepartum hemorrhage | 2.0 | | | 3.0 | 1.7 | | 2.7
Hypertension complicating pregnancy, childbirth, and the puerperium
Other preexisting hypertension complicating pregnancy childbirth and the puerperium | 0.3 | | | 0.8 | 0.3 | | 0.8
Preeclampsia | 58.3 | | | 99.7 | 57.4 | | 104.5
Eclampsia | 0.4 | | | 1.6 | 0.3 | | 1.1
Unspecified hypertension complicating pregnancy childbirth or the puerperium | 4.8 | | | 8.1 | 4.8 | | 8.3
Late pregnancy
Post-term pregnancy | 126.5 | | | 92.7 | 129.8 | | 91.4
Prolonged pregnancy | 1.1 | | | 1.2 | 0.8 | | 1.0
Other current conditions in the mother
Diabetes mellitus | 5.3 | | | 20.3 | 4.6 | | 16.7
Thyroid dysfunction | 12.5 | | | 17.7 | 34.4 | | 47.6
Anemia | 127.4 | | | 186.1 | 73.3 | | 128.3
Mental disorders | 50.9 | | | 59.2 | 31.3 | | 37.5
Cardiovascular disorders | 4.0 | | | 8.1 | 5.3 | | 8.5
Normal delivery and other indications for care in pregnancy, labor, and delivery
Multiple gestation
Multiple gestation | | 4.3 | 28.8 | | | 6.5 | | 42.5
Malposition and malpresentation of fetus
Breech | | 3.6 | 75.8 | | | 3.4 | | 94.0
Other malposition and malpresentation | | 14.3 | 88.5 | | | 17.7 | | 104.1
Disproportion
Fetopelvic disproportion | | 0.2 | 44.6 | | | 0.2 | | 48.2
Unusually large fetus causing disproportion | | 0.2 | 4.7 | | | 0.2 | | 5.1
Abnormality of organs and soft tissues of pelvis
Previous cesarean section | | 23.8 | 488.2 | | | 24.2 | | 434.3
Cervical incompetence | | 3.5 | 5.4 | | | 3.7 | | 6.7
Other known or suspected fetal and placental
Fetal distress | | 0.9 | 2.3 | | | 1.0 | | 2.2
Intrauterine death | | 5.2 | 3.0 | | | 4.2 | | 2.0
Poor fetal growth | | 21.6 | 35.0 | | | 17.4 | | 31.1
Excessive fetal growth | | 10.8 | 40.6 | | | 17.0 | | 57.7
Polyhydramnios
Polyhydramnios | | 4.9 | 14.2 | | | 5.9 | | 16.5
Other problems associated with amniotic cavity
Oliogohydramnios | | 25.4 | 40.3 | | | 22.8 | | 36.0
Premature rupture of membranes | | 39.1 | 39.7 | | | 43.2 | | 39.9
Delayed delivery after spontaneous or unspecified rupture of membranes | | 11.0 | 14.2 | | | 11.3 | | 13.5
Delayed delivery after artificial rupture of membranes | | 0.3 | 0.3 | | | 0.7 | | 0.9
Infection of amniotic cavity | | 17.0 | 29.1 | | | 14.3 | | 25.8
Other indications for care or intervention related
Failed mechanical induction | | 0.3 | 36.1 | | | 0.2 | | 37.1
Abnormality in fetal heart rate or rhythm | | 121.6 | 202.4 | | | 120.4 | | 180.2
Complications occurring mainly during the course of labor and delivery
Obstructed labor
Obstruction caused by malposition of fetus | | 0.6 | 19.4 | | | 0.7 | | 20.2
Shoulder dystocia | | 21.3 | 0.6 | | | 20.9 | | 0.7
Failed trial of labor, unspecified | | 0.1 | 6.8 | | | 0.0 | | 5.7
Other causes of obstructed labor | | 0.1 | 0.2 | | | 0.0 | | 0.2
Unspecified obstructed labor | | 0.3 | 0.4 | | | 0.4 | | 0.5
Abnormality of forces of labor
Precipitate labor | | 33.4 | 0.3 | | | 27.7 | | 0.3
Long labor
Prolonged first stage | | 1.1 | 0.7 | | | 1.4 | | 1.1
Prolonged second stage | | 4.0 | 2.1 | | | 7.3 | | 3.7
Prolonged labor, unspecified | | 1.9 | 1.7 | | | 1.8 | | 1.6
Trauma to perineum and vulva during delivery
First-degree perineal laceration | | 232.2 | 0.6 | | | 240.6 | | 0.8
Second-degree perineal laceration | | 177.9 | 0.3 | | | 313.5 | | 0.7
Third-degree perineal laceration | | 16.1 | 0.1 | | | 31.5 | | 0.1
Fourth-degree perineal laceration | | 4.8 | 0.0 | | | 6.8 | | 0.0
Postpartum hemorrhage
Third-stage hemorrhage | | 3.0 | 1.5 | | | 3.2 | | 1.5
Other immediate postpartum hemorrhage | | 26.7 | 21.6 | | | 22.9 | | 16.3
Delayed and secondary postpartum | | 3.2 | 0.7 | | | 3.3 | | 0.5
Complications of the puerperium
Obstetrical pulmonary embolism
Obstetrical air embolism | | 0.0 | 0.0 | | | 0.0 | | 0.0
Amniotic fluid embolism | | 0.0 | 0.1 | | | 0.0 | | 0.1
Obstetrical blood-clot embolism | | 0.1 | 0.3 | | | 0.1 | | 0.2
Other pulmonary embolism | | 0.0 | . | | | . | | 0.0