# Statistical Brief #171 Trends in Operating Room Procedures in U.S. Hospitals, 2001–2011

## Introduction

More than 24 million hospital stays (63% of all stays) in 2011 involved some type of procedure.^1^ Some of these procedures (such as a chest X-ray or skin biopsy) occurred outside of the operating room (OR). Others were major OR procedures (such as hip replacement or heart valve repair). Hospital stays that involve OR procedures are more costly, on average, than stays that do not involve OR procedures.^2^

Over time, some OR procedures have become more prevalent, while others have decreased in frequency. For instance, prior research has found that the volume of coronary artery bypass graft (CABG) decreased by 70 percent from 1997 to 2007, while the volume of percutaneous transluminal coronary angioplasty (PTCA) increased by 20 percent during this same time period.^3^ Such trends may reflect changing standards in surgical care, the introduction of new surgical techniques, a shift in procedure setting from inpatient to outpatient, or an aging population, among other reasons.

This Statistical Brief presents data from the Healthcare Cost and Utilization Project (HCUP) on trends in OR procedures from 2001 through 2011. For this Statistical Brief, OR procedures are defined using the HCUP procedure classes tool.^4^ In this tool, OR procedures are identified based on diagnosis-related groups (DRGs) that use physician panels to determine whether the procedure would be performed in a hospital OR in most hospitals. The findings in this Statistical Brief represent an update of 2007 statistics reported by Elixhauser and Andrews.^5^ We present the 2001 and 2011 volume of OR procedures by major clinical body system. For selected high-volume procedures, we provide the trends and identify differences over the 11-year period examined. All differences between estimates noted in the text are significantly different at the .001 level or better.

## Findings

Highlights

■ In 2011, over 15 million operating room (OR) procedures were performed in U.S. hospitals. Although the overall number of procedures remained stable from 2001–2011, the mix of procedures changed.
■ In 2001, musculoskeletal procedures constituted 17.9 percent of all procedures. By 2011, this figure rose to 24.2 percent, which is a 38 percent increase in 11 years.
■ Within the musculoskeletal system, knee arthroplasty had the largest growth in volume, nearly doubling between 2001 and 2011 (a 93 percent increase). Approximately 718,500 knee arthroplasties were performed in 2011. There was a 70 percent growth in spinal fusion during the 11-year period.
■ Among digestive-related procedures, appendectomies decreased by 13 percent, while colorectal resection and cholecystectomy procedures remained relatively stable over time.
■ Two common cardiovascular procedures decreased from 2001–2011. Coronary artery bypass graft (CABG) procedures decreased by nearly half to 213,700 procedures in 2011, and percutaneous coronary angioplasty (PTCA) decreased by more than one-fourth to 560,500 procedures in 2011.

### Operating room procedures by clinical body system, 2001 and 2011

Table 1 presents the number of OR procedures by major clinical body system in 2001 and 2011. Although the overall number of procedures remained relatively unchanged across this time frame, the mix of procedures changed substantially.

Table 1 Operating room procedures by clinical body system, 2001 and 2011

Rank (2011) | Clinical body system | 2001 | | 2011
Rank (2011) | Clinical body system | Number, in thousands | Percent | Number, in thousands | Percent
Total operating room procedures | | 15,334 | 100.0 | 15,662 | 100.0
1 | Musculoskeletal system | 2,740 | 17.9 | 3,785 | 24.2
2 | Digestive system | 2,764 | 18.0 | 2,898 | 18.5
3 | Cardiovascular system | 2,383 | 15.5 | 2,123 | 13.6
4 | Female genital organs | 2,000 | 13.0 | 1,343 | 8.6
5 | Obstetrical procedures | 1,064 | 6.9 | 1,307 | 8.3
6 | Male genital organs | 1,428 | 9.3 | 1,283 | 8.2
7 | Nervous system | 796 | 5.2 | 917 | 5.9
8 | Integumentary system | 596 | 3.9 | 473 | 3.0
9 | Urinary system | 471 | 3.1 | 432 | 2.8
10 | Hemic and lymphatic system | 290 | 1.9 | 331 | 2.1
11 | Respiratory system | 301 | 2.0 | 313 | 2.0
12 | Miscellaneous | 191 | 1.2 | 171 | 1.1
13 | Nose, mouth, and pharynx | 146 | 1.0 | 125 | 0.8
14 | Endocrine system | 96 | 0.6 | 116 | 0.7
15 | Eye | 41 | 0.3 | 24 | 0.2
16 | Ear | 29 | 0.2 | 20 | 0.1

Note: The difference in volume between 2001 and 2011 was statistically significant for each clinical body system at p<.0001.

Source: Agency for Healthcare Research and Quality (AHRQ). Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2001 and 2011.

In 2011, nearly one-fourth (24.2 percent) of the 15,661,700 total OR procedures involved the musculoskeletal system, which is a 38 percent increase from 17.9 percent in 2001. There was a small increase (5 percent) in OR procedures of the digestive system between 2001 and 2011—from 18.0 percent to 18.5 percent of all OR procedures. OR procedures involving the cardiovascular system decreased from 15.5 percent of all OR procedures in 2001 to 13.6 percent in 2011 (an 11 percent decrease in volume). OR procedures involving the female and male genital organs each constituted over 8 percent of all OR procedures in 2011, and both decreased in volume from 2001 (33 percent for female genital organs and 10 percent for male genital organs). Obstetrical procedures also represented just over 8 percent of all OR procedures in 2011—a 23 percent increase in volume since 2001.

Figures 1 through 7 provide the 2001–2011 trends for selected OR procedures from the clinical body systems in Table 1 that comprise the largest number of procedures performed in 2011. Selected OR procedures presented in the figures are those with at least 100,000 annual discharges and those that represent relatively homogeneous groups of procedures.^6^

Figure 1 Orthopedic operating room procedures, 2001–2011

Note: Percentage differences presented in the figure refer to changes in procedure volume between 2001 and 2011.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2001–2011

This figure is a line chart showing the number of procedures by year for two procedures. Arthroplasty of the knee (93% increase in procedure volume from 2001 to 2011); 2001: 372,000; 2002: 407,000; 2003: 434,000; 2004: 488,000; 2005: 556,000; 2006: 553,000; 2007: 611,000; 2008: 687,000; 2009: 686,000; 2010: 730,000; 2011: 718,000; Hip replacement, total and partial (40% increase in procedure volume from 2001 to 2011); 2001: 332,000; 2002: 346,000; 2003: 343,000; 2004: 368,000; 2005: 383,000; 2006: 370,000; 2007: 404,000; 2008: 439,000; 2009: 438,000; 2010: 456,000; 2011: 467,000; Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2001–2011

Figure 2 Back-related operating room procedures, 2001–2011

Note: Percentage differences presented in the figure refer to changes in procedure volume between 2001 and 2011.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2001–2011

This figure is a line chart showing the number of procedures by year for two operating room procedures. Laminectomy; 2001: 485,000; 2002: 476,000; 2003: 325,000; 2004: 324,000; 2005: 349,000; 2006: 360,000; 2007: 368,000; 2008: 426,000; 2009: 447,000; 2010: 492,000; 2011: 488,000; Spinal fusion (70% increase in procedure volume from 2001 to 2011); 2001: 288,000; 2002: 306,000; 2003: 325,000; 2004: 324,000; 2005: 349,000; 2006: 360,000; 2007: 368,000; 2008: 426,000; 2009: 447,000; 2010: 492,000; 2011: 488,000; Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2001–2011

Figure 3 Digestive-related operating room procedures, 2001–2011

Note: Percentage differences presented in the figure refer to changes in procedure volume between 2001 and 2011.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2001–2011

This figure is a line chart showing the number of procedures by year for three operating room procedures. Colorectal resection; 2001: 307,000; 2002: 319,000; 2003: 315,000; 2004: 316,000; 2005: 320,000; 2006: 320,000; 2007: 329,000; 2008: 341,000; 2009: 326,000; 2010: 318,000; 2011: 333,000; Appendectomy (13% decrease in procedure volume from 2001 to 2011); 2001: 377,000; 2002: 386,000; 2003: 386,000; 2004: 384,000; 2005: 391,000; 2006: 382,000; 2007: 377,000; 2008: 379,000; 2009: 370,000; 2010: 352,000; 2011: 327,000; Cholecystectomy and common duct exploration; 2001: 466,000; 2002: 477,000; 2003: 467,000; 2004: 456,000; 2005: 446,000; 2006: 448,000; 2007: 434,000; 2008: 465,000; 2009: 460,000; 2010: 450,000; 2011: 449,000; Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2001–2011

Figure 4 Heart-related operating room procedures, 2001–2011

Note: Percentage differences presented in the figure refer to changes in procedure volume between 2001 and 2011.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2001–2011

This figure is a line chart showing the number of procedures by year for four operating room procedures. Heart valve procedures; 2001: 100,000; 2002: 97,000; 2003: 102,000; 2004: 96,000; 2005: 103,000; 2006: 110,000; 2007: 98,000; 2008: 108,000; 2009: 124,000; 2010: 107,000; 2011: 120,000; Coronary artery bypass graft (46% decrease in procedure volume from 2001 to 2011); 2001: 395,000; 2002: 370,000; 2003: 348,000; 2004: 308,000; 2005: 275,000; 2006: 305,000; 2007: 251,000; 2008: 262,000; 2009: 268,000; 2010: 218,000; 2011: 214,000; Percutaneous coronary angioplasty (PTCA) (28% decrease in procedure volume from 2001 to 2011); 2001: 774,000; 2002: 757,000; 2003: 800,000; 2004: 791,000; 2005: 795,000; 2006: 907,000; 2007: 722,000; 2008: 758,000; 2009: 693,000; 2010: 562,000; 2011: 560,000; Cardiac pacemaker or cardioverter/defibrillator procedures (42% increase in procedure volume from 2001 to 2011); 2001: 96,000; 2002: 127,000; 2003: 146,000; 2004: 159,000; 2005: 179,000; 2006: 201,000; 2007: 182,000; 2008: 179,000; 2009: 177,000; 2010: 143,000; 2011: 136,000; Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2001–2011

Figure 5 Other vascular operating room procedures, 2001–2011

Note: Percentage differences presented in the figure refer to changes in procedure volume between 2001 and 2011.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2001–2011

This figure is a line chart showing the number of procedures by year for two operating room procedures. Endarterectomy, vessel of head and neck (32% decrease in procedure volume from 2001 to 2011); 2001: 151,000; 2002: 149,000; 2003: 141,000; 2004: 128,000; 2005: 123,000; 2006: 120,000; 2007: 120,000; 2008: 120,000; 2009: 113,000; 2010: 98,000; 2011: 103,000; Peripheral vascular bypass (37% decrease in procedure volume from 2001 to 2011); 2001: 121,000; 2002: 114,000; 2003: 106,000; 2004: 98,000; 2005: 89,000; 2006: 90,000; 2007: 82,000; 2008: 83,000; 2009: 80,000; 2010: 73,000; 2011: 76,000; Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2001–2011

Figure 6 Operating room procedures related to female genital organs, 2001–2011

Note: Percentage differences presented in the figure refer to changes in procedure volume between 2001 and 2011.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2001–2011

This figure is a line chart showing the number of procedures by year for four operating room procedures. Oophorectomy, unilateral and bilateral (47% decrease in procedure volume from 2001 to 2011); 2001: 504,000; 2002: 528,000; 2003: 469,000; 2004: 458,000; 2005: 442,000; 2006: 408,000; 2007: 391,000; 2008: 375,000; 2009: 346,000; 2010: 307,000; 2011: 268,000; Ligation of fallopian tubes; 2001: 299,000; 2002: 320,000; 2003: 319,000; 2004: 336,000; 2005: 329,000; 2006: 347,000; 2007: 346,000; 2008: 308,000; 2009: 290,000; 2010: 432,000; 2011: 274,000; Hysterectomy, abdominal and vaginal (38% decrease in procedure volume from 2001 to 2011); 2001: 627,000; 2002: 662,000; 2003: 608,000; 2004: 596,000; 2005: 590,000; 2006: 469,000; 2007: 539,000; 2008: 512,000; 2009: 483,000; 2010: 432,000; 2011: 389,000; Repair of bladder or rectal hernia (39% decrease in procedure volume from 2001 to 2011); 2001: 143,000; 2002: 147,000; 2003: 138,000; 2004: 136,000; 2005: 131,000; 2006: 130,000; 2007: 122,000; 2008: 120,000; 2009: 105,000; 2010: 93,000; 2011: 88,000; Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2001–2011

Figure 7 Delivery and newborn operating room procedures, 2001–2011

Note: Percentage differences presented in the figure refer to changes in procedure volume between 2001 and 2011.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2001–2011

This figure is a line chart showing the number of procedures by year for two operating room procedures. Circumcision; 2001: 1,182,000; 2002: 1,247,000; 2003: 1,189,000; 2004: 1,205,000; 2005: 1,229,000; 2006: 1,218,000; 2007: 1,297,000; 2008: 1,225,000; 2009: 1,167,000; 2010: 1,144,000; 2011: 1,101,000; Cesarean section (28% increase in procedure volume from 2001 to 2011); 2001: 996,000; 2002: 1,104,000; 2003: 1,171,000; 2004: 1,271,000; 2005: 1,304,000; 2006: 1,346,000; 2007: 1,482,000; 2008: 1,378,000; 2009: 1,382,000; 2010: 1,278,000; 2011: 1,272,000; Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2001–2011

### Trends for selected musculoskeletal OR procedures, 2001–2011

Figure 1 presents the trend in two orthopedic OR procedures from 2001 through 2011. Knee arthroplasty nearly doubled (93 percent increase) over the 11-year period, from 371,600 procedures in 2001 to 718,500 procedures in 2011. Hip replacement procedures increased by 40 percent over the 10-year period, from 332,500 procedures in 2001 to 466,500 procedures in 2011.

Back-related OR procedures are shown in Figure 2. Spinal fusion increased by 70 percent, from 287,600 procedures in 2001 to 488,300 procedures in 2011. Laminectomy remained relatively stable during the same time period at about 490,000 procedures each year.

### Trends for selected digestive OR procedures, 2001–2011

As shown in Figure 3, the volume of appendectomy procedures decreased by 13 percent over the 11-year period, from 376,700 procedures in 2001 to 327,100 procedures in 2011. Colorectal resection procedures and cholecystectomy/common duct exploration procedures remained relatively stable during this time: colorectal resection (about 320,000 procedures per year) and cholecystectomy (about 460,000 procedures per year).

### Trends for selected cardiovascular OR procedures, 2001–2011

Figure 4 shows that the number of coronary artery bypass graft (CABG) procedures decreased by 46 percent, from 395,100 procedures in 2001 to 213,700 procedures in 2011. Similarly, percutaneous coronary angioplasty (PTCA) decreased by 28 percent, from 773,900 procedures in 2001 to 560,500 procedures in 2011; the decrease occurred primarily between 2006 and 2011. The volume of cardiac pacemaker or cardioverter/defibrillator procedures increased by 42 percent during this time, from 96,000 procedures in 2001 to 135,800 procedures in 2011. Heart valve procedures remained relatively stable during the 11-year time period at about 110,000 procedures each year.

Figure 5 shows a decrease in two specific vascular OR procedures that are not related to the heart. Both endarterectomy and peripheral vascular bypass decreased by approximately one-third between 2001 and 2011. Endarterectomy decreased from 151,000 procedures in 2001 to 102,700 procedures in 2011. Peripheral vascular bypass decreased from 121,000 procedures in 2001 to 76,200 procedures in 2011.

### Trends for selected OR procedures related to female genital organs, 2001–2011

Figure 6 shows that the volume of hysterectomy, oophorectomy, and repair of bladder or rectal hernia procedures each decreased by about 40 percent between 2001 and 2011. Hysterectomy decreased from 626,600 procedures in 2001 to 389,100 procedures in 2011. Oophorectomy decreased from 504,100 procedures in 2001 to 268,200 procedures in 2011. Repair of bladder or rectal hernia procedures decreased from 143,400 procedures in 2001 to 87,800 procedures in 2011. In contrast, ligation of the fallopian tubes remained relatively stable during the 11-year time period at about 310,000 procedures each year.

### Trends for selected obstetrical and newborn OR procedures, 2001–2011

Figure 7 shows that the volume of Cesarean section increased 28 percent from 995,700 procedures in 2001 to 1,272,000 procedures in 2011, although there appears to be some retreat from the high point in 2007. Circumcision remained relatively stable during the 11-year period at about 1,200,000 procedures each year.^7^

## Data Source

The estimates in this Statistical Brief are based upon data from the Healthcare Cost and Utilization Project (HCUP) 2001 through 2011 Nationwide Inpatient Sample (NIS). Estimates of the volume for selected operating room (OR) procedures were taken from HCUPnet, the online query system that provides free access to information from HCUP: http://hcupnet.ahrq.gov/. HCUPnet provides the ability to retrieve health statistics and information on hospital inpatient and emergency department utilization. For the purposes of this Statistical Brief, the number of OR procedures is reported to the nearest hundred.

Many hypothesis tests were conducted for this Statistical Brief. Thus, to decrease the number of false-positive results, we reduced the significance level to .001 for individual tests.

## Definitions

### Procedures, ICD-9-CM, and Clinical Classifications Software (CCS)

All-listed procedures include all procedures performed during the hospital stay, whether for definitive treatment or for diagnostic or exploratory purposes. ICD-9-CM is the International Classification of Diseases, Ninth Revision, Clinical Modification, which assigns numeric codes to procedures. There are about 4,000 ICD-9-CM procedure codes.

CCS categorizes procedure codes into clinically meaningful categories.^8^ This “clinical grouper” makes it easier to quickly understand patterns of procedure use. CCS categories identified as “Other” typically are not reported; these categories include miscellaneous, otherwise unclassifiable procedures that may be difficult to interpret as a group.

Major OR procedures were defined using procedure classes, which categorize each ICD-9-CM procedure code as either major therapeutic, major diagnostic, minor therapeutic, or minor diagnostic.^9^

Table 2 lists the specific CCS procedure categories and clinical body systems for the selected OR procedures presented in the trend figures in this Statistical Brief.

Table 2 Clinical Classifications Software procedure category and clinical body system for selected operating room (OR) procedures presented in trend figures

Trend figure | CCS procedure category | Clinical body system
Figure 1: Orthopedic OR procedures | 152: Arthroplasty knee | Musculoskeletal system
Figure 1: Orthopedic OR procedures | 153: Hip replacement, total and partial | Musculoskeletal system
Figure 2: Back-related OR procedures | 3: Laminectomy | Nervous system
Figure 2: Back-related OR procedures | 158: Spinal fusion | Musculoskeletal system
Figure 3: Digestive-related OR procedures | 78: Colorectal resection | Digestive system
Figure 3: Digestive-related OR procedures | 80: Appendectomy | Digestive system
Figure 3: Digestive-related OR procedures | 84: Cholecystectomy and common duct exploration | Digestive system
Figure 4: Heart-related OR procedures | 43: Heart valve procedures | Cardiovascular system
Figure 4: Heart-related OR procedures | 44: Coronary artery bypass graft (CABG) | Cardiovascular system
Figure 4: Heart-related OR procedures | 45: Percutaneous coronary angioplasty (PTCA) | Cardiovascular system
Figure 4: Heart-related OR procedures | 48: Cardiac pacemaker or cardioverter/defibrillator procedures | Cardiovascular system
Figure 5: Other vascular OR procedures | 51: Endarterectomy, vessel of head and neck | Cardiovascular system
Figure 5: Other vascular OR procedures | 55: Peripheral vascular bypass | Cardiovascular system
Figure 6: OR procedures related to female genital organs | 119: Oophorectomy, unilateral and bilateral | Female genital organs
Figure 6: OR procedures related to female genital organs | 121: Ligation of fallopian tubes | Female genital organs
Figure 6: OR procedures related to female genital organs | 124: Hysterectomy, abdominal and vaginal | Female genital organs
Figure 6: OR procedures related to female genital organs | 129: Repair of bladder or rectal hernia | Female genital organs
Figure 7: Delivery and newborn OR procedures | 115: Circumcision | Male genital organs
Figure 7: Delivery and newborn OR procedures | 134: Cesarean section | Obstetrical procedures

### Types of hospitals included in HCUP

HCUP is based on data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). HCUP data include obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded are long-term care, rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. However, if a patient received long-term care, rehabilitation, or treatment for psychiatric or chemical dependency conditions in a community hospital, the discharge record for that stay will be included in the Nationwide Inpatient Sample (NIS).

### Unit of analysis

The unit of analysis is the hospital discharge (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the hospital multiple times in one year will be counted each time as a separate “discharge” from the hospital.

## For More Information

For more information about HCUP, visit http://www.hcup-us.ahrq.gov/.

For additional HCUP statistics, visit HCUPnet, our interactive query system, at http://hcupnet.ahrq.gov/.

For information on other hospitalizations in the United States, refer to the following HCUP Statistical Briefs located at http://www.hcup-us.ahrq.gov/reports/statbriefs/statbriefs.jsp:

- Statistical Brief #144, Overview of Hospital Stays in the United States, 2010
- Statistical Brief #146, Costs for Hospital Stays in the United States 2010
- Statistical Brief #148, Most Frequent Conditions in U.S. Hospitals, 2010
- Statistical Brief #149, Most Frequent Procedures Performed in U.S. Hospitals, 2010

For a detailed description of HCUP, more information on the design of the Nationwide Inpatient Sample (NIS), and methods to calculate estimates, please refer to the following publications:

Introduction to the HCUP Nationwide Inpatient Sample, 2009. Online. May 2011. U.S. Agency for Healthcare Research and Quality. http://hcup-us.ahrq.gov/db/nation/nis/NIS_2009_INTRODUCTION.pdf. Accessed December 4, 2013.

Houchens R, Elixhauser A. Final Report on Calculating Nationwide Inpatient Sample (NIS) Variances, 2001. HCUP Methods Series Report #2003-2. Online. June 2005 (revised June 6, 2005). U.S. Agency for Healthcare Research and Quality. http://www.hcup-us.ahrq.gov/reports/CalculatingNISVariances200106092005.pdf. Accessed December 4, 2013.

1 Pfuntner A, Wier LM, Stocks C. (2013). Most Frequent Procedures Performed in U.S. Hospitals, 2011. HCUP Statistical Brief #165. .

2 Elixhauser A, Andrews RM. (2010). Profile of inpatient operating room procedures in US hospitals in 2007. Arch Surg. .

3 Ibid.

4 HCUP Procedure Classes. Healthcare Cost and Utilization Project (HCUP). .

5 Elixhauser and Andrews 2010.

6 Procedures are identified using AHRQ's Clinical Classifications Software (CCS). Certain CCS procedure categories with at least 100,000 annual discharges are not reported: procedures that are identified as “other”; procedures that are nonspecific and could be performed for a variety of reasons (e.g., treatment, fracture, or dislocation of lower extremity other than hip or femur; small bowel resection; amputation of lower extremity; partial excision of the bone); and procedures that are likely to be adjuncts to other procedures (e.g., excision, lysis peritoneal adhesions; treatment, fracture, or dislocation of hip and femur).

7 Non-neonatal circumcisions represent fewer than 1 percent of all OR circumcision procedures and were excluded from Figure 7.

8 HCUP Clinical Classifications Software (CCS). Healthcare Cost and Utilization Project (HCUP). .

9 HCUP Procedure Classes. Healthcare Cost and Utilization Project (HCUP). .