# Statistical Brief #169 Trends in Pediatric and Adult Hospital Stays for Asthma, 2000–2010

## Introduction

Asthma is a chronic disease characterized by inflammation of the airways. It restricts the passage of air into the lungs and leads to episodes of wheezing, coughing, chest tightness, and shortness of breath. Severe asthmatic episodes can close off airways completely and, in some cases, may be life-threatening.^1^

In 2010, approximately 7.0 million children aged 0–17 years and 18.7 million adults aged 18 years and older had a diagnosis of asthma. The prevalence of asthma in the United States has increased from 7.3 percent of the population in 2001 to 8.4 percent in 2010.^2^

Asthma is largely controllable with proper primary care, and the need for hospitalization can usually be prevented. However, differences in rates of hospitalization for asthma suggest that there is significant room for improvement in caring for the condition.

This Statistical Brief presents data from the Healthcare Cost and Utilization Project (HCUP) on trends in pediatric and adult inpatient hospital stays for asthma at U.S. community hospitals from 2000 through 2010. In addition, we present patient characteristics of pediatric and adult hospital stays for asthma in 2010. Differences that are noted in the text exhibit at least a 10 percent difference between estimates and are statistically significant at 0.05 or better.

## Findings

Highlights

■ From 2000 through 2010, the rate of pediatric hospital stays for asthma declined from 165 to 130 per 100,000 population, respectively, whereas the rate for adults remained about 119 per 100,000 population.
■ The average cost per asthma-related hospital stay for children remained relatively stable at about $3,600 from 2000 to 2010, whereas the average cost per asthma-related hospital stay for adults increased from $5,200 to $6,600.
■ Among children, the rate of hospital stays for asthma was 54 percent higher for males than females. This pattern was reversed among adults: females had a 129 percent higher rate of hospital stays than males.
■ Rates of asthma-related admission were more than three times higher among African American children and two times higher for African American adults compared with White and Asian and Pacific Islander patients.
■ Pediatric and adult patients in the lowest income communities had consistently higher rates of hospital stays for asthma than those in the highest income communities.
■ Medicaid was the most frequent expected primary payer among children and adults aged 18–44 years; private insurance was the second most frequent payer.

### Rate of pediatric and adult hospital stays for asthma, 2000–2010

Figure 1 displays the age- and sex-adjusted rates of hospital stays for asthma from 2000 through 2010 for children (aged 2–17 years) and adults (aged 18 years and older).^3^ The rate of pediatric asthma-related hospital stays declined from about 165 per 100,000 population in 2000 to 130 per 100,000 population in 2010. Although there was some variation across years, the rate of adult asthma-related hospital stays remained relatively unchanged between 2000 and 2010 at about 119 hospital stays per 100,000 population. The rate of pediatric hospital stays was higher than the rate of adult hospital stays for asthma from 2000 through 2005; pediatric and adult rates were similar from 2006 through 2010.

Figure 1 Trends in the rate of hospital stays for asthma per 100,000 population for children and adults, 2000–2010

Note: Rates are adjusted for age and sex.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2000–2010, and AHRQ Prevention Quality Indicators (PQIs)

Figure 1 is a line graph showing the number of hospital stays for asthma per 100,000 population by year for children and adults. Children aged 2–17 years; 2000: 165; 2001: 148; 2002: 149; 2003: 178; 2004: 156; 2005: 165; 2006: 144; 2007: 132; 2008: 118; 2009: 145; 2010: 130; Adults aged 18 years and older; 2000: 112; 2001: 113; 2002: 120; 2003: 136; 2004: 120; 2005: 127; 2006: 124; 2007: 118; 2008: 125; 2009: 131; 2010: 119

### Average cost of pediatric and adult hospital stays for asthma, 2000–2010

Figure 2 displays the average inflation-adjusted cost of hospital stays for asthma from 2000 through 2010 for children (aged 2–17 years) and adults (aged 18 years and older). The average cost per hospital stay for children with asthma remained relatively stable at about $3,600 from 2000 to 2010. During this same period, the average cost per adult asthma-related hospital stay increased from $5,200 to $6,600. The average cost per hospital stay for asthma was consistently higher for adults than children across all years.

Figure 2 Trends in the average cost of hospital stays for asthma for children and adults, 2000–2010

Note: Costs were adjusted for inflation to 2010 using the price index for the gross domestic product.

Source: Agency for Healthcare Research and Quality, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2000–2010, and AHRQ Prevention Quality Indicators (PQIs)

Figure 2 is a line graph showing the mean cost per hospital stay for asthma by year for children and adults. Children aged 2–17 years; 2000: 3,300; 2001: 3,200; 2002: 3,800; 2003: 3,400; 2004: 3,700; 2005: 3,500; 2006: 3,300; 2007: 3,400; 2008: 3,300; 2009: 3,300; 2010: 3,600; Adults aged 18 years and older; 2000: 5,200; 2001: 5,300; 2002: 5,900; 2003: 6,100; 2004: 6,100; 2005: 6,200; 2006: 6,300; 2007: 6,300; 2008: 6,300; 2009: 6,300; 2010: 6,600

### Rate of pediatric and adult hospital stays for asthma by patient characteristics, 2010

Table 1 displays the rate of asthma-related hospital stays for children and adults by patient characteristics. In 2010, the rate of hospital stays for asthma was similar for children (129.7 per 100,000 population) and adults (119.3 per 100,000 population). Among children, the rate of hospital stays for asthma was 54 percent higher for males than females (156.5 versus 101.7 stays per 100,000 population). This pattern was reversed among adults: females had a 129 percent higher rate of hospital stays than males (163.0 versus 71.2 hospital stays per 100,000 population). Across both age groups, African American and Hispanic patients had higher rates of asthma relative to White and Asian and Pacific Islander patients in 2010. Notably, hospitalization rates were more than three times higher for African American children and two times higher for African American adults compared with White and with Asian and Pacific Islander patients. Pediatric and adult patients in the lowest income communities had higher rates of hospital stays for asthma than those in the highest income communities.

Table 1 Adjusted rate of hospital stays for asthma per 100,000 population for children and adults, 2010

Patient characteristic | Hospital stays for asthma per 100,000 population
Patient characteristic | Children (aged 2–17 years) | Adults (aged 18 years and older)
Total U.S. | 129.7 | 119.3
Sex
Male | 156.5 | 71.2
Female | 101.7 | 163.0
Race/ethnicity
Non-Hispanic
White | 83.8 | 90.5
African American | 363.9 | 297.9
Asian and Pacific Islander | 78.2 | 65.4
Hispanic (of any race) | 128.8 | 144.6
Community-level income
First quartile (lowest income) | 182.8 | 194.3
Second quartile | 123.7 | 117.4
Third quartile | 113.9 | 100.0
Fourth quartile (highest income) | 95.2 | 72.6
Location of patient residence
Large metropolitan | 140.6 | 139.1
Small metropolitan | 124.9 | 94.5
Micropolitan | 97.6 | 99.2
Not metropolitan or micropolitan | 104.0 | 110.0
Location of inpatient treatment
Northeast | 176.8 | 167.6
Midwest | 104.6 | 120.5
South | 130.3 | 120.8
West | 119.7 | 76.5

Note: Rates are adjusted for age and sex.

Source: Agency for Healthcare Research and Quality (AHRQ). Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS) and State Inpatient Databases (SID) disparities analytic file, 2010, and AHRQ Prevention Quality Indicators (PQIs).

Adults residing in large metropolitan areas had a higher rate of hospital stays for asthma (139.1 per 100,000 population) than adults residing in other areas. Children residing in large metropolitan areas had a higher rate of hospital stays for asthma (140.6 per 100,000 population) than children residing in micropolitan areas only (97.6 per 100,000 population). Adults treated in the Northeast had a higher rate of hospital stays for asthma (167.6 per 100,000 population) than adults in other Census regions. Children treated in the Northeast had a significantly higher rate of hospital stays for asthma (176.8 per 100,000 population) than children treated in the Midwest only (104.6 per 100,000 population).

### Distribution of stays by age group and expected primary payer, 2010

Figure 3 shows that Medicaid was the largest expected primary payer of hospital stays for asthma among children aged 2–17 years (55 percent) and adults aged 18–44 years (35 percent). Private insurance was the second largest primary payer of hospital stays for asthma among these same two age groups (children, 38 percent; adults aged 18–44 years, 29 percent). Among adults aged 45–64 years, private insurance was the payer for one-third of all asthma-related hospital stays, and Medicaid and Medicare each were payers for about one-fourth of these stays. Among patients aged 65 years and older, nearly 9 out of 10 hospital stays for asthma were billed to Medicare. The proportion of asthma-related hospital stays that were uninsured was highest among patients aged 18–44 years (21 percent), followed by patients aged 45–64 years (12 percent).

Figure 3 Distribution of hospital stays for asthma by age group and primary expected payer, 2010

Note: Percentages less than 2 percent are not labeled. The Medicare percentage for children aged 2–17 years is not visible because it is only 0.2 percent.

Source: Agency for Healthcare Research and Quality, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2010, and AHRQ Prevention Quality Indicators (PQIs)

Figure 3 is a stacked bar graph showing the percent distribution by age group. Age group 2–17 years (129.7 stays per 100,000); Private insurance, 38; Medicare, less than 2; Medicaid, 55; Other insurance, 3; Uninsured, 4; Age group 18–44 years (67.9 stays per 100,000); Private insurance, 29; Medicare, 11; Medicaid, 35; Other insurance, 5; Uninsured, 21; Age group 45–64 years (155.2 stays per 100,000); Private insurance, 33; Medicare, 25; Medicaid, 26; Other insurance, 4; Uninsured, 12; Age group 65 years and older (212.1 stays per 100,000); Private insurance, 8; Medicare, 88; Medicaid, 3; Other insurance, less than 2; Uninsured, less than 2

## Data Source

The estimates in this Statistical Brief are based upon data from the Healthcare Cost and Utilization Project (HCUP) 2000–2010 Nationwide Inpatient Sample (NIS) and a 2010 disparities analysis file (see description below) created from the State Inpatient Databases (SID). The disparities analysis file is designed to provide national estimates on racial disparities using weighted records from a sample of hospitals in the SID.

Differences that are noted in the text exhibit at least a 10 percent difference between estimates and achieved a level of statistical significance of 0.05 or better.

### State Inpatient Databases disparities analysis file

Measures of race and ethnicity can be problematic in hospital discharge databases. Some States do not collect information on race and ethnicity from hospitals and, within States that collect the information, some hospitals do not code race and ethnicity reliably. A disparities analysis file designed to provide national estimates by race and ethnicity was constructed using the HCUP SID from participating States that report patient race and ethnicity. This file was created using a stratified, weighted sample of hospitals with good reporting of these measures. It contains data from about 2,000 hospitals and is a 40-percent sample of community, nonrehabilitation hospitals in the United States.

For 2010, SID data from the following 37 States were used: Alaska, Arizona, Arkansas, California, Colorado, Connecticut, Florida, Georgia, Hawaii, Illinois, Indiana, Iowa, Kansas, Kentucky, Maryland, Massachusetts, Michigan, Montana, Mississippi, Nevada, New Jersey, New Mexico, New York, North Carolina, Oklahoma, Oregon, Pennsylvania, Rhode Island, South Carolina, South Dakota, Tennessee, Texas, Utah, Virginia, Vermont, Wisconsin, and Wyoming.

## Definitions

### Diagnoses and ICD-9-CM

The principal diagnosis is that condition established after study to be chiefly responsible for the patient's admission to the hospital. Secondary diagnoses are concomitant conditions that coexist at the time of admission or develop during the stay.

ICD-9-CM is the International Classification of Diseases, Ninth Revision, Clinical Modification, which assigns numeric codes to diagnoses. There are approximately 14,000 ICD-9-CM diagnosis codes.

### Case definition: asthma

Rates of asthma hospital stays for adults and children were based on the AHRQ Prevention Quality Indicators (PQIs) for asthma (PQI #15 for adults and PDI #14 for children), version 4.1. Rates were adjusted by age and sex using the 2000 United States population as the standard^4^.

The numerator (outcome of interest) of the rate included the following:

- Inpatient hospital stays with an ICD-9-CM principal diagnosis code of asthma, defined as one of the following codes:
  ○ 49300 EXT ASTHMA W/O STAT ASTH
  ○ 49301 EXT ASTHMA W STATUS ASTH
  ○ 49302 EXT ASTHMA W ACUTE EXAC OCT00
  ○ 49310 INT ASTHMA W/O STAT ASTH
  ○ 49311 INT ASTHMA W STATUS ASTH
  ○ 49312 INT ASTHMA W ACUTE EXAC OCT00
  ○ 49320 CH OB ASTH W/O STAT ASTH
  ○ 49321 CH OB ASTHMA W STAT ASTH
  ○ 49322 CH OBS ASTH W ACUTE EXAC OCT00
  ○ 49381 EXERCSE IND BRONCHOSPASM OCT03
  ○ 49382 COUGH VARIANT ASTHMA OCT03
  ○ 49390 ASTHMA W/O STATUS ASTHM
  ○ 49391 ASTHMA W/ STATUS ASTHM
  ○ 49392 ASTHMA W ACUTE EXACERBTN OCT00
- Adults must be 18 years or older or any age if identified on a maternal record. Maternal is defined by the major diagnostic category (MDC) of 14 for pregnancy, childbirth, and puerperium. Children are limited to nonmaternal hospital stays aged 2 through 17 years old. Consistent with the AHRQ Quality Indicator for pediatric asthma, hospital stays for patients younger than 2 years were excluded because an asthma diagnosis in younger children may be difficult to distinguish from bronchospasm.
- Hospital stays were excluded for any one of the following reasons:
  ○ Hospital stay was transferred into the hospital from another acute care hospital, skilled nursing facility, intermediate care facility, or other health care facility
  ○ Hospital stay had any ICD-9-CM diagnosis code of cystic fibrosis or anomalies of the respiratory system, defined as one of the following:
    ■ 27700 CYSTIC FIBROS W/O ILEUS
    ■ 27701 CYSTIC FIBROS W ILEUS
    ■ 27702 CYSTIC FIBROS W PUL MAN
    ■ 27703 CYSTIC FIBROSIS W GI MAN
    ■ 27709 CYSTIC FIBROSIS NEC
    ■ 74721 ANOMALIES OF AORTIC ARCH
    ■ 7483 LARYNGOTRACH ANOMALY NEC
    ■ 7484 CONGENITAL CYSTIC LUNG
    ■ 7485 AGENESIS OF LUNG
    ■ 74860 LUNG ANOMALY NOS
    ■ 74861 CONGEN BRONCHIECTASIS
    ■ 74869 LUNG ANOMALY NEC
    ■ 7488 RESPIRATORY ANOMALY NEC
    ■ 7489 RESPIRATORY ANOMALY NOS
    ■ 7503 CONG ESOPH FISTULA/ATRES
    ■ 7593 SITUS INVERSUS
    ■ 7707 PERINATAL CHR RESP DIS

The denominator (population at risk) of the rate is the national population specific to the age group: 2 through 17 years for children and 18 years and older for adults.

### Prevention Quality Indicators

The Prevention Quality Indicators (PQIs; version 4.1), a component of the AHRQ Quality Indicators (QIs), are a set of measures that can be used with hospital inpatient hospital stay data to identify access to and quality of care for ambulatory care-sensitive conditions. These are conditions for which good outpatient care can potentially prevent the need for hospitalization or for which early intervention can prevent complications or more severe disease. PQI rates can also be affected by other factors such as disease prevalence. The PQIs are adjusted for age and sex.

Further information on the AHRQ QIs, including documentation and free software downloads, is available at http://www.qualityindicators.ahrq.gov/. It also includes information on the Pediatric Quality Indicators (PDIs, formerly referred to as PedQIs). The PDIs contain measures of potentially preventable hospitalizations for children for asthma, gastroenteritis, diabetes short-term complications, and perforated appendix. Additional information on how the QI software was applied to the HCUP data for the statistics reported in this Statistical Brief is available in Coffey et al., 2012.^5^

### Types of hospitals included in HCUP

HCUP is based on data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). HCUP data include obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded are long-term care, rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. However, if a patient received long-term care, rehabilitation, or treatment for psychiatric or chemical dependency conditions in a community hospital, the hospital stay record for that stay will be included in the Nationwide Inpatient Sample (NIS) and the SID disparities analysis file.

### Unit of analysis

The unit of analysis is the hospital hospital stay (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the hospital multiple times in one year will be counted each time as a separate “hospital stay” from the hospital.

### Costs and charges

Total hospital charges were converted to costs using HCUP Cost-to-Charge Ratios based on hospital accounting reports from the Centers for Medicare & Medicaid Services (CMS).^6^ Costs will reflect the actual expenses incurred in the production of hospital services, such as wages, supplies, and utility costs; charges represent the amount a hospital billed for the case. For each hospital, a hospital-wide cost-to-charge ratio is used. Hospital charges reflect the amount the hospital billed for the entire hospital stay and do not include professional (physician) fees. For the purposes of this Statistical Brief, costs are reported to the nearest hundred. Costs were deflated to 2010 using the price index for the gross domestic product.^7^

### Patients' race and ethnicity

HCUP uniform coding includes race and ethnicity in one data element (RACE). Because of variability in the collection of race and ethnicity information in the State data provided to HCUP, HCUP maintains a uniform set of categories based on race definitions used in the 1977 Office of Management and Budget (OMB) Directive 15. It uses the combined race-ethnicity format (separate categories for Hispanic and five non-Hispanic racial groups—White, Black, Asian and Pacific Islander, American Indian or Alaska Native, and Other). When a State and its hospitals collect Hispanic ethnicity separately from race, HCUP assigns the data to the combined race and ethnicity categorization and uses Hispanic ethnicity to override any other race category to create uniform coding across States. There is limited reporting of American Indian or Alaska Native (AIAN) in the HCUP data, so statistics for this group were not presented.

This Statistical Brief reports race and ethnicity for the following categories: White non-Hispanic, African American non-Hispanic, Asian or Pacific Islander non-Hispanic, and Hispanic (of any race).

### Median community-level income

Median community-level income is the median household income of the patient's ZIP Code of residence. The cut-offs for the quartile designation are determined yearly using ZIP Code demographic data obtained from the Nielsen Company. The income quartile is set to the lowest income for homeless patients.

### Location of patients' residence

Place of residence is based on a simplified adaptation of the 2003 version of the Urban Influence Codes (UIC). The 12 categories of the UIC are combined into four broader categories that differentiate between large metropolitan areas with a population of 1 million or more residents, small metropolitan areas with a population less than 1 million residents, micropolitan areas, and nonurban residual areas that are neither metropolitan or micropolitan.

### Location of inpatient treatment

Location is based on the region of the treatment hospital and is one of the four regions defined by the U.S. Census Bureau:

- Northeast: Maine, New Hampshire, Vermont, Massachusetts, Rhode Island, Connecticut, New York, New Jersey, and Pennsylvania
- Midwest: Ohio, Indiana, Illinois, Michigan, Wisconsin, Minnesota, Iowa, Missouri, North Dakota, South Dakota, Nebraska, and Kansas
- South: Delaware, Maryland, District of Columbia, Virginia, West Virginia, North Carolina, South Carolina, Georgia, Florida, Kentucky, Tennessee, Alabama, Mississippi, Arkansas, Louisiana, Oklahoma, and Texas
- West: Montana, Idaho, Wyoming, Colorado, New Mexico, Arizona, Utah, Nevada, Washington, Oregon, California, Alaska, and Hawaii

### Payer

Payer is the expected primary payer for the hospital stay. To make coding uniform across all HCUP data sources, payer combines detailed categories into general groups:

- Medicare: includes patients covered by fee-for-service and managed care Medicare
- Medicaid: includes patients covered by fee-for-service and managed care Medicaid
- Private Insurance: includes Blue Cross, commercial carriers, and private health maintenance organizations (HMOs) and preferred provider organizations (PPOs)
- Other: includes Medicare, Worker's Compensation, TRICARE/CHAMPUS, CHAMPVA, Title V, and other government programs. Uninsured: includes an insurance status of “self-pay” and “no charge.”

Hospital stays billed to the State Children's Health Insurance Program (SCHIP) may be classified as Medicaid, Private Insurance, or Other, depending on the structure of the State program. Because most State data do not identify SCHIP patients specifically, it is not possible to present this information separately.

When more than one payer is listed for a hospital stay, the first-listed payer is used.

## For More Information

For more information about HCUP, visit http://www.hcup-us.ahrq.gov/.

For additional HCUP statistics, visit HCUPnet, our interactive query system, at http://hcupnet.ahrq.gov/.

For information on other hospitalizations in the United States, refer to the following HCUP Statistical Briefs located at http://www.hcup-us.ahrq.gov/reports/statbriefs/statbriefs.jsp:

- Statistical Brief #166, Overview of Hospital Stays in the United States, 2011
- Statistical Brief #168, Costs for Hospital Stays in the United States, 2011
- Statistical Brief #162, Most Frequent Conditions in U.S. Hospitals, 2011
- Statistical Brief #165, Most Frequent Procedures Performed in U.S. Hospitals, 2011

For a detailed description of HCUP, more information on the design of the Nationwide Inpatient Sample (NIS), and methods to calculate estimates, please refer to the following publications:

Introduction to the HCUP Nationwide Inpatient Sample, 2011. Online. June 2013. U.S. Agency for Healthcare Research and Quality. https://www.hcup-us.ahrq.gov/db/nation/nis/NIS_Introduction_2011.pdf. Accessed December 4, 2013.

Introduction to the HCUP State Inpatient Databases, 2011. Online. August 2013. U.S. Agency for Healthcare Research and Quality. http://www.hcup-us.ahrq.gov/db/state/siddist/Introduction_to_SID.pdf. Accessed December 4, 2013.

Houchens R, Elixhauser A. Final Report on Calculating Nationwide Inpatient Sample (NIS) Variances, 2001. HCUP Methods Series Report #2003-2. Online. June 2005 (revised June 6, 2005). U.S. Agency for Healthcare Research and Quality. http://www.hcup-us.ahrq.gov/reports/CalculatingNISVariances200106092005.pdf. Accessed December 4, 2013.

Houchens RL, Elixhauser A. Using the HCUP Nationwide Inpatient Sample to Estimate Trends. (Updated for 1988–2004). HCUP Methods Series Report #2006–05. Online. August 18, 2006. U.S. Agency for Healthcare Research and Quality. http://www.hcup-us.ahrq.gov/reports/methods/2006_05_NISTrendsReport_1988-2004.pdf. Accessed December 4, 2013.

1 U.S. Department of Health and Human Services (HHS). (2007). Expert Panel Report 3: Guidelines for the Diagnosis and Management of Asthma. .

2 Akinbami LJ, Moorman JE, Bailey C, Zahran HS, King M, Johnson CA, et al. (2012). Trends in Asthma Prevalence, Health CareUse, and Mortality in the United States, 2001–2010. .

3 Consistent with the AHRQ Quality Indicator for pediatric asthma, hospital stays for patients younger than 2 years were excluded because an asthma diagnosis in younger children may be difficult to distinguish from bronchospasm.

4 U.S. Census Bureau, Population Division. (2011). Intercensal Estimates of the Resident Population by Single Year of Age, Sex, Race,and Hispanic Origin for the United States: April 1, 2000 to July 1, 2010. .

5 Coffey R, Barrett M, Houchens R, Moy E, Andrews R, Coenen N. (2012). Methods Applying AHRQ Quality Indicators to Healthcare Cost and Utilization Project (HCUP) Data for the Eleventh (2013) National Healthcare Quality Report (NHQR) and National Healthcare Disparities Report (NHDR). .

6 (2001-2009). HCUP Cost-to-Charge Ratio Files (CCR). Healthcare Cost and Utilization Project (HCUP). .

7 U.S. Department of Commerce Bureau of Economic Analysis. National Income and Product Accounts Tables. Section 1, Domestic Product and Income. .