# Statistical Brief #167 Emergency Department Visits for Adults with Diabetes, 2010

## Introduction

Diabetes is a critical public health concern in the United States. It is estimated that diabetes affects approximately 25.8 million Americans (8.9 percent of the population), and its incidence continues to rise annually.^1^ Diabetes and its associated complications are significant sources of hospitalization and medical expenditures.^1,2^ Patients with poor blood glucose control and overall diabetes management have significantly greater risk of acute and chronic complications, including cardiovascular, kidney, eye, and nerve diseases.^3^ Emergency department (ED) utilization among patients with diabetes is likely affected by several factors, including lack of primary care, poor adherence to care plans and lifestyle modifications, and presence of complications.

This Statistical Brief presents data from the Healthcare Cost and Utilization Project (HCUP) on ED visits among patients aged 18 years and older with diabetes in 2010. Variations in ED visit rates for patients with diabetes overall, ED visits resulting in treatment and release, and ED visits resulting in subsequent admission to the hospital are presented across patient demographics. The most common diagnoses for ED visits by patients with uncomplicated and complicated diabetes are shown, as is the variation in disposition from the ED by presence of diabetic complications. All differences between estimates noted in the text are statistically significant at the 0.05 level or better.

## Findings

Highlights

■ In 2010, there were approximately 12.1 million diabetes-related ED visits for adults aged 18 years or older (515 per 10,000 U.S. population), or 9.4 percent of all ED visits. Most (57.9 percent) were treat-and-release visits.
■ Diabetes-related ED visit rates were highest for patients aged 65 and older (1,307 per 10,000 U.S. population) compared with 45–64 year olds (584 per 10,000 U.S. population) and 18–44 year olds (183 per 10,000 U.S. population).
■ Diabetes-related ED visit rates were higher among patients from the lowest income communities (526 per 10,000 U.S. population) than from the highest income communities (236 per 10,000 U.S. population).
■ Government insurance (e.g., Medicare and Medicaid) was the primary expected payer for 68.7 percent of diabetes-related ED visits.
■ There were approximately 675,000 diabetes-related ED visits that involved neurological complications, 409,000 ED visits with kidney complications, and 186,000 ED visits with eye complications.
■ Diabetes with complications was the most common (6.4 percent) primary reason for ED visits among adults with diabetes, followed by nonspecific chest pain (5.6 percent) and congestive heart failure (3.3 percent).

### General Findings

In 2010, there were approximately 12.1 million diabetes-related ED visits for adults (defined as having a diabetes diagnosis documented in the patient's discharge record), or about 9.4 percent of all ED visits for adults. This translates to approximately 515 visits per 10,000 U.S. population. Most of these visits were ED treatment and release (57.9 percent); the remaining (42.1 percent) resulted in a hospitalization at the same facility. In comparison, only 15.3 percent of all adult ED visits (for patients with and without diabetes) resulted in a hospitalization.

Characteristics of patients with diabetes who were seen in the ED are presented in Table 1 for all ED visits and by discharge status (i.e., admitted versus treated and released). Adults aged 65 years and older accounted for the largest proportion of diabetes-related ED visits (43.6 percent) and had the highest rate of diabetes-related ED visits (1,307 per 10,000 U.S. population). This older population also represented a greater proportion of diabetes-related ED visits that resulted in hospitalization, whereas treat-and-release ED visits were more common among individuals aged 45–64 years.

Table 1 Diabetes-related^a^ emergency department (ED) visits for patients aged 18 years and older, 2010

Characteristic | All diabetes-related ED visits N=12,128,000 | | Diabetes-related ED visits resulting in hospitalization n=5,110,000 | | Diabetes-related ED visits resulting in treatment and release n=7,018,000
Characteristic | Percent Distribution | Rate (per 10,000) | Percent Distribution | Rate (per 10,000) | Percent Distribution | Rate (per 10,000)
Age^b^
18–44 | 17.0 | 183 | 9.9 | 45 | 22.1 | 137
45-64 | 39.4 | 584 | 34.8 | 218 | 42.8 | 367
≥65 | 43.6 | 1,307 | 55.2 | 698 | 35.1 | 609
Sex^b^
Male | 44.7 | 475 | 47.3 | 212 | 42.8 | 263
Female | 55.3 | 554 | 52.7 | 223 | 57.2 | 332
Community Income
1^st^ Quartile (Low) | 34.9 | 526 | 32.3 | 204 | 36.8 | 321
2^nd^ Quartile | 28.1 | 440 | 26.8 | 176 | 29.1 | 264
3^rd^ Quartile | 21.4 | 330 | 22.7 | 147 | 20.5 | 183
4^th^ Quartile (High) | 15.6 | 236 | 18.2 | 116 | 13.7 | 120
Patient Residence^b^
Large Metro | 47.9 | 348 | 53.5 | 164 | 43.7 | 184
Small Metro | 33.1 | 432 | 30.6 | 168 | 34.8 | 263
Rural | 19.1 | 455 | 15.9 | 160 | 21.4 | 296
Region
Northeast | 16.7 | 366 | 20.0 | 185 | 14.3 | 181
Midwest | 23.2 | 421 | 22.2 | 170 | 23.9 | 251
South | 42.3 | 447 | 40.3 | 179 | 43.8 | 268
West | 17.8 | 299 | 17.5 | 124 | 18.0 | 175

a Diabetes mellitus appears as a diagnosis on the discharge record.

b p<0.05 (Chi-square comparing proportion of admitted versus treat-and-release visits)

Source: Agency for Healthcare Research and Quality (AHRQ). (2010). Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Emergency Department Sample (NEDS).

Females constituted approximately 55 percent of diabetes-related ED visits. Diabetes-related ED visit rates were highest from lower income (526 per 10,000 U.S. population) and rural communities (455 per 10,000). The West had the lowest rate of diabetes-related ED visits (299 per 10,000 U.S. population) compared with the other regions.

The rate of diabetes-related ED visits that resulted in a hospital admission was similar across the metropolitan and rural areas; however, the rate of diabetes-related ED visits that were treated and released was higher for patients from rural areas (296 per 10,000 U.S. population) compared with large (184 per 10,000 U.S. population) and small (263 per 10,000 U.S. population) metropolitan regions.

Figure 1 shows the expected primary payer for diabetes-related ED visits among adults. The payer distribution is different between the two types of ED visits—those resulting in a hospital admission and those being treated and released. Although Medicare was the most common expected primary payer (53.7 percent) for diabetes-related ED visits in general, this payer accounted for a larger proportion of ED visits that resulted in admission (64.7 percent) compared with treat-and-release ED visits (45.7 percent). The opposite pattern was observed for the uninsured, which accounted for only 5.5 percent of diabetes-related ED visits resulting in a hospital admission compared with 12.3 percent of treat-and-release visits. Similarly, private insurers were the primary expected payer for a larger share of the treat-and-release ED visits (25.3 percent) compared to ED visits resulting in a hospital admission (17.3 percent).

Figure 1 Percentage of diabetes-related^a^ a Diabetes mellitus appears as a diagnosis on the discharge record. emergency department (ED) visits for patients aged 18 years and older by expected primary payer, 2010

^b^ p<0.05 (Chi-square comparing proportion of admitted versus treat-and-release visits)

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Emergency Department Sample (NEDS), 2010

This is a stacked bar chart showing the percentage for each expected primary payer by the discharge status of ED visits for patients with diabetes; All Discharges; Medicare, 53.7%; Medicaid, 15%; Private, 21.9%; Uninsured, 9.4%; Admitted to Hospital; Medicare, 64.7%; Medicaid, 12.6%; Private, 17.3%; Uninsured, 5.5%; Treated and Released; Medicare, 45.7%; Medicaid, 16.8%; Private, 25.3%; Uninsured, 12.3%; Diabetes-related ED visit means that diabetes mellitus appears as a diagnosis on the discharge record. p<0.05 (Chi-square comparing proportion of admitted versus treat-and-release visits) for all comparisons; Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Emergency Department Sample (NEDS), 2010

### Types of diabetes-related diagnoses for ED visits among adults

Patients with diabetes often experience short-term (acute) and long-term complications as a result of their condition. Table 2 lists the specific diabetes diagnoses seen in the ED. The majority of diabetes-related ED encounters included no mention of complications associated with diabetes (84.7 percent). Treat-and-release diabetes-related ED encounters were more frequently listed without any diabetes complications (91.7 percent) than visits that resulted in admission (75.1 percent). Among patients who are treated and released, the higher proportion of ED visits with no complications may reflect utilization of EDs for diabetes care and management, initial diagnosis of diabetes in the ED, or incomplete coding. These findings also suggest that ED visits involving diabetes complications are more likely to result in admission to the hospital than those without complications.

Table 2 Types of diabetes-related^a^ diagnoses (all-listed) during emergency department (ED) visits for patients aged 18 years and older

All-listed condition (ICD-9-CM code) | All diabetes-related ED visits | | Diabetes-related ED visits resulting in hospitalization | | Diabetes-related ED visits resulting in treatment and release
All-listed condition (ICD-9-CM code) | Number of visits in thousands | Percent Distribution | Number of visits in thousands | Percent Distribution | Number of visits in thousands | Percent Distribution
All diabetes | 12,128 | 100 | 5,110 | 100 | 7,018 | 100
Diabetes with no mention of complications^b^ | 10,273 | 84.7 | 3,839 | 75.1 | 6,434 | 91.7
Diabetes with complications^b,c^ | 1,855 | 15.3 | 1,271 | 24.9 | 584 | 8.3
Other or unspecified complications | 723 | 6.0 | 371 | 7.3 | 352 | 5.0
Neurological complications | 675 | 5.6 | 521 | 10.2 | 154 | 2.2
Renal complications | 410 | 3.4 | 345 | 6.7 | 65 | 0.9
Acute complications | 223 | 1.8 | 199 | 3.9 | 24 | 0.3
Eye complications | 186 | 1.5 | 148 | 2.9 | 38 | 0.5
Peripheral circulatory complications | 94 | 0.8 | 78 | 1.5 | 16 | 0.2

Abbreviation: ICD-9-CM, International Classification of Diseases, Ninth Revision, Clinical Modification

a Diabetes mellitus appears as a diagnosis on the discharge record.

b p<0.05 (Chi-square comparing proportion of admitted versus treat-and-release visits)

c Not mutually exclusive (i.e., visits may involve more than one complication)

Note: Patients seen in the ED may not have diabetes complications documented in their discharge record if the information on complication status was not collected during the visit. These proportions reflect only those ED visits with complications recorded in the discharge record and do not suggest that patients with no mention of complications have no complications.

Source: Agency for Healthcare Research and Quality (AHRQ). (2010). Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Emergency Department Sample (NEDS).

Diabetes can affect several different body systems. Table 2 also includes information about different types of complications. The most common complication listed was other or unspecified complications (6.0 percent of all diabetes-related ED visits), followed by neurological (5.6 percent) and renal (3.4 percent) complications. Among ED visits that resulted in hospitalization, neurological complications were the most common (10.2 percent of diabetes-related ED visits).

### Most frequent primary reason for ED visits among adults with diabetes

It is likely that patients with diabetes present to the ED for conditions unrelated to diabetes. Table 3 shows the most frequent first-listed conditions for ED visits for adults with diabetes. The first-listed condition may be interpreted as the primary reason for the ED visit. For patients admitted to the hospital, the first-listed condition is the principal diagnosis, which is defined as the chief reason for the hospital stay. The principal diagnosis is determined after evaluation during this stay.

Table 3 Most frequent first-listed conditions for diabetes-related^a^ emergency department (ED) visits for patients aged 18 years and older, 2010

First-listed condition | All diabetes-related ED visits | | | Diabetes-related ED visits resulting in hospitalization | | | Diabetes-related ED visits resulting in treatment and release
First-listed condition | Number of visits in thousands | % | Rank | Number of visits in thousands | % | Rank | Number of visits in thousands | % | Rank
Diabetes with complications | 771 | 6.4 | 1 | 413 | 3.4 | 1 | 358 | 3.0 | 2
Nonspecific chest pain | 681 | 5.6 | 2 | 180 | 1.5 | 5 | 501 | 4.1 | 1
Congestive heart failure | 395 | 3.3 | 3 | 338 | 2.8 | 2 | 58 | 0.5 | -
Abdominal pain | 384 | 3.2 | 4 | 30 | 0.2 | - | 355 | 2.9 | 3
Urinary tract infection | 345 | 2.8 | 5 | 148 | 1.2 | 9 | 197 | 1.6 | 9
Skin and subcutaneous tissue infection | 342 | 2.8 | 6 | 134 | 1.1 | - | 208 | 1.7 | 8
Chronic obstructive pulmonary disease and bronchiectasis | 295 | 2.4 | 7 | 166 | 1.5 | 6 | 129 | 1.1 | -
Superficial injury; contusion | 284 | 2.4 | 8 | 8 | <0.1 | - | 277 | 2.3 | 4
Diabetes without complications | 278 | 2.3 | 9 | 12 | 0.1 | - | 266 | 2.2 | 5
Spondylosis/intervertebral disc disorders; other back problems | 274 | 2.3 | 10 | 33 | 0.3 | - | 241 | 2.0 | 7
Septicemia | 242 | 2.0 | - | 237 | 2.0 | 3 | 5 | <0.1 | -
Pneumonia | 273 | 2.2 | - | 216 | 1.8 | 4 | 57 | 0.5 | -
Acute cerebrovascular disease | 176 | 1.5 | - | 155 | 1.3 | 7 | 22 | 0.2 | -
Acute myocardial infarction | 169 | 1.4 | - | 151 | 1.2 | 8 | 18 | 0.1 | -
Acute and unspecified renal failure | 145 | 1.2 | - | 135 | 1.1 | 10 | 9 | 0.1 | -
Sprains and strains | 266 | 2.2 | - | 4 | <0.1 | - | 262 | 2.2 | 6
Other disconnective tissue disease | 201 | 1.7 | - | 25 | 0.2 | - | 176 | 1.5 | 10

a Diabetes mellitus appears as a diagnosis on the discharge record.

Note: Percent of all ED visits among patients with diabetes

Source: Agency for Healthcare Research and Quality (AHRQ). (2010). Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Emergency Department Sample (NEDS).

Diabetes with complications was the most common first-listed condition for diabetes-related ED visits among adults, accounting for 6.4 percent of diabetes-related ED visits (771,181) in 2010. Nonspecific chest pain was the second most common first-listed condition for diabetes-related ED visits (5.6 percent) and the most common first-listed condition for diabetes-related ED visits resulting in treatment and release. For treat-and-release diabetes-related ED visits, diabetes with complications (3.0 percent), abdominal pain (2.9 percent), and superficial injury/contusion (2.3 percent) were also top-ranking first-listed conditions. For admitted patients, other chronic conditions—particularly circulatory and respiratory-related conditions—accounted for the most frequent first-listed conditions. Notably, the top 10 first-listed conditions for all ED visits account for one-third of the ED visits.

## Data Source

The estimates in this Statistical Brief are based upon data from the Healthcare Cost and Utilization Project (HCUP) 2010 Nationwide Emergency Department Sample (NEDS). Supplemental sources included population denominator data for use with HCUP databases.^4^

## Definitions

### Diagnoses, ICD-9-CM, and Clinical Classifications Software (CCS)

ICD-9-CM is the International Classification of Diseases, Ninth Revision, Clinical Modification, which assigns numeric codes to diagnoses. There are approximately 14,000 ICD-9-CM diagnosis codes.

The following ICD-9-CM codes were used to identify patients with diabetes. “All-listed” refers to the occurrence of one or more of these codes in any diagnosis field, and “first-listed” refers to the occurrence of one or more of these codes in the first diagnosis field.

Description | ICD-9-CM Code
Uncontrolled diabetes without mention of complications | 250.0x
Diabetes with acute complications | 250.1x-250.3x
Diabetes with renal complications | 250.4x
Diabetes with eye complications | 250.5x
Diabetes with neurological complications | 250.6x
Diabetes with peripheral circulatory complications | 250.7x
Diabetes with other or unspecified complications | 250.8x-250.9x

CCS categorizes ICD-9-CM diagnoses into a manageable number of clinically meaningful categories.^5^ This “clinical grouper” makes it easier to quickly understand patterns of diagnoses. CCS categories identified as “Other” typically are not reported; these categories include miscellaneous, otherwise unclassifiable diagnoses that may be difficult to interpret as a group. CCS categories were used in this Statistical Brief to identify the most common first-listed diagnoses for patients with diabetes. The corresponding CCS codes and descriptions are shown below.

CCS Code | CCS Description
2 | Septicemia
49 | Diabetes without complications
50 | Diabetes with complications
100 | Acute myocardial infarction
102 | Nonspecific chest pain
108 | Congestive heart failure
109 | Acute cerebrovascular disease
122 | Pneumonia
127 | Chronic obstructive pulmonary disease and bronchiectasis
157 | Acute and unspecified renal failure
159 | Urinary tract infection
197 | Skin and subcutaneous tissue infection
205 | Spondylosis/intervertebral disc disorders; other back problems
211 | Other disconnective tissue disease
232 | Sprains and strains
239 | Superficial injury; contusion
251 | Abdominal pain

### Types of hospitals included in HCUP

HCUP is based on data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). HCUP data include obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded are long-term care, rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. Community hospitals included in the Nationwide Emergency Department Sample (NEDS) have hospital-based emergency departments and no more than 90 percent of their ED visits resulting in admission.

### Unit of analysis

The unit of analysis is the emergency department (ED) encounter, not a person or patient. This means that a person who is seen in the ED multiple times in one year will be counted each time as a separate “encounter” in the ED.

### Location of patients' residence

Place of residence is based on the urban-rural classification scheme for U.S. counties developed by the National Center for Health Statistics (NCHS). For this Statistical Brief, we collapsed the NCHS categories into either large metropolitan, small metropolitan, or rural according to the following:

- Large Metropolitan: includes metropolitan areas and counties of metropolitan areas with 1 million or more residents
- Small Metropolitan: includes areas with 50,000 to 999,999 residents
- Rural: includes nonmetropolitan counties (i.e., counties with no town greater than 50,000 residents).

### Median community-level income

Median community-level income is the median household income of the patient's ZIP Code of residence. The cut-offs for the quartile designation are determined using ZIP Code demographic data obtained from the Nielsen Company. The income quartile is missing for homeless and foreign patients.

### Payer

Payer is the expected primary payer for the ED visit or hospital discharge. To make coding uniform across all HCUP data sources, payer combines detailed categories into general groups:

– Medicare: includes patients covered by fee-for-service and managed care Medicare
– Medicaid: includes patients covered by fee-for-service and managed care Medicaid
– Private Insurance: includes Blue Cross, commercial carriers, and private health maintenance organizations (HMOs) and preferred provider organizations (PPOs)
– Other: Includes Worker's Compensation, TRICARE/CHAMPUS, CHAMPVA, Title V, and other government programs
– Uninsured: includes an insurance status of “self-pay” and “no charge.”

Hospital stays billed to the State Children's Health Insurance Program (SCHIP) may be classified as Medicaid, Private Insurance, or Other, depending on the structure of the State program. Because most State data do not identify SCHIP patients specifically, it is not possible to present this information separately. When more than one payer is listed for a ED visit or hospital discharge, the first-listed payer is used. Other expected payers were not reported in this Statistical Brief.

### Region

Region is one of the four regions defined by the U.S. Census Bureau—

– Northeast: Maine, New Hampshire, Vermont, Massachusetts, Rhode Island, Connecticut, New York, New Jersey, and Pennsylvania
– Midwest: Ohio, Indiana, Illinois, Michigan, Wisconsin, Minnesota, Iowa, Missouri, North Dakota, South Dakota, Nebraska, and Kansas
– South: Delaware, Maryland, District of Columbia, Virginia, West Virginia, North Carolina, South Carolina, Georgia, Florida, Kentucky, Tennessee, Alabama, Mississippi, Arkansas, Louisiana, Oklahoma, and Texas
– West: Montana, Idaho, Wyoming, Colorado, New Mexico, Arizona, Utah, Nevada, Washington, Oregon, California, Alaska, and Hawaii

## For More Information

For more information about HCUP, visit http://www.hcup-us.ahrq.gov/.

For additional HCUP statistics, visit HCUPnet, our interactive query system, at http://hcupnet.ahrq.gov/.

For information about other hospitalizations in the United States, refer to the following HCUP Statistical Briefs located at http://www.hcup-us.ahrq.gov/reports/statbriefs/statbriefs.jsp:

- Statistical Brief #144, Overview of Hospital Stays in the United States, 2010
- Statistical Brief #146, Costs for Hospital Stays in the United States, 2010
- Statistical Brief #148, Most Frequent Conditions in U.S. Hospitals, 2010
- Statistical Brief #149, Most Frequent Procedures Performed in U.S. Hospitals, 2010

For a detailed description of HCUP, more information on the design of the Nationwide Emergency Department Sample (NEDS), and methods to calculate estimates, please refer to the following publications:

Introduction to the HCUP Nationwide Emergency Department Sample, 2010. Online. November 2012. U.S. Agency for Healthcare Research and Quality. http://hcup-us.ahrq.gov/db/nation/neds/NEDS2010Introductionv3.pdf. Accessed October 9, 2013.

Introduction to the HCUP State Emergency Department Databases. Online. December 2012. U.S. Agency for Healthcare Research and Quality. http://hcup-us.ahrq.gov/db/state/sedddist/Introduction_to_SEDD.pdf. Accessed October 9, 2013.

1 Centers for Disease Control and Prevention. (2011). National Diabetes Fact Sheet: National Estimates and General Information on Diabetes and Prediabetes in the United States, 2011. .

2 Fraze TK, Jiang HJ, Burgess J. (2010). Hospital Stays for Patients with Diabetes, 2008. HCUP Statistical Brief #93. .

3 Diabetes Control and Complications Trial Research Group. (1993). The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. New England Journal of Medicine. .

4 Barrett M, Lopez-Gonzalez L, Coffey R, Levit K. (2013). Population Denominator Data for use with the HCUP Databases (Updated with 2012 Population data). HCUP Methods Series Report #2013-01. .

5 HCUP Clinical Classifications Software (CCS). Healthcare Cost and Utilization Project (HCUP). .