# Statistical Brief #163 Hospital Stays for Newborns, 2011

## Introduction

Almost 99 percent of births in the United States take place in hospitals.^1^ Live births account for about 10 percent of all hospital discharges, and birth is the most frequent reason for hospital stays. Tracking the numbers and clinical conditions of newborns as well as demographic characteristics such as their sex, health insurance coverage, and geographic region can provide insight into trends and variations in their health. These characteristics can also indicate areas in which to target interventions to improve birth outcomes.

Although a majority of newborns are healthy babies, some are born prematurely and/or with low birth weight. Premature birth is a birth that takes place before 37 weeks of gestation have passed, and low birth weight refers to weight at birth of less than 2500 grams. Premature babies have higher rates of mortality and a higher likelihood of adverse health outcomes, including developmental delays. Premature birth is also one of the leading causes of low birth weight in newborns. Babies with low birth weight are more likely than babies with normal weight to have complications such as respiratory distress syndrome—a disorder that causes babies to need extra oxygen or help for breathing.^2^ Preterm births also impose a heavy financial burden on the U.S. health care system, costing more than $26 billion annually.^3^

This Statistical Brief presents data from the Healthcare Cost and Utilization Project (HCUP) on characteristics of live hospital births (i.e., newborns excluding stillbirths) in the United States in 2011. Demographic characteristics of newborns in 2008 are compared to data from 2011. Hospital utilization and costs are compared for selected birth outcomes and clinical conditions for 2011. All differences between estimates noted in the text are statistically significant at the .001 or better probability level.

## Findings

Highlights

■ In 2011 there were 3,800,000 live births in hospitals, which is 436,000 less or a decrease of 10.3 percent compared to 2008.
■ More than half (51 percent) of live hospital births were male in 2008 and 2011.
■ In 2011, newborns weighing less than 1500 grams had the longest average hospital stays (42.6 days) and incurred the highest average hospital costs ($76,700).
■ Average hospital costs were significantly higher for newborns with conditions such as preterm birth ($21,500), low birth weight ($27,200), and/or respiratory distress syndrome ($54,900) compared to all newborns ($3,200).
■ The percentage of hospital stays for newborns covered by Medicaid increased from 40.5 in 2008 to 44.7 in 2011.
■ Among all hospital newborns, those covered by Medicaid had higher incidence rates for preterm (8.9 percent) and low birth weight (6.8 percent) compared to those covered by private payers (8.1 percent and 5.5 percent, respectively).

### Demographic characteristics of all live hospital births, 2008 and 2011

In 2011, there were 3,800,000 live births in hospitals, which was 436,000 less or a decrease of 10.3 percent compared to 2008. Table 1 shows that for both data years, newborns were more likely to be covered by Medicaid or private insurance, live in a large metropolitan area with more than 1 million residents, and live in communities with lower median income. In 2008 and 2011, more than half (51.3 and 51.1 percent, respectively) of newborns were male. In 2008, Medicaid covered 40.5 percent of hospital stays for newborns, which increased to 44.7 percent in 2011.

Table 1 Demographic characteristics of live hospital births, 2008 and 2011

Characteristics | 2008 | | 2011
Characteristics | Count (thousands) | Percent | Count (thousands) | Percent
Overall | 4,236 | 100 | 3,800 | 100
Sex
Male | 2,171 | 51.3 | 1,943 | 51.1
Female | 2,064 | 48.7 | 1,856 | 48.9
Insurance
Medicaid | 1,715 | 40.5 | 1,694 | 44.7
Private | 2,161 | 51.1 | 1,848 | 48.7
Uninsured | 239 | 5.6 | 136 | 3.6
Other | 117 | 2.8 | 115 | 3.0
Urbanicity
Large metropolitan areas with at least 1M residents | 2,448 | 57.9 | 2,184 | 57.6
Small metropolitan areas with less than 1M residents | 1,156 | 27.3 | 1,042 | 27.5
Micropolitan areas | 392 | 9.3 | 349 | 9.2
Not metropolitan or micropolitan | 235 | 5.6 | 219 | 5.8
Income at ZIP Code, U.S. $
1–40,999 | 1,099 | 26.3 | 984 | 26.3
41,000–50,999 | 1,114 | 26.6 | 909 | 24.3
51,000–66,999 | 1,002 | 24.0 | 1,013 | 27.0
67,000 and above | 969 | 23.2 | 840 | 22.4

Source: Agency for Healthcare Research and Quality (AHRQ), Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS)

The number of newborns per 1,000 women aged 15 to 50 years was the highest in the West (54.2 per 1,000 women) and the lowest in the Northeast (47.4 per 1,000 women) (Figure 1).

Figure 1 Number of live hospital births per 1,000 women aged 15–50 years by region, 2011

Source: The number of births is based on the Agency for Healthcare Research and Quality (AHRQ), Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS). The population count for women aged 15 to 50 years is based on the U.S. Census Bureau, American Community Survey.

This figure is a bar graph showing the rate per 1,000 women by region. Northeast, 47.4, Midwest, 49.4, South, 49.3, West, 54.2. Source: The number of births is based on the Agency for Healthcare Research and Quality, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample. The population count for women aged 15 to 50 years is based on the U.S. Census Bureau, American Community Survey.

### Health insurance for hospital newborns by region, 2011

Figure 2 shows the type of health insurance for hospital newborns by region in 2011. Medicaid had the largest share in the South, accounting for nearly half of the hospital stays for newborns. In the Northeast, Midwest, and West, private insurance covered half or more of newborn hospital stays. Across all regions, the share covered by other insurance types or the uninsured was less than 10 percent.

Figure 2 Distribution of major insurance types for hospital newborns by region, 2011

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organizations, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS)

This is a bar graph showing the percentage of newborn hospital stays by the payer and region. Northeast: Medicaid, 38; private, 58; uninsured, 3 ; other, 1. Midwest: Medicaid, 42; private, 51; uninsured, 4; other, 3. South: Medicaid, 49; private, 42; uninsured, 5; other, 4. West: Medicaid, 45; private, 50; uninsured, 2; other, 3. Source: Agency for Healthcare Research and Quality, Center for Delivery, Organizations, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample.

### Hospital costs and length of stay by selected clinical outcomes, 2011

Table 2 provides information on average length of stay and costs for all newborns and for newborns with complications such as prematurity, low birth weight, and respiratory distress syndrome. On average, newborns stayed in the hospital for 3.4 days and incurred average hospital costs of $3,200. Newborns that were preterm or had low birth weight or respiratory distress syndrome had higher average lengths of stay and higher average costs compared to all newborns. Preterm newborns had hospital stays averaging 14.3 days with mean costs of $21,500. Among newborns with low birth weight, those who weighed less than 1500 grams had hospital stays averaging 42.6 days with mean costs of $76,700 compared to 10.9 days and $14,000 for those weighing 1500 grams or more. Newborns with respiratory distress syndrome had hospital stays averaging 31.3 days and average costs of $55,000. Newborns that died after birth had hospital stays averaging 7.4 days and average costs of $28,600.

Table 2 Average length of newborn hospital stays and hospital costs by selected clinical outcomes, 2011

Outcomes | Count | Percent | Average length of stay (days) | Average hospital costs (U.S. $) | Aggregated hospital costs (millions U.S. $)
All live hospital births | 3,800,000 | 100.0 | 3.4 | 3,200 | 12,200
Preterm | 321,900 | 8.5 | 14.3 | 21,500 | 6,900
Low birth weight | 231,900 | 6.1 | 17.7 | 27,200 | 6,200
Weight less than 1500g | 49,300 | 1.3 | 42.6 | 76,700 | 3,700
Weight greater than or equal to 1500g | 181,500 | 4.8 | 10.9 | 14,000 | 2,500
Respiratory distress syndrome | 75,100 | 2.0 | 31.3 | 55,000 | 4,100
Died after birth | 10,900 | 0.3 | 7.4 | 28,600 | 300

Note: The categories for preterm, low birth weight, and respiratory distress syndrome overlap and are not mutually exclusive.

Source: Agency for Healthcare Research and Quality (AHRQ), Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS)

### Incidence of selected birth outcomes and average hospital costs by insurance category, 2011

Figures 3 and 4 show the incidence of select outcomes among live hospital births and the average hospital costs associated with these birth outcomes by insurance category. Hospital newborns covered by Medicaid had higher incidence rates of preterm (8.9 percent) and low birth weight (6.8 percent), compared with those covered by private insurance (8.1 percent and 5.5 percent, respectively). Mortality rate after birth was also higher for newborns covered by Medicaid than for the privately insured (0.3 versus 0.2 percent). However, the incidence rate of respiratory distress syndrome was similar for newborns covered by these two insurance categories (2.1 percent for Medicaid and 1.9 percent for private insurance).

Figure 3 Incidence of select conditions among live hospital births by insurance category, 2011

Abbreviation: RDS, respiratory distress syndrome

Note: The categories for preterm, low birth weight, and respiratory distress syndrome overlap and are not mutually exclusive.

Source: Agency for Healthcare Research and Quality (AHRQ), Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS)

This is a bar graph, showing the incidence rate (percentage) and the payer for selected birth outcomes. Preterm: Medicaid, 8.9; private, 8.1. Low Birth Weight: Medicaid, 6.8; private, 5.5. Respiratory Distress Syndrome (RDS): Medicaid, 2.1; private, 1.9. Died After Birth: Medicaid, 0.3; private, 0.2. Source: Agency for Healthcare Research and Quality, Center for Delivery, Organizations, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample. Note: The categories for preterm, low birth weight, and respiratory distress syndrome overlap and are not mutually exclusive.

Figure 4 Average hospital costs for select conditions among live hospital births by insurance category, 2011

Abbreviation: RDS, respiratory distress syndrome

Note: The categories for preterm, low birth weight, and respiratory distress syndrome overlap and are not mutually exclusive.

Source: Agency for Healthcare Research and Quality (AHRQ), Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS)

This is a bar graph, showing the average hospital costs in dollars and the payer for selected birth outcomes. Preterm: Medicaid, 22,500; private, 21,600. Low Birth Weight: Medicaid, 27,300; private, 28,400. Respiratory Distress Syndrome (RDS): Medicaid, 57,700; private, 54,600. Died After Birth: Medicaid, 31,300; private, 31,700. Source: Agency for Healthcare Research and Quality, Center for Delivery, Organizations, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample. Note: The categories for preterm, low birth weight, and respiratory distress syndrome overlap and are not mutually exclusive.

Average hospital costs were similar among Medicaid and private payers for newborns with preterm, low birth weight, and respiratory distress syndrome, and for those who died after birth. Average costs for Medicaid ranged from $22,500 (preterm) to $57,700 (respiratory distress syndrome) and average costs for private payers ranged from $21,600 (preterm) to $54,600 (respiratory distress syndrome).

## Data Source

The estimates in this Statistical Brief are based on data from the Healthcare Cost and Utilization Project (HCUP) 2008 and 2011 National Inpatient Sample (NIS).

Many hypothesis tests were conducted for this Statistical Brief. Thus, to decrease the number of false-positive results, we reduced the significance level to .001 for individual tests.

## Definitions

### Diagnoses, ICD-9-CM, and Clinical Classifications Software (CCS)

The principal diagnosis is that condition established after study to be chiefly responsible for the patient's admission to the hospital. Secondary diagnoses are concomitant conditions that coexist at the time of admission or that develop during the stay.

ICD-9-CM is the International Classification of Diseases, Ninth Revision, Clinical Modification, which assigns numeric codes to diagnoses. There are approximately 14,000 ICD-9-CM diagnosis codes.

### Case definition

The ICD-9-CM codes defining all newborns, stillbirths, preterm birth, low birth weight, and respiratory distress syndrome include diagnosis codes in the following range.

– All newborns: V30–V39
– Stillbirths: V32, V35, or V36
– Preterm birth: 7650x, 7651x, 765.20–765.28
– Low birth weight: 7640x, 7641x, 7642x, 7649x, 7650x, and 7651x, with 5th digit from 0 to 8 OR V2130, V2131, V2132, V2133, V2134, V2135
– Respiratory distress syndrome: 769

Note that the categories for preterm, low birth weight, and respiratory distress syndrome overlap and are not mutually exclusive. The selection procedure involved two steps. First, all hospital live births (excluding still births) were identified. Second, preterm, low birth weight, and newborns with respiratory distress syndrome were flagged without hierarchical assignment.

### Types of hospitals included in HCUP

HCUP is based on data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). HCUP data include obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded are long-term care, rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. However, if a patient received long-term care, rehabilitation, or treatment for psychiatric or chemical dependency conditions in a community hospital, the discharge record for that stay will be included in the Nationwide Inpatient Sample (NIS).

### Unit of analysis

The unit of analysis is the hospital discharge (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the hospital multiple times in one year will be counted each time as a separate “discharge” from the hospital.

### Costs and charges

Total hospital charges were converted to costs using HCUP Cost-to-Charge Ratios based on hospital accounting reports from the Centers for Medicare & Medicaid Services (CMS).^4^ Costs will reflect the actual expenses incurred in the production of hospital services, such as wages, supplies, and utility costs; charges represent the amount a hospital billed for the case. For each hospital, a hospital-wide cost-to-charge ratio is used. Hospital charges reflect the amount the hospital billed for the entire hospital stay and do not include professional (physician) fees. For the purposes of this Statistical Brief, average costs are reported to the nearest hundred.

### Location of patients' residence

Place of residence is based on the urban-rural classification scheme for U.S. counties developed by the National Center for Health Statistics (NCHS):

– Large Central Metropolitan: Central counties of metropolitan areas with 1 million or more residents
– Large Fringe Metropolitan: Fringe counties of counties of metropolitan areas with 1 million or more residents
– Medium Metropolitan: Counties in metropolitan areas of 250,000–999,999 residents
– Small Metropolitan: Counties in metropolitan areas of 50,000–249,999 residents
– Micropolitan: Nonmetropolitan counties, i.e., a nonmetropolitan county with an area of 10,000 or more residents
– Noncore: Nonmetropolitan and nonmicropolitan counties.

### Median community-level income

Median community-level income is the median household income of the patient's ZIP Code of residence. The cut-offs for the quartile designation are determined using ZIP Code demographic data obtained from the Nielsen Company. The income quartile is missing for homeless and foreign patients.

### Insurance

Insurance coverage is defined by the expected primary payer for the hospital stay. To make coding uniform across all HCUP data sources, detailed payers were combined into general categories:

– Medicare: includes patients covered by fee-for-service and managed care Medicare
– Medicaid: includes patients covered by fee-for-service and managed care Medicaid.
– Private Insurance: includes Blue Cross, commercial carriers, and private health maintenance organizations (HMOs) and preferred provider organizations (PPOs)
– Other: includes Worker's Compensation, TRICARE/CHAMPUS, CHAMPVA, Title V, and other government programs
– Uninsured: includes an insurance status of “self-pay” and “no charge.”

Encounters billed to the State Children's Health Insurance Program (SCHIP) may be classified as Medicaid, Private Insurance, or Other, depending on the structure of the State program. Because most State data do not identify SCHIP patients specifically, it is not possible to present this information separately.

When more than one payer is listed for a hospital discharge, the first-listed payer is used.

### Region

Region is one of the four regions defined by the U.S. Census Bureau:

– Northeast: Maine, New Hampshire, Vermont, Massachusetts, Rhode Island, Connecticut, New York, New Jersey, and Pennsylvania
– Midwest: Ohio, Indiana, Illinois, Michigan, Wisconsin, Minnesota, Iowa, Missouri, North Dakota, South Dakota, Nebraska, and Kansas
– South: Delaware, Maryland, District of Columbia, Virginia, West Virginia, North Carolina, South Carolina, Georgia, Florida, Kentucky, Tennessee, Alabama, Mississippi, Arkansas, Louisiana, Oklahoma, and Texas
– West: Montana, Idaho, Wyoming, Colorado, New Mexico, Arizona, Utah, Nevada, Washington, Oregon, California, Alaska, and Hawaii

## For More Information

For more information about HCUP, visit http://www.hcup-us.ahrq.gov/.

For additional HCUP statistics, visit HCUPnet, our interactive query system, at http://hcupnet.ahrq.gov/.

For information on other hospitalizations in the United States, download HCUP Facts and Figures: Statistics on Hospital-Based Care in the United States in 2009, located at http://www.hcup-us.ahrq.gov/reports.jsp.

For a detailed description of HCUP, more information on the design of the NIS, and methods to calculate estimates, please refer to the following publications:

Introduction to the HCUP Nationwide Inpatient Sample, 2009. Online. May 2011. U.S. Agency for Healthcare Research and Quality. http://hcup-us.ahrq.gov/db/nation/nis/NIS_2009_INTRODUCTION.pdf. Accessed August 16, 2013.

Houchens R, Elixhauser A. Final Report on Calculating Nationwide Inpatient Sample (NIS) Variances, 2001. HCUP Methods Series Report #2003-2. Online. June 2005 (revised June 6, 2005). U.S. Agency for Healthcare Research and Quality. http://www.hcup-us.ahrq.gov/reports/CalculatingNISVariances200106092005.pdf. Accessed August 16, 2013.

Houchens RL, Elixhauser A. Using the HCUP Nationwide Inpatient Sample to Estimate Trends. (Updated for 1988–2004). HCUP Methods Series Report #2006–05. Online. August 18, 2006. U.S. Agency for Healthcare Research and Quality. http://www.hcup-us.ahrq.gov/reports/methods/2006_05_NISTrendsReport_1988-2004.pdf. Accessed August 16, 2013.

1 Martin JA, Hamilton BE, Ventura SJ, Osterman MJ, Wilson EC, Mathews TJ. (2012). Births: Final data for 2010. National Vital Statistics Reports. .

2 March of Dimes. (2013). Low Birthweight. .

3 Centers for Disease Control and Prevention. (2013). Preterm Birth. .

4 (2001–2009). HCUP Cost-to-Charge Ratio Files (CCR). Healthcare Cost and Utilization Project (HCUP). .