# Statistical Brief #162 Most Frequent Conditions in U.S. Hospitals, 2011

## Introduction

A patient can be admitted to the hospital with more than one medical condition. The principal diagnosis is the condition primarily responsible for the patient's admission. Hospitals need to know the most common principal diagnoses so that they can appropriately plan for and provide the resources required to treat patients with these more frequent conditions.

The Agency for Healthcare Research and Quality has provided an annual overview of national statistics on inpatient hospital stays, including principal diagnoses, since 2005. The statistics are based on data from the Healthcare Cost and Utilization Project (HCUP). The results from 2005 through 2009 are presented in a series of HCUP Facts and Figures reports.^1^

The analysis of 2010 data on principal diagnoses was published in HCUP Statistical Brief #148, titled Most Frequent Conditions in U.S. Hospitals, 2010.^2^ The present Statistical Brief analyzes 2011 data on the most common principal diagnoses for all hospital stays in the United States and covers stays by age and primary payer. The change in the number of stays and the rates of hospitalization in the population between 1997 and 2011 are also presented for the most common conditions. All differences between estimates noted in the text are statistically significant at the .001 level or better.

## Findings

Highlights

■ Liveborn (newborn infant) remained the most common reason for hospitalization in 2011 (10 percent of all stays).
■ Between 1997 and 2011, the hospitalization rate for acute renal failure had the steepest growth across all conditions, increasing 346 percent.
■ The hospitalization rate for septicemia increased rapidly among adults aged 45 years and older: 180 percent for adults aged 45–64 years, 104 percent for adults aged 65–84 years, and 74 percent for adults aged 85 years and older.
■ Congestive heart failure was the most common reason for hospitalization for adults aged 85 years and older in 2011 and the second most common reason for adults aged 65–84 years. However, for both age groups the hospitalization rate decreased between 1997 and 2011 (18 percent and 31 percent, respectively).
■ A diagnosis of mood disorders was the most common reason for hospitalization among children aged 1–17 years.
■ For adults aged 18–44 years, the hospitalization rate for delivery following a previous Cesarean section was 81 percent higher in 2011 than it was in 1997.
■ Asthma was the third most common reason for hospitalization among children aged 1–17 years in 2011, but the rate of hospitalization fell by nearly half since 1997 (from 24 to 13 stays per 10,000 population).

### Most frequent principal diagnoses during hospital stays, 2011

Table 1 shows that there were 38.6 million hospital stays in 2011 in the United States (1,239 stays per 10,000 population). The 10 most frequent principal diagnoses listed in Table 1 accounted for 30 percent of all hospital stays.

Table 1 Number of hospital stays and stays per 10,000 population by the most frequent principal diagnoses, 2011

Principal CCS diagnosis | Number of stays in thousands | Stays per 10,000 population
All stays | 38,591 | 1,239
Liveborn (newborn infant) | 3,818 | 123
Pneumonia (except that caused by tuberculosis and sexually transmitted diseases) | 1,114 | 36
Septicemia (except in labor) | 1,094 | 35
Congestive heart failure, nonhypertensive | 970 | 31
Osteoarthritis | 964 | 31
Mood disorders | 896 | 29
Cardiac dysrhythmias | 795 | 26
Chronic obstructive pulmonary disease and bronchiectasis | 729 | 23
Complication of device, implant, or graft | 699 | 22
Spondylosis, intervertebral disc disorders, other back problems | 667 | 21

Abbreviation: CCS, Clinical Classifications Software

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 2011

The most common reason for hospitalization was liveborn (newborn infant), which accounted for 3.8 million stays in 2011 (10 percent of all stays).

Respiratory and circulatory conditions were among the 10 most common principal diagnoses in 2011. Two respiratory conditions—pneumonia and chronic obstructive pulmonary disease (COPD)—together accounted for 5 percent of all hospitalizations. Two circulatory conditions—congestive heart failure (CHF) and cardiac dysrhythmias—together accounted for another 5 percent of stays.

Osteoarthritis and spondylosis, both musculoskeletal conditions, were the fifth and tenth most frequent principal diagnoses, respectively, in 2011. A diagnosis of mood disorders, the only mental health diagnosis on the list, was the sixth most common condition and accounted for 896,000 stays in 2011.

### Principal diagnoses with the most rapid growth, 1997–2011

Although the overall hospitalization rate in 2011 changed little from what it was in 1997, the rate increased sharply for some principal diagnoses (Table 2). Among the most common conditions for hospitalization, stays for acute renal failure experienced the most growth between 1997 and 2011, with the hospitalization rate increasing 346 percent (from 4 to 16 stays per 10,000 population). The hospitalization rate for five conditions—prolonged pregnancy, septicemia, pulmonary heart disease, osteoarthritis, and anemia—at least doubled during this period.

Table 2 Number of hospital stays, stays per 10,000 population, and percentage change in rate, by selected principal diagnoses, 1997 and 2011

Principal CCS diagnosis | Number of stays in thousands | | Stays per 10,000 population | | Change in rate, %
Principal CCS diagnosis | 1997 | 2011 | 1997 | 2011 | 1997–2011
All stays | 34,679 | 38,591 | 1,272 | 1,239 | −3
Diagnoses with most rapid growth in stays per population^*^
Acute and unspecified renal failure | 98 | 498 | 4 | 16 | 346
Prolonged pregnancy | 104 | 282 | 4 | 9 | 138
Septicemia (except in labor) | 413 | 1,094 | 15 | 35 | 132
Pulmonary heart disease | 80 | 200 | 3 | 6 | 118
Osteoarthritis | 418 | 964 | 15 | 31 | 102
Anemia | 100 | 229 | 4 | 7 | 100
Respiratory failure, insufficiency, arrest (adult) | 199 | 404 | 7 | 13 | 78
Skin and subcutaneous tissue infections | 330 | 652 | 12 | 21 | 73
Previous Cesarean Section | 271 | 502 | 10 | 16 | 62
Intestinal infection | 136 | 248 | 5 | 8 | 59

Abbreviation: CCS, Clinical Classifications Software

* Includes only conditions with at least 100,000 stays in either 1997 or 2011.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 1997 and 2011

### Most frequent principal diagnoses by age for hospital stays, 2011

Table 3 displays the five most frequent reasons for hospitalization by age group in 2011, as well as the change in the hospitalization rate for these diagnoses since 1997. The overall hospitalization rate increased with age with the exception of infants, whose high hospitalization rate (10,665 stays per 10,000 population) was driven largely by newborn births; these births accounted for 89 percent of stays for children who were younger than 1 year.

Table 3 Number of hospital stays, stays per 10,000 population, and percentage change in rate, by most frequent principal diagnoses and patient age, 1997 and 2011

Principal CCS diagnosis | Number of stays in thousands | | Stays per 10,000 population | | Change in rate, %
Principal CCS diagnosis | 1997 | 2011 | 1997 | 2011 | 1997–2011
All ages, total stays | 34,679 | 38,591 | 1,272 | 1,239 | −3
< 1 year, total stays | 4,426 | 4,262 | 11,799 | 10,665 | −10
Liveborn (newborn infant) | 3,776 | 3,815 | 10,067 | 9,545 | −5
Acute bronchitis | 108 | 74 | 288 | 184 | −36
Hemolytic jaundice and perinatal jaundice | 33 | 35 | 88 | 89 | 1
Pneumonia (except that caused by tuberculosis and sexually transmitted diseases) | 55 | 25 | 148 | 61 | −59
Short gestation, low birth weight, and fetal growth retardation | 22 | 20 | 59 | 50 | −16
1–17 years, total stays | 1,821 | 1,402 | 271 | 201 | −26
Mood disorders | 64 | 112 | 10 | 16 | 68
Pneumonia (except that caused by tuberculosis and sexually transmitted diseases) | 135 | 97 | 20 | 14 | −31
Asthma | 159 | 93 | 24 | 13 | −44
Appendicitis and other appendiceal conditions | 65 | 66 | 10 | 9 | −3
Epilepsy, convulsions | 46 | 49 | 7 | 7 | 1
18–44 years, total stays | 9,444 | 9,385 | 850 | 827 | −3
Trauma to perineum and vulva | 676 | 642 | 61 | 57 | −7
Previous Cesarean section | 270 | 500 | 24 | 44 | 81
Mood disorders | 335 | 430 | 30 | 38 | 26
Prolonged pregnancy | 99 | 274 | 9 | 24 | 171
Hypertension complicating pregnancy, childbirth, and the puerperium | 172 | 239 | 15 | 21 | 36
45–64 years, total stays | 6,496 | 9,695 | 1,154 | 1,171 | 1
Osteoarthritis | 105 | 402 | 19 | 49 | 160
Septicemia (except in labor) | 73 | 302 | 13 | 36 | 180
Spondylosis, intervertebral disc disorders, other back problems | 190 | 297 | 34 | 36 | 6
Mood disorders | 136 | 271 | 24 | 33 | 35
Complication of device, implant, or graft | 143 | 268 | 25 | 32 | 28
65–84 years, total stays | 10,121 | 10,533 | 3,319 | 2,954 | −11
Osteoarthritis | 281 | 507 | 92 | 142 | 54
Congestive heart failure, nonhypertensive | 581 | 468 | 191 | 131 | −31
Septicemia (except in labor) | 195 | 466 | 64 | 131 | 104
Pneumonia (except that caused by tuberculosis and sexually transmitted diseases) | 514 | 432 | 168 | 121 | −28
Cardiac dysrhythmias | 333 | 406 | 109 | 114 | 4
85+ years, total stays | 2,362 | 3,283 | 6,047 | 5,723 | −5
Congestive heart failure, nonhypertensive | 202 | 245 | 517 | 426 | −18
Pneumonia (except that caused by tuberculosis and sexually transmitted diseases) | 197 | 197 | 504 | 343 | −32
Septicemia (except in labor) | 76 | 195 | 196 | 340 | 74
Urinary tract infections | 75 | 151 | 191 | 264 | 38
Cardiac dysrhythmias | 70 | 131 | 179 | 229 | 28

Abbreviation: CCS, Clinical Classifications Software

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 1997 and 2011

Among children aged 1–17 years, the diagnosis of mood disorders was the most common reason for hospitalization in 2011 (16 stays per 10,000 population). Asthma was the third most common condition among children aged 1–17 years in 2011, but the rate of hospitalization fell by nearly half since 1997 (from 24 to 13 stays per 10,000 population).

For adults aged 18–44 years, conditions related to pregnancy and childbirth accounted for four of the top five diagnoses in 2011: trauma to the perineum and vulva due to childbirth, delivery following a Cesarean section, prolonged pregnancy, and hypertension complicating pregnancy and childbirth. Together, these diagnoses accounted for 18 percent of stays among adults aged 18–44 years. Between 1997 and 2011, the hospitalization rate for delivery following a Cesarean section nearly doubled, and the rate for prolonged pregnancy nearly tripled. The hospitalization rate for normal pregnancy and/or delivery, however, fell 58 percent during this period (data not shown).

Among adults aged 45–64 years, musculoskeletal conditions—osteoarthritis and back problems (including spondylosis and disc disorders)—accounted for two of the five most frequent diagnoses in 2011. The hospitalization rate for osteoarthritis, the most common reason for hospitalization, grew by 160 percent between 1997 and 2011 (from 19 to 49 stays per 10,000 population). Osteoarthritis was also the most frequent principal diagnosis for adults aged 65–84 years, with the hospitalization rate increasing 54 percent since 1997.

Adults aged 65–84 years and aged 85 years and older shared four of the top five principal diagnoses: congestive heart failure (CHF), septicemia, pneumonia, and cardiac dysrhythmias. CHF was the most common reason for hospitalization for adults aged 85 years and older and the second most common reason for adults aged 65–84 years, but the hospitalization rate decreased for each of these age groups between 1997 and 2011 (18 percent and 31 percent, respectively).

Several principal diagnoses were common among multiple age groups in 2011. Pneumonia was a frequent condition among the youngest and oldest patients—children aged 17 years and younger and adults aged 65 years and older. The rate of hospitalization for pneumonia decreased in each of these age groups between 1997 and 2011. Septicemia was a common reason for hospitalization among adults aged 45 years and older. The overall hospitalization rate for septicemia increased rapidly between 1997 and 2011: 180 percent for adults aged 45–64 years, 104 percent for adults aged 65–84 years, and 74 percent for adults aged 85 years and older.

### Hospital stays for septicemia among adults aged 45–64 years, 65–84 years, and 85 years and older, 1997 and 2011

One age-related finding of particular interest warranted additional analysis: septicemia had the most rapid growth in hospital stays per population between 1997 and 2011 among adults aged 45 years and older. Table 4 shows the number of stays and rate of hospitalization for the principal diagnoses that constitute septicemia, as listed in the International Classification of Diseases, Ninth Revision, Clinical Modification (ICD-9-CM).

Table 4 Number of hospital stays, stays per 10,000 population, and percentage change in rate of selected principal diagnoses for septicemia among adults aged 45–64 years, 65–84 years, and 85 years and older, 1997 and 2011

Principal ICD-9-CM Diagnosis^*^ | Number of stays | | Stays per 10,000 population | | Change in rate, %
Principal ICD-9-CM Diagnosis^*^ | 1997 | 2011 | 1997 | 2011 | 1997–2011
45–64 years, total septicemia stays | 73,339 | 301,842 | 13.0 | 36.0 | 180
Septicemia NOS | 21,612 | 195,693 | 4.0 | 24.0 | 516
Staphylcoccus Aureus Septicemia | 1,843 | 9,915 | 0.3 | 1.0 | 266
Staphylcoccus Septicemia NEC | 967 | 3,650 | 0.2 | 0.4 | 157
Anaerobic Septicemia | 676 | 2,090 | 0.1 | 0.3 | 110
Bacteremia | 2,473 | 7,126 | 0.4 | 1.0 | 96
65–84 years, total septicemia stays | 195,367 | 466,317 | 64.0 | 131.0 | 104
Septicemia NOS | 72,583 | 311,680 | 24.0 | 87.0 | 267
Staphylcoccus Aureus Septicemia | 3,555 | 9,573 | 1.0 | 3.0 | 130
Staphylcoccus Septicemia NEC | 2,402 | 5,751 | 1.0 | 2.0 | 105
Anaerobic Septicemia | 1,952 | 4,460 | 1.0 | 1.0 | 95
Bacteremia | 4,400 | 8,124 | 1.0 | 2.0 | 58
85 years and older, total septicemia stays | 76,451 | 195,319 | 196.0 | 340.0 | 74
Septicemia NOS | 33,318 | 137,791 | 85.0 | 240.0 | 182
Staphylcoccus Aureus Septicemia | 980 | 2,968 | 3.0 | 5.0 | 106
Bacteremia | 993 | 2,520 | 3.0 | 4.0 | 73
Anaerobic Septicemia | 703 | 1,673 | 2.0 | 3.0 | 62

Abbreviations: NOS, not otherwise specified; NEC, not elsewhere classified

* Includes principal ICD-9-CM diagnoses for septicemia that had the most rapid growth in stays per population between 1997 and 2011. The 1997 data were not available for diagnosis codes 038.12 (MRSA Septicemia), 449 (Septic Arterial Embolism), 995.91 (Sirs-Infect W/O Org Dysf [after Oct 1, 2006]), and 995.92 (Sirs-Infect W Organ Dysf [after Oct 1, 2006]). Because the significance level for growth is .001, only four diagnoses are shown for adults aged 85 years and older.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 1997 and 2011

Unspecified septicemia (septicemia NOS) accounted for the majority of septicemia hospitalizations (65–71 percent) within each of the age groups in 2011. The rate of hospitalization for unspecified septicemia increased six fold for adults aged 45–64 years, more than tripled for adults aged 65–84 years, and more than doubled for adults aged 85 years and older between 1997 and 2011.

### Most frequent principal diagnoses by payer during hospital stays, 2011

Table 5 shows the five most frequent principal diagnoses for hospital stays by primary payer. Some of the most frequent diagnoses were specific to individual payers; however, other diagnoses were common among several primary payers.

Table 5 Number of hospital stays, percentage distribution, and percentage change in stays by the most frequent principal diagnoses and payer, 1997 and 2011

Payer and principal CCS diagnosis | Number of stays in thousands | | Share^*^ of payer-specific total stays, % | | Change in number of stays, %
Payer and principal CCS diagnosis | 1997 | 2011 | 1997 | 2011 | 1997–2011
All payers, total stays | 34,679 | 38,591 | 100 | 100 | 11
Medicare, total stays | 12,618 | 15,337 | 100 | 100 | 22
Congestive heart failure, nonhypertensive | 757 | 739 | 6 | 5 | −2
Septicemia (except in labor) | 276 | 722 | 2 | 5 | 161
Pneumonia (except that caused by tuberculosis and sexually transmitted diseases) | 703 | 667 | 6 | 4 | −5
Cardiac dysrhythmias | 375 | 529 | 3 | 3 | 41
Osteoarthritis | 279 | 525 | 2 | 3 | 88
Medicaid, total stays | 5,644 | 7,578 | 100 | 100 | 34
Liveborn (newborn infant) | 1,224 | 1,705 | 22 | 23 | 39
Mood disorders | 147 | 244 | 3 | 3 | 66
Trauma to perineum and vulva | 224 | 240 | 4 | 3 | 7
Previous Cesarean section | 84 | 218 | 1 | 3 | 159
Pneumonia (except that caused by tuberculosis and sexually transmitted diseases) | 166 | 152 | 3 | 2 | −8
Private insurance, total stays | 13,388 | 12,231 | 100 | 100 | −9
Liveborn (newborn infant) | 2,204 | 1,853 | 16 | 15 | –16
Trauma to perineum and vulva | 431 | 385 | 3 | 3 | −11
Osteoarthritis | 117 | 372 | 1 | 3 | 219
Mood disorders | 227 | 289 | 2 | 2 | 27
Spondylosis, intervertebral disc disorders, other back problems | 258 | 280 | 2 | 2 | 9
Uninsured, total stays | 1,676 | 2,068 | 100 | 100 | 23
Liveborn (newborn infant) | 191 | 137 | 11 | 7 | −28
Mood disorders | 55 | 103 | 3 | 5 | 88
Skin and subcutaneous tissue infections | 28 | 75 | 2 | 4 | 170
Alcohol-related disorders | 48 | 69 | 3 | 3 | 44
Diabetes mellitus with complications | 31 | 62 | 2 | 3 | 100

Abbreviation: CCS, Clinical Classifications Software

* Population denominators are not available by payer, so hospitalization rate by payer could not be calculated.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS), 1997 and 2011

Medicare was the primary payer for 15.3 million stays in 2011—an increase of 22 percent from 1997. Congestive heart failure (CHF) and septicemia were the most common principal diagnoses, each accounting for 5 percent of Medicare stays. The number of Medicare stays for septicemia more than doubled between 1997 and 2011. There was also an increase in the number of stays for cardiac dysrhythmias (41 percent) and osteoarthritis (88 percent) during this time period.

There were 7.6 million stays with Medicaid as the primary payer in 2011—a 34-percent increase since 1997. Conditions related to pregnancy and childbirth were three of the top five reasons for Medicaid stays: liveborn (newborn infant), trauma to the perineum and vulva caused by childbirth, and delivery following a Cesarean section. Together, these diagnoses accounted for 29 percent of Medicaid stays. The number of stays for delivery following a Cesarean section more than doubled between 1997 and 2011.

Private insurance was the primary payer for 12.2 million stays in 2011. The two most common reasons for stays billed to private insurance were related to pregnancy and childbirth: liveborn (newborn infant; 15 percent of stays) and trauma to the perineum and vulva caused by childbirth (3 percent of stays). The number of private insurance stays with osteoarthritis more than tripled since 1997.

The uninsured accounted for 2.1 million stays in 2011—an increase of 23 percent from 1997. Three of the most common conditions among uninsured hospital stays increased sharply between 1997 and 2011: mood disorders grew by 88 percent, diabetes mellitus with complications doubled, and stays for skin and subcutaneous tissue infections more than doubled.

Several principal diagnoses were common in stays across multiple primary payers. Liveborn (newborn infant) was the most common diagnosis for stays billed to Medicaid, private insurance, and the uninsured. The number of liveborn stays with Medicaid as the primary payer increased 39 percent between 1997 and 2011, but remained relatively stable for private insurance and uninsured stays. The diagnosis of mood disorders was also common for stays with a primary payer of Medicaid, private insurance, or the uninsured. Stays for mood disorders increased between 1997 and 2011 by 66 percent for Medicaid and 88 percent for the uninsured.

## Data Source

The estimates in this Statistical Brief are based upon data from the Healthcare Cost and Utilization Project (HCUP) 2011 Nationwide Inpatient Sample (NIS). Historical data were drawn from the 1997 Nationwide Inpatient Sample (NIS). The statistics were generated from HCUPnet, a free, online query system that provides users with immediate access to the largest set of publicly available, all-payer national, regional, and State-level hospital care databases from HCUP. The Clinical Classifications Software (CCS) diagnosis categories for behavioral health (CCS 650–663 and 670), including Mood Disorders (CCS 657) and Alcohol-Related Disorders (CCS 660), were not available in HCUPnet for 1997; these statistics were separately calculated using the HCUP 1997 NIS. Supplemental sources included population denominator data for use with HCUP databases.^3^

Many hypothesis tests were conducted for this Statistical Brief. Thus, to decrease the number of false-positive results, we reduced the significance level to .001 for individual tests.

## Definitions

### Diagnoses, ICD-9-CM, and Clinical Classifications Software (CCS)

The principal diagnosis is that condition established after study to be chiefly responsible for the patient's admission to the hospital. Secondary diagnoses are concomitant conditions that coexist at the time of admission or develop during the stay.

ICD-9-CM is the International Classification of Diseases, Ninth Revision, Clinical Modification, which assigns numeric codes to diagnoses. There are approximately 14,000 ICD-9-CM diagnosis codes.

CCS categorizes ICD-9-CM diagnoses into a manageable number of clinically meaningful categories.^4^ This “clinical grouper” makes it easier to quickly understand patterns of diagnoses. CCS categories identified as “Other” typically are not reported; these categories include miscellaneous, otherwise unclassifiable diagnoses that may be difficult to interpret as a group.

### Case definition

The ICD-9-CM codes defining septicemia (except in labor) include diagnosis codes in the following range: 003.1, 036.2, 038.xx, 054.5, 449, 771.81, 790.7, 995.91, or 995.92.

### Types of hospitals included in HCUP

HCUP is based on data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). HCUP data include obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded are long-term care, rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. However, if a patient received long-term care, rehabilitation, or treatment for psychiatric or chemical dependency conditions in a community hospital, the discharge record for that stay will be included in the Nationwide Inpatient Sample (NIS).

### Unit of analysis

The unit of analysis is the hospital discharge (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the hospital multiple times in one year will be counted each time as a separate “discharge” from the hospital.

### Payer

Payer is the expected primary payer for the hospital stay. To make coding uniform across all HCUP data sources, payer combines detailed categories into general groups:

– Medicare: includes patients covered by fee-for-service and managed care Medicare
– Medicaid: includes patients covered by fee-for-service and managed care Medicaid
– Private Insurance: includes Blue Cross, commercial carriers, and private health maintenance organizations (HMOs) and preferred provider organizations (PPOs)
– Other: includes Worker's Compensation, TRICARE/CHAMPUS, CHAMPVA, Title V, and other government programs
– Uninsured: includes an insurance status of “self-pay” and “no charge.”

Encounters billed to the State Children's Health Insurance Program (SCHIP) may be classified as Medicaid, Private Insurance, or Other, depending on the structure of the State program. Because most State data do not identify SCHIP patients specifically, it is not possible to present this information separately.

When more than one payer is listed for a hospital discharge, the first-listed payer is used.

## For More Information

For more information about HCUP, visit http://www.hcup-us.ahrq.gov/.

For additional HCUP statistics, visit HCUPnet, our interactive query system, at http://hcupnet.ahrq.gov/.

For information on other hospitalizations in the United States, download HCUP Facts and Figures: Statistics on Hospital-Based Care in the United States in 2009, located at http://www.hcup-us.ahrq.gov/reports.jsp.

For a detailed description of HCUP, more information on the design of the Nationwide Inpatient Sample (NIS), and methods to calculate estimates, please refer to the following publications:

Introduction to the HCUP Nationwide Inpatient Sample, 2011. Online. June 2013. U.S. Agency for Healthcare Research and Quality. https://www.hcup-us.ahrq.gov/db/nation/nis/NIS_Introduction_2011.pdf. Accessed August 19, 2013.

Houchens R, Elixhauser A. Final Report on Calculating Nationwide Inpatient Sample (NIS) Variances, 2001. HCUP Methods Series Report #2003-2. Online. June 2005 (revised June 6, 2005). U.S. Agency for Healthcare Research and Quality. http://www.hcup-us.ahrq.gov/reports/CalculatingNISVariances200106092005.pdf. Accessed August 19, 2013.

Houchens RL, Elixhauser A. Using the HCUP Nationwide Inpatient Sample to Estimate Trends. (Updated for 1988–2004). HCUP Methods Series Report #2006–05. Online. August 18, 2006. U.S. Agency for Healthcare Research and Quality. http://www.hcup-us.ahrq.gov/reports/methods/2006_05_NISTrendsReport_1988-2004.pdf. Accessed August 19, 2013.

1 Healthcare Cost and Utilization Project (HCUP). (2013). HCUP Facts Figures. .

2 Pfuntner A, Wier LM, Stocks C. (2013). Most Frequent Conditions in U.S. Hospitals, 2010. HCUP Statistical Brief #148. .

3 Barrett M, Lopez-Gonzalez L, Coffey R, Levit K. Population Denominator Data for use with the HCUP Databases (Updated with 2012 Population data). HCUP Methods Series Report #2013-01. .

4 HCUP Clinical Classifications Software (CCS). Healthcare Cost and Utilization Project (HCUP) U.S. Agency for Healthcare Research and Quality Rockville, MD Updated March 2013. http://www.hcup-us.ahrq.gov/toolssoftware/ccs/ccs.jsp August 19, 2013.