# Statistical Brief #159 Trends in Rates of Perforated Appendix, 2001–2010

## Introduction

Monitoring trends in access to and quality of health care is an important way to identify whether care is improving for different groups of people. Trends can be considered in conjunction with contextual events that might explain changes over time for the nation, overall, and for subpopulations. For example, difficult economic times may inhibit or delay patients in seeking health care.^1^ Most recently, the “Great Recession” from 2007–2009 was associated with downward trends in health care utilization across various racial and ethnic groups and types of health care services.^2^

The Healthcare Cost and Utilization Project data, in conjunction with the Agency for Healthcare Research and Quality (AHRQ) Prevention Quality Indicators (PQIs), may be used to monitor trends in access to health care over time. In particular, rates of ambulatory care sensitive conditions—where hospitalizations potentially could be avoided or minimized with appropriate outpatient care—are useful indicators of health care quality and access.^3^

Perforated appendix—the rupture and subsequent spillage of intestinal contents into the abdominal cavity—is considered to be a potentially avoidable condition when appendicitis (inflammation of the appendix) is treated in a prompt and appropriate manner. Patients who experience perforation have worse prognoses and require longer hospital stays than other patients with appendicitis.^4^

From 1970 to 1995, rates of perforated appendix among patients with appendicitis steadily increased.^5^ Furthermore, rates of perforated appendix are known to vary by patient characteristics. Racial and ethnic minorities, patients covered by Medicaid, and uninsured patients exhibited higher perforation rates and longer durations of symptoms before presenting to a health care professional.^6,7^

This Statistical Brief uses 2001–2010 data from the Healthcare Cost and Utilization Project (HCUP) to present contemporary trends in the risk-adjusted rate of perforated appendix per 1,000 inpatient discharges for appendicitis. Trends are examined by patient characteristics including age, race and ethnicity, community income, expected primary payer, urban or rural location of the residence, and region of the treatment hospital. Rates have been risk adjusted by age and sex. Differences that are noted in the text exhibit at least a 10 percent difference between estimates and achieved a level of statistical significance of 0.05 or better.

## Findings

Highlights

■ The adjusted rate of perforated appendix among adults with appendicitis decreased from 2001–2008, but the declining trend did not persist into 2009 and 2010.
■ A similar declining trend was seen across racial and ethnic groups and community income quartiles, with the decrease ending between 2007 and 2009 (depending on the group).
■ Black patients had higher rates of perforated appendix than White patients and other minorities in almost all years between 2001 and 2007, but not in the more recent years examined (2008–2010).
■ Patients in the lowest income communities had consistently higher rates of perforated appendix than those in the highest income communities between 2001 and 2008. This difference did not continue to 2010.
■ Patients covered by Medicare and Medicaid and uninsured patients had decreasing rates of perforated appendix from 2004. Rates reached a low point in 2008 or 2009 and then increased in 2010. Privately insured patients had the lowest rates, and these did not change from 2004–2010.
■ Patients treated in the Northeast often had lower adjusted rates of perforated appendix than patients treated in other regions.

### Characteristics of discharges with appendicitis and perforated appendix

Table 1 compares characteristics for all hospital stays in 2010 involving appendicitis versus stays specifically for perforated appendix. Overall, about 30 percent of the hospital stays for appendicitis involved a perforated appendix. Only a few patient characteristics demonstrated any difference in the distribution of discharges. Discharges of patients aged 18 to 44 years represented 42.3 percent of all appendicitis stays but only 29.0 percent of stays with a perforated appendix. Discharges covered by Medicare represented 9.9 percent of appendicitis stays but were a larger percentage of stays for a perforated appendix (16.0 percent). In terms of utilization, the length of stay for perforated appendix discharges was almost three times longer than all appendicitis discharges (5.2 and 1.8 days, respectively). The total cost for perforated appendix discharges was more than 50 percent higher than all appendicitis discharges ($12,800 and $7,800, respectively).

Table 1 Characteristics for appendicitis and perforated appendix, 2010

| All Appendicitis | Perforated Appendix
Total number of inpatient discharges | 292,297 | 89,133
Age group, in years (%)
1–17 | 26.3 | 26.6
18–44 | 42.3 | 29.0
45–64 | 22.1 | 28.7
65 and older | 9.3 | 15.7
Sex (%)
Male | 55.2 | 57.9
Female | 44.8 | 42.1
Race and Ethnicity (%)
White, non-Hispanic | 62.0 | 63.7
African American, non-Hispanic | 7.5 | 7.8
Hispanic (of any race) | 22.7 | 20.8
Asian and Pacific Islander, non-Hispanic | 3.5 | 3.5
Community income quartile (%)
First quartile (lowest income) | 24.9 | 24.9
Second quartile | 23.6 | 24.5
Third quartile | 25.7 | 25.8
Fourth quartile (highest income) | 25.8 | 24.8
Expected Primary Payer (%)
Private insurance | 52.8 | 48.0
Medicare | 9.9 | 16.0
Medicaid | 19.0 | 18.8
Uninsured (self pay or no charge) | 13.3 | 12.6
Urban or Rural Location (%)
Large central metropolitan | 32.8 | 31.9
Large fringe metropolitan | 25.8 | 24.9
Medium metropolitan | 19.1 | 19.8
Small metropolitan | 7.3 | 7.4
Micropolitan | 9.0 | 9.5
Not metropolitan or micropolitan | 5.9 | 6.4
Region (%)
Northeast | 19.3 | 17.6
Midwest | 17.5 | 19.3
South | 34.3 | 35.9
West | 28.9 | 27.2
Length of Stay, days (mean) | 1.8 | 5.2
Total costs, U.S. dollars (mean) | 7,800 | 12,800

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS) and State Inpatient Databases disparities analytic file, 2010

### Overall trend

The adjusted rate of perforated appendix among adults decreased 12 percent between 2001 and 2008, from a rate of 307 to 270 stays per 1,000 appendicitis discharges, and then did not significantly change in 2009 and 2010 (Figure 1). Rates of perforated appendix for pediatric discharges with appendicitis did not change significantly between 2001 and 2010.

Figure 1 Trends in the rate of perforated appendix per 1,000 appendicitis discharges by age, 2001–2010

Note: Rates are adjusted for age and sex.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS) and AHRQ Prevention Quality Indicators

Figure 1. Trends in the rate of perforated appendix by age, 2001 through 2010. This is a line graph showing the rate per 1,000 appendicitis discharges by year for adults and children. Rates are adjusted for age and sex. The rates for adults aged 18 years and older were: 2001, 307; 2002, 303; 2003, 303; 2004, 294; 2005, 286; 2006, 286; 2007, 280; 2008, 270; 2009, 275; 2010, 287. The rates for children younger than 18 years were: 2001, 305; 2002, 303; 2003, 312; 2004, 309; 2005, 309; 2006, 298; 2007, 301; 2008, 291; 2009, 298; 2010, 302. Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample and AHRQ Prevention Quality Indicators.

### Rates of perforated appendix per 1,000 appendicitis discharges by race and ethnicity, 2001–2010

Black patients had higher rates of perforated appendix compared to White patients and other minority groups from 2001 to 2007, with the exception of 2004. For example, in 2002, the rate for Black patients was 13 to 25 percent higher than the rate for White patients and other minority groups. By 2010, only Black patients had a higher rate of perforated appendix (16 percent higher) than Hispanic patients. Rates for patients who were Hispanic or Asian and Pacific Islander did not differ from rates for White patients in all years.

The adjusted rate of perforated appendix for adults decreased during the early years examined, reaching a low point in 2007, 2008, or 2009, depending on the racial and ethnic group. Rates did not significantly change through 2010 for each group after that low point. The decline was 11 percent for White patients between 2001 and 2007; 17 percent for Asian and Pacific Islander patients from 2001 to 2008; and almost 20 percent for Black and Hispanic patients between 2001 and 2009 (Figure 2).

Figure 2 Trends in the rate of perforated appendix per 1,000 appendicitis discharges for adults by race and ethnicity, 2001–2010

Notes: Data labels apply to groups with the lowest and highest rates. Rates are adjusted for age and sex.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), State Inpatient Databases disparities analytic file and AHRQ Prevention Quality Indicators

Figure 2. Trends in the rate of perforated appendix for adults by race/ethnicity, 2001 through 2010. This is a line graph showing the rate per 1,000 adult appendicitis discharges by year for four groups of discharges. Rates are adjusted for age and sex. Black (highest rates) 2001, 355; 2002, 347; 2003, 334; 2004, 309; 2005, 317; 2006, 324; 2007, 302; 2008, 298; 2009, 292; 2010, 304. Asian and Pacific Islander (lowest rates) 2001, 316; 2002, 276; 2003, 270; 2004, 267; 2005, 270; 2006, 272; 2007, 269; 2008, 262; 2009, 263; 2010, 286. White 2001, 305; 2002, 303; 2003, 295; 2004, 288; 2005, 283; 2006, 279; 2007, 271; 2008, 276; 2009, 275; 2010, 285. Hispanic 2001, 322; 2002, 306; 2003, 294; 2004, 292; 2005, 283; 2006, 284; 2007, 276; 2008, 272; 2009, 258; 2010, 261. Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample and AHRQ Prevention Quality Indicators.

### Rates of perforated appendix per 1,000 appendicitis discharges by community income, 2001–2010

Between 2001 and 2008, patients residing in the lowest income communities had consistently higher rates of perforated appendix than those residing in the highest income communities, with differences ranging from 13 to 18 percent. This difference did not persist in 2009 and 2010.

The adjusted rates of perforated appendix for adults decreased by 12 percent for patients in communities with the lowest income from 2001 to 2009, and they decreased for patients in communities with the highest income from 2001 to 2008. Declining trends did not persist into 2010 (Figure 3).

Figure 3 Trends in the rate of perforated appendix per 1,000 appendicitis discharges for adults by community income, 2001–2010

Notes: Rates are adjusted for age and sex.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS) and AHRQ Prevention Quality Indicators

Figure 3. Trends in the rate of perforated appendix for adults by community income, 2001 through 2010. This is a line graph showing the rate per 1,000 adult appendicitis discharges by year for two income levels. Rates are adjusted for age and sex. Lowest income communities 2001, 321; 2002, 327; 2003, 324; 2004, 314; 2005, 305; 2006, 311; 2007, 300; 2008, 286; 2009, 282; 2010, 295. Highest income communities 2001, 285; 2002, 288; 2003, 275; 2004, 273; 2005, 271; 2006, 265; 2007, 257; 2008, 250; 2009, 266; 2010, 274. Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample and AHRQ Prevention Quality Indicators.

### Rates of perforated appendix per 1,000 appendicitis discharges by expected primary payer, 2004–2010

The adjusted rates of perforated appendix for privately insured adult patients remained unchanged during the period examined; however, the rates decreased for all other expected primary payers between 2004, and they reached a low point in either 2008 or 2009 (depending on the group). The decrease from 2004 to the lowest point was 24 percent for Medicare patients (in 2008); 19 percent for Medicaid patients (in 2009); and 10 percent for uninsured patients (in 2009) (Figure 4). In addition, the rates of perforated appendix increased from the lowest point to 2010 for three payer groups: a 21 percent increase for Medicare patients; a 10 percent increase for Medicaid patients; and a 13 percent increase for uninsured patients.

Figure 4 Trends in the rate of perforated appendix per 1,000 appendicitis discharges for adults by expected primary payer, 2004–2010^a^ a Data for 2001–2003 are not available.

Notes: Data labels apply to groups with the lowest and highest rates. Rates are adjusted for age and sex.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS) and AHRQ Prevention Quality Indicators

Figure 4. Trends in the rate of perforated appendix for adults by expected primary payer, 2004 through 2010. This is a line graph showing the rate per 1,000 adult appendicitis discharges by year for four insurance groups. Data for 2001 through 2003 are not available. Rates are adjusted for age and sex. Private insurance (lowest rates) 2004, 279; 2005, 270; 2006, 267; 2007, 263; 2008, 256; 2009, 262; 2010, 272. Medicare (highest rates) 2004, 374; 2005, 331; 2006, 353; 2007, 314; 2008, 283; 2009, 314; 2010, 341. Medicaid 2004, 328; 2005, 302; 2006, 301; 2007, 301; 2008, 293; 2009, 265; 2010, 292. Uninsured 2004, 326; 2005, 332; 2006, 330; 2007, 296; 2008, 308; 2009, 292; 2010, 330. Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample and AHRQ Prevention Quality Indicators.

The adjusted rates of perforated appendix for Medicare and uninsured patients were consistently higher than the rates for privately insured patients for all years. Compared to privately insured patients, Medicare patients had rates 10 to 34 percent higher and uninsured patients had rates 11 to 24 percent higher. From 2004 to 2008, Medicaid patients had rates 12 to 17 percent higher than privately insured patients.

### Rates of perforated appendix per 1,000 appendicitis discharges by urban or rural location, 2004–2010

From 2004 to 2009, the adjusted rate of perforated appendix for adults decreased 12 percent among patients residing in large central metropolitan areas and then increased 11 percent from 2009 to 2010 (Figure 5). The trends in other metropolitan and non-metropolitan areas did not demonstrate a significant change over time. Patients residing in rural areas (not metropolitan or micropolitan) had adjusted rates of perforated appendix that were 12 to 20 percent higher than individuals residing in large central and fringe metropolitan areas from 2006 to 2009. By 2010, there were no differences in the rates of perforated appendix across urban or rural location.

Figure 5 Trends in the rate of perforated appendix per 1,000 appendicitis discharges for adults by urban or rural location, 2004–2010^a^ a Data for 2001–2003 are not available.

Notes: Data labels apply to groups with the lowest and highest rates. Rates are adjusted for age and sex.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS) and AHRQ Prevention Quality Indicators

Figure 5. Trends in the rate of perforated appendix for adults by urban-rural location, 2004 through 2010. This is a line graph showing the rate per 1,000 adult appendicitis discharges per year for six community sizes. Data for 2001 through 2003 are not available. Rates are adjusted for age and sex. Large fringe metropolitan (lowest rates) 2004, 283; 2005, 276; 2006, 276; 2007, 269; 2008, 263; 2009, 272; 2010, 277. Not metropolitan or micropolitan (highest rates) 2004, 305; 2005, 291; 2006, 315; 2007, 310; 2008, 301; 2009, 309; 2010, 307. Large central metropolitan 2004, 292; 2005, 283; 2006, 276; 2007, 276; 2008, 260; 2009, 257; 2010, 286. Medium metropolitan 2004, 295; 2005, 297; 2006, 296; 2007, 275; 2008, 276; 2009, 295; 2010, 291. Small metropolitan 2004, 305; 2005, 292; 2006, 312; 2007, 296; 2008, 282; 2009, 294; 2010, 292. Micropolitan 2004, 307; 2005, 296; 2006, 288; 2007, 300; 2008, 286; 2009, 282; 2010, 293. Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample and AHRQ Prevention Quality Indicators.

### Rates of perforated appendix per 1,000 appendicitis discharges by region, 2004–2010

Patients treated in the Northeast often had lower adjusted rates of perforated appendix than patients treated in other regions. Rates of perforated appendix in the Midwest were 14 to 20 percent higher than rates in the Northeast in all years. Rates of perforated appendix in the South were 10 to 19 percent higher than rates in the Northeast in all years except 2009. Rates of perforated appendix in the West were 11 to 16 percent higher than rates in the Northeast from 2004 to 2007.

From 2004 to 2009, the adjusted rate of perforated appendix for adults decreased 11 percent in the South, but this downward trend reversed from 2009 to 2010 (Figure 6). Trends in other regions did not demonstrate a significant change over time.

Figure 6 Trends in the rate of perforated appendix per 1,000 appendicitis discharges for adults by region, 2004–2010^a^ a Data for 2001–2003 are not available.

Notes: Data labels apply to groups with the lowest and highest rates. Rates are adjusted for age and sex.

Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project (HCUP), Nationwide Inpatient Sample (NIS) and AHRQ Prevention Quality Indicators

Figure 6. Trends in the rate of perforated appendix for adults by region, 2004 through 2010. This is a line graph showing the rate per 1,000 adult appendicitis discharges by year for four regions. Data for 2001 through 2003 are not available. Northeast (lowest rates) 2004, 264; 2005, 254; 2006, 256; 2007, 246; 2008, 249; 2009, 255; 2010, 265. Midwest (highest rates) 2004, 300; 2005, 295; 2006, 293; 2007, 293; 2008, 284; 2009, 307; 2010, 311. South 2004, 307; 2005, 302; 2006, 294; 2007, 289; 2008, 275; 2009, 274; 2010, 297. West 2004, 294; 2005, 287; 2006, 296; 2007, 287; 2008, 268; 2009, 272; 2010, 274. Source: Agency for Healthcare Research and Quality (AHRQ), Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample and AHRQ Prevention Quality Indicators. Rates are adjusted for age and sex.

## Data Source

The estimates in this Statistical Brief are based upon data from the Healthcare Cost and Utilization Project (HCUP) 2001–2010 Nationwide Inpatient Samples (NIS) and disparities analysis files created from the State Inpatient Databases (SID). The disparities analysis files are designed to provide national estimates on racial disparities using weighted records from a sample of hospitals in the SID.

### State Inpatient Databases (SID) disparities analysis file

Race and ethnicity measures can be problematic in hospital discharge databases. Some States do not collect information on race and ethnicity from hospitals and, within States that collect the information, some hospitals do not code race and ethnicity reliably. A disparities analysis file designed to provide national estimates by race and ethnicity was constructed using the HCUP SID from participating States that report patient race and ethnicity. This file was created using a stratified, weighted sample of hospitals with good reporting of patient race and ethnicity. It contains data from about 2,000 hospitals and is a 40-percent sample of community, non-rehabilitation hospitals in the United States. For 2001 and 2002, SID data from the following 22 States were used: AZ, CA, CO, CT, FL, GA, HI, KS, MA, MD, MI, MO, NJ, NY, PA, RI, SC, TN, TX, VA, VT, and WI. For 2003, SID data from NH were added, for a total of 23 States. In 2004, SID data from AR were added, but SID data from PA were not available. In 2005, SID data from OK were added, but SID data from VA were not available. In 2006, SID data from UT and VA were added, for a total of 25 States. In 2007, SID data from WY were added, for a total of 26 States. In 2008, SID data from KY, ME, NV, OR, and PA were added, for a total of 31 States. In 2009, SID data from IA, IL, NM, SD, and WA were added, for a total of 36 States. In 2010, SID data from ME, NH, and WA were not available; SID from AK, IN, MS, and NC were added, for a total of 37 states.^7^

Many hypothesis tests were conducted for this Statistical Brief. We required a significance level of less than 0.05 in conjunction with a 10 percent difference in the rates for individual tests.

## Definitions

### Perforated Appendix

Rates of perforated appendix for adults and children were based on the AHRQ Prevention Quality Indicators (PQIs) for perforated appendix (PQI #2 and PDI #17), version 4.1 of the PQI software. Rates were adjusted by age and sex using hospitalizations for 2000 in the United States as the standard population.

The PQI for perforated appendix for adults includes the following cases in the denominator (population at risk):

- All non-maternal discharges of patients aged 18 years and older with diagnosis code for appendicitis in any field.
- ICD-9-CM diagnosis codes for appendicitis includes:
  ○ 5400 AC APPEND W PERITONITIS
  ○ 5409 ACUTE APPENDICITIS NOS
  ○ 5401 ABSCESS OF APPENDIX
  ○ 541 APPENDICITIS NOS

The numerator (outcome of interest) for the PQI for perforated appendix includes the following:

- Discharges with ICD-9-CM diagnosis code for perforations or abscesses of appendix in any field among cases meeting the inclusion rules for the denominator.
- ICD-9-CM diagnosis codes (outcome of interest):
  ○ 5400 AC APPEND W PERITONITIS
  ○ 5401 ABSCESS OF APPENDIX

The denominators exclude cases that are:

- transferred from a hospital (different facility)
- transferred from a skilled nursing facility (SNF) or intermediate care facility (ICF)
- transferred from another health care facility
- in major diagnostic category (MDC) number 14 (pregnancy, childbirth, and puerperium)

Identical criteria were used to identify perforated appendix cases for children, except the calculation included discharges of individuals aged 1 to 17 years only.

### Prevention Quality Indicators

The Prevention Quality Indicators (PQIs; version 4.1), a component of the AHRQ Quality Indicators (QIs), are a set of measures that can be used with hospital inpatient discharge data to identify access to and quality of care for “ambulatory care-sensitive conditions.” These are conditions for which good outpatient care can potentially prevent the need for hospitalization or for which early intervention can prevent complications or more severe disease. PQI rates can also be affected by other factors such as disease prevalence. The PQIs are adjusted for age and sex.

Further information on the AHRQ QIs, including documentation and free software downloads, is available at http://www.qualityindicators.ahrq.gov/. It also includes information on the Pediatric Quality Indicators (PDIs, formerly referred to as PedQIs). The PDIs contain measures of potentially preventable hospitalizations for children for asthma, gastroenteritis, diabetes short-term complications, and perforated appendix. Additional information on how the QI software was applied to the HCUP data for the statistics reported in this Statistical Brief is available in Coffey et al., 2012.^8^

### Types of hospitals included in HCUP

HCUP is based on data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). HCUP data include obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded are long-term care, rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. However, if a patient received long-term care, rehabilitation, or treatment for psychiatric or chemical dependency conditions in a community hospital, the discharge record for that stay will be included in the Nationwide Inpatient Sample (NIS) and the SID disparities analysis file.

### Unit of analysis

The unit of analysis is the hospital discharge (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the hospital multiple times in one year will be counted each time as a separate “discharge” from the hospital.

### Costs and charges

Total hospital charges were converted to costs using HCUP Cost-to-Charge Ratios based on hospital accounting reports from the Centers for Medicare & Medicaid Services (CMS).^9^Costs will reflect the actual expenses incurred in the production of hospital services, such as wages, supplies, and utility costs; charges represent the amount a hospital billed for the case. For each hospital, a hospital-wide cost-to-charge ratio is used. Hospital charges reflect the amount the hospital billed for the entire hospital stay and do not include professional (physician) fees. For the purposes of this Statistical Brief, costs are reported to the nearest hundred.

### Patients’ race and ethnicity

HCUP uniform coding includes race and ethnicity in one data element (RACE). Because of variability in the collection of race and ethnicity information in the State data provided to HCUP, HCUP maintains a uniform set of categories based on race definitions used in the 1977 Office of Management and Budget (OMB) Directive 15. It uses the combined race-ethnicity format (separate categories for Hispanic and five Non-Hispanic racial groups—White, Black, Asian and Pacific Islander, American Indian or Alaska Native, and Other). When a State and its hospitals collect Hispanic ethnicity separately from race, HCUP assigns the data to the combined race and ethnicity categorization and uses Hispanic ethnicity to override any other race category to create uniform coding across States. There is also limited reporting of American Indian or Alaska Native (AIAN) in the HCUP data, so statistics for this group were not presented.

This Statistical Brief reports race and ethnicity for the following categories: White Non-Hispanic; African American Non-Hispanic, Asian or Pacific Islander Non-Hispanic, and Hispanic (of any race).

### Median community-level income

Median community-level income is the median household income of the patient’s ZIP Code of residence. The cut-offs for the quartile designation are determined yearly using ZIP Code demographic data obtained from the Nielsen Company. The income quartile is missing for homeless and foreign patients.

### Payer

Payer is the expected primary payer for the hospital stay. To make coding uniform across all HCUP data sources, payer combines detailed categories into general groups:

– Medicare: includes patients covered by fee-for-service and managed care Medicare
– Medicaid: includes patients covered by fee-for-service and managed care Medicaid.
– Private Insurance: includes Blue Cross, commercial carriers, and private health maintenance organizations (HMOs) and preferred provider organizations (PPOs)
– Other: includes Worker’s Compensation, TRICARE/CHAMPUS, CHAMPVA, Title V, and other government programs
– Uninsured: includes an insurance status of “self-pay” and “no charge.”

Encounters billed to the State Children’s Health Insurance Program (SCHIP) may be classified as Medicaid, Private Insurance, or Other, depending on the structure of the State program. Because most State data do not identify SCHIP patients specifically, it is not possible to present this information separately.

When more than one payer is listed for a hospital discharge, the first-listed payer is used.

### Location of patients’ residence

Place of residence is based on the urban-rural classification scheme for U.S. counties developed by the National Center for Health Statistics (NCHS):

– Large Central Metropolitan: Central counties of metropolitan areas with 1 million or more residents
– Large Fringe Metropolitan: Fringe counties of counties of metropolitan areas with 1 million or more residents
– Medium Metropolitan: Counties in metropolitan areas of 250,000–999,999 residents
– Small Metropolitan: Counties in metropolitan areas of 50,000–249,999 residents
– Micropolitan: Nonmetropolitan counties, i.e., a nonmetropolitan county with an area of 10,000 or more residents
– Non-core: Nonmetropolitan and nonmicropolitan counties.

### Region

Region is one of the four regions defined by the U.S. Census Bureau and is based on the region of the treatment hospital:

– Northeast: Maine, New Hampshire, Vermont, Massachusetts, Rhode Island, Connecticut, New York, New Jersey, and Pennsylvania
– Midwest: Ohio, Indiana, Illinois, Michigan, Wisconsin, Minnesota, Iowa, Missouri, North Dakota, South Dakota, Nebraska, and Kansas
– South: Delaware, Maryland, District of Columbia, Virginia, West Virginia, North Carolina, South Carolina, Georgia, Florida, Kentucky, Tennessee, Alabama, Mississippi, Arkansas, Louisiana, Oklahoma, and Texas
– West: Montana, Idaho, Wyoming, Colorado, New Mexico, Arizona, Utah, Nevada, Washington, Oregon, California, Alaska, and Hawaii

## For More Information

For more information about HCUP, visit http://www.hcup-us.ahrq.gov/.

For additional HCUP statistics, visit HCUPnet, our interactive query system, at http://hcupnet.ahrq.gov/.

For information on other hospitalizations in the United States, download HCUP Facts and Figures: Statistics on Hospital-Based Care in the United States in 2009, located at http://www.hcup-us.ahrq.gov/reports.jsp.

For a detailed description of HCUP, more information on the design of the Nationwide Inpatient Sample (NIS), and methods to calculate estimates, please refer to the following publications:

Introduction to the HCUP Nationwide Inpatient Sample, 2009. Online. May 2011. U.S. Agency for Healthcare Research and Quality. http://hcup-us.ahrq.gov/db/nation/nis/NIS_2009_INTRODUCTION.pdf. Accessed June 25, 2013.

Houchens R, Elixhauser A. Final Report on Calculating Nationwide Inpatient Sample (NIS) Variances, 2001. HCUP Methods Series Report #2003-2. Online. June 2005 (revised June 6, 2005). U.S. Agency for Healthcare Research and Quality. http://www.hcup-us.ahrq.gov/reports/CalculatingNISVariances200106092005.pdf. Accessed June 25, 2013.

Houchens RL, Elixhauser A. Using the HCUP Nationwide Inpatient Sample to Estimate Trends. (Updated for 1988–2004). HCUP Methods Series Report #2006–05. Online. August 18, 2006. U.S. Agency for Healthcare Research and Quality. http://www.hcup-us.ahrq.gov/reports/methods/2006_05_NISTrendsReport_1988-2004.pdf. Accessed June 25, 2013.

1 Robert Wood Johnson Foundation. (2009). Impact of the Economy on Health Care.

2 Morternsen K, Chen J. (2013). The great recession and racial and ethnic disparities in health services use. JAMA Internal Medicine.

3 Agency for Healthcare Research and Quality. (2012). Prevention Quality Indicators #2: Technical Specifications. Perforated Appendix Admission Rate [version 4.4].

4 Siddique K, Mirza S, Harinath G. (2013). Appendiceal inflammation affects the length of stay following appendicectomy amongst children: a myth or reality?. Frontiers of Medicine.

5 Livingston EH, Woodward WA, Sarosi GA, Haley RW. (2007). Disconnect between incidence of nonperforated and perforated appendicitis: implications for pathophysiology and management. Annals of Surgery.

6 Braveman P, Schaaf VM, Egerter S, Bennett T, Schecter W. (1994). Insurance-related difference in the risk of ruptured appendix. New England Journal of Medicine.

7 Bratton SL, Haberkern CM, Waldhausen JHT. (2000). Acute appendicitis risks of complications: age and Medicaid insurance. Pediatrics.

8 Coffey R, Barret M, Houchens R, Moy E, Andrews R, Coenen N. (2012). Methods Applying AHRQ Quality Indicators to Healthcare Cost and Utilization Project (HCUP) Data for the Eleventh (2013) National Healthcare Quality Report (NHQR) and National Healthcare Disparities Report (NHDR). HCUP Methods Series Report #2012-03.

9 HCUP Cost-to-Charge Ratio Files (CCR). Healthcare Cost and Utilization Project (HCUP). 2001–2009.