# Statistical Brief #153 Readmissions to U.S. Hospitals by Diagnosis, 2010

## Introduction

The problem of readmissions to the hospital is receiving increased attention as a potential way to address problems in quality of care, cost of care, and care transitions.^1,2^ Medicare reports 30-day hospital readmissions for acute myocardial infarction, congestive failure, and pneumonia for individual hospitals across the country.^3^ Interventions are underway to reduce hospital readmissions at the state and national level.^4,5^

Prior research reports have focused on readmissions for specific conditions such as congestive heart failure, pneumonia, chronic obstructive pulmonary disease (COPD), and psychoses.^6,7,8^ This Statistical Brief provides an overview of 30-day all-payer, all-cause readmissions to U.S. hospitals for a range of conditions in 2010, thereby presenting the most comprehensive national estimates on readmissions by condition.

In this Statistical Brief, readmission was defined as a subsequent hospital admission within 30 days following an original admission (or index stay) that occurred from January through November 2010. All-cause readmissions were examined; thus, readmissions may or may not include conditions that were listed as the principal diagnosis during the index stay. Readmissions were tracked across the same or different hospitals. Some readmissions may be planned or unavoidable—no attempt was made to remove these types of readmissions from the analysis.

Readmission rates using Healthcare Cost and Utilization Project (HCUP) data are presented for the most frequently treated conditions in U.S. hospitals during 2010 and for the conditions with the highest readmission rates. All estimates were taken from HCUPnet, the online query system that provides free access to information from HCUP.^9^ For a subset of conditions, readmission rates are presented by age group and expected payer (insurance status). Patients younger than 1 year were excluded from this analysis. Readmission rates were calculated without risk adjustment.

Appendix A provides detailed information on readmission rates for most conditions treated in U.S. hospitals in 2010. The table provides information on the number of index stays for each condition, the number of all-cause readmissions within 30 days, and the percentage of index stays that were followed by a readmission within 30 days for any cause. Excluded were nonspecific conditions and any conditions with fewer than 5,000 index stays or fewer than 500 readmissions. Conditions are organized by etiology or body system.

## Findings

Highlights

■ For several of the most frequently treated conditions in U.S. hospitals, at least one in five cases resulted in a readmission within 30 days: congestive heart failure (24.7 percent), schizophrenia (22.3 percent), and acute and unspecified renal failure (21.7 percent).
■ For several conditions, over one in four patients were readmitted: sickle cell anemia (31.9 percent), gangrene (31.6 percent), hepatitis (30.9 percent), diseases of the white blood cells (30.9 percent), and chronic renal failure (27.4 percent).
■ For conditions with both large numbers of stays and high readmission rates, Medicare and especially Medicaid patients were more likely to be readmitted than privately insured or uninsured patients. For example, congestive heart failure readmission rates were 30.1 percent for Medicaid, 25.0 percent for Medicare, 19.5 percent for privately insured, and 17.1 for uninsured patients.
■ For the same selected conditions, children and adolescents had the highest readmission rates only for complications of devices, implants or grafts (25.5 percent), compared to 19.2 percent for patients aged 65 years and older.

### Readmission rates for the most frequently treated conditions

Table 1 lists the 30 most frequently treated conditions in U.S. hospitals, with their 30-day readmission rates. The most frequent conditions and their readmission rates were pneumonia (15.7 percent), mood disorders (14.8 percent), osteoarthritis (4.8 percent), congestive heart failure (24.7 percent), and cardiac dysrhythmias (14.8 percent).

Table 1 All-cause 30-day readmissions ranked by the most frequently treated conditions^*^ in U.S. hospitals, 2010

Rank | Principal diagnosis for index hospital stay ** | Number of index stays | 30-day all-cause readmissions
Rank | Principal diagnosis for index hospital stay ** | Number of index stays | Number of readmissions | Percent readmitted
1 | Pneumonia | 924,160 | 144,894 | 15.7
2 | Mood disorders | 883,245 | 131,125 | 14.8
3 | Osteoarthritis | 872,661 | 42,241 | 4.8
4 | Congestive heart failure, nonhypertensive | 847,073 | 209,017 | 24.7
5 | Cardiac dysrhythmias | 705,616 | 104,607 | 14.8
6 | Septicemia (except in labor) | 696,122 | 145,896 | 21.0
7 | Coronary atherosclerosis | 666,897 | 90,147 | 13.5
8 | Trauma to perineum and vulva due to childbirth | 610,073 | 5,046 | 0.8
9 | Chronic obstructive pulmonary disease and bronchiectasis | 606,186 | 126,443 | 20.9
10 | Nonspecific chest pain | 601,899 | 61,465 | 10.2
11 | Complication of device, implant or graft | 596,062 | 121,036 | 20.3
12 | Spondylosis, intervertebral disc disorders, other back problems | 579,103 | 47,774 | 8.2
13 | Skin and subcutaneous tissue infections | 576,902 | 64,680 | 11.2
14 | Urinary tract infections | 522,921 | 84,858 | 16.2
15 | Acute myocardial infarction | 520,901 | 85,932 | 16.5
16 | Acute cerebrovascular disease | 520,793 | 71,174 | 13.7
17 | Diabetes mellitus with complications | 480,958 | 97,784 | 20.3
18 | Previous C-section | 462,378 | 7,046 | 1.5
19 | Complications of surgical procedures or medical care | 453,266 | 81,353 | 17.9
20 | Biliary tract disease | 430,988 | 48,062 | 11.2
21 | Schizophrenia and other psychotic disorders | 397,166 | 88,629 | 22.3
22 | Fluid and electrolyte disorders | 396,551 | 73,721 | 18.6
23 | Asthma | 347,404 | 41,320 | 11.9
24 | Acute and unspecified renal failure | 326,586 | 70,756 | 21.7
25 | Gastrointestinal hemorrhage | 320,613 | 54,154 | 16.9
26 | Intestinal obstruction without hernia | 315,128 | 51,135 | 16.2
27 | Fracture of neck of femur (hip) | 291,847 | 38,668 | 13.2
28 | Diverticulosis and diverticulitis | 289,097 | 35,461 | 12.3
29 | Pancreatic disorders (not diabetes) | 282,159 | 49,936 | 17.7
30 | Appendicitis and other appendiceal conditions | 262,024 | 12,875 | 4.9

Source: Weighted national estimates from a readmissions analysis file derived from the Healthcare Cost and Utilization Project (HCUP) State Inpatient Databases (SID), 2010, Agency for Healthcare Research and Quality (AHRQ).

* Information is provided for diagnoses with 5,000 or more weighted index stays and 500 or more weighted readmissions. See text and Definitions for details on methods for calculating readmissions.

** Clinical Classification Software (CCS) label. Excludes cancers and nonspecific CCS categories.

Among these most frequent conditions, the highest readmission rates were seen for congestive heart failure (24.7 percent), schizophrenia (22.3 percent), and acute and unspecified renal failure (21.7 percent). In other words, for these conditions over one in five patients were readmitted to the hospital within 30 days.

The lowest readmission rates were for childbirth-related procedures (trauma to perineum and vulva during childbirth, 0.8 percent; C-section, 1.5 percent), osteoarthritis (4.8 percent), and appendicitis (4.9 percent).

### Conditions with the highest readmission rates

Table 2 lists conditions ranked by the highest readmission rates. Because cancer readmissions are often planned, cancer is excluded from this table (although cancer-related conditions are included in the Appendix).

Table 2 All-cause 30-day readmissions ranked by conditions with the highest readmission rates,^*^ U.S. hospitals, 2010

Rank | Principal diagnosis for index hospital stay ** | Number of index stays | 30-day all-cause readmissions
Rank | Principal diagnosis for index hospital stay ** | Number of index stays | Number of readmissions | Percent readmitted
1 | Sickle cell anemia | 87,326 | 27,837 | 31.9
2 | Gangrene | 33,786 | 10,693 | 31.6
3 | Hepatitis | 37,480 | 11,593 | 30.9
4 | Disease of white blood cells | 54,861 | 16,771 | 30.6
5 | Chronic renal failure | 17,394 | 4,766 | 27.4
6 | Systemic lupus erythematosus and connective tissue disorders | 18,850 | 5,123 | 27.2
7 | Mycoses | 23,026 | 6,222 | 27.0
8 | HIV infection | 34,958 | 9,230 | 26.4
9 | Screening and history of mental health and substance abuse | 60,417 | 15,695 | 26.0
10 | Peritonitis and intestinal abscess | 25,219 | 6,315 | 25.0
11 | Congestive heart failure, nonhypertensive | 847,073 | 209,017 | 24.7
12 | Personality disorders | 5,436 | 1,316 | 24.2
13 | Nutritional deficiencies | 9,845 | 2,355 | 23.9
14 | Coagulation and hemorrhagic disorders | 33,397 | 7,920 | 23.7
15 | Respiratory failure, insufficiency, arrest (adult) | 260,781 | 59,842 | 22.9
16 | Nausea and vomiting | 51,833 | 11,854 | 22.9
17 | Schizophrenia and other psychotic disorders | 397,166 | 88,629 | 22.3
18 | Acute and unspecified renal failure | 326,586 | 70,756 | 21.7
19 | Aspiration pneumonitis, food/vomitus | 147,837 | 31,772 | 21.5
20 | Hypertension with complications and secondary hypertension | 211,243 | 45,309 | 21.4
21 | Chronic ulcer of skin | 50,845 | 10,823 | 21.3
22 | Pleurisy, pneumothorax, pulmonary collapse | 101,298 | 21,485 | 21.2
23 | Early or threatened labor | 179,175 | 37,797 | 21.1
24 | Septicemia | 696,122 | 145,896 | 21.0
25 | Anemia | 203,098 | 42,374 | 20.9
26 | Chronic obstructive pulmonary disease and bronchiectasis | 606,186 | 126,443 | 20.9
27 | Aortic and peripheral arterial embolism or thrombosis | 26,104 | 5,381 | 20.6
28 | Heart valve disorders | 100,327 | 20,613 | 20.5
29 | Diabetes mellitus with complications | 480,958 | 97,784 | 20.3
30 | Complication of device, implant or graft | 596,062 | 121,036 | 20.3

Source: Weighted national estimates from a readmissions analysis file derived from Healthcare Cost and Utilization Project (HCUP) State Inpatient Databases (SID), 2010, Agency for Healthcare Research and Quality (AHRQ).

* Information is provided for diagnoses with 5,000 or more weighted index stays and 500 or more weighted readmissions. See text and Definitions for details on methods for calculating readmissions.

** Clinical Classification Software (CCS) label. Excludes cancers and nonspecific CCS categories.

The five conditions with the highest readmission rates were sickle cell anemia (31.9 percent), gangrene (31.6 percent), hepatitis (30.9 percent), diseases of the white blood cells (30.9 percent), and chronic renal failure (27.4 percent). In other words, over one in four patients were readmitted to the hospital within 30 days for these conditions.

### Readmission rates by age and insurance status for selected conditions

Figures 1–5 provide details on 30-day all-cause readmission rates for the five conditions from Table 2 that involved more than 300,000 index stays and had overall readmission rates of at least 20 percent.^10^

Figure 1 All-cause 30-day readmission rates for congestive heart failure by age and insurance status, U.S. hospitals, 2010

Source: Weighted national estimates from a readmissions analysis file derived from the Healthcare Cost and Utilization Project (HCUP) State Inpatient Databases (SID), 2010, Agency for Healthcare Research and Quality (AHRQ).

-- Indicates too few cases to report.

Figure 1. All-cause 30-day readmission rates for congestive heart failure by age and insurance status, U.S. hospitals, 2010. This is a bar chart showing percent readmitted by age in years and by expected primary payer. Ages 1 through 17, too few cases to report. Ages 18 through 44, 26.1 percent. Ages 45 through 64, 25.7 percent. Ages 65 and older, 24.2 percent. Medicare payer, 25.0 percent. Medicaid payer, 30.1 percent. Privately insured, 19.5 percent. Uninsured, 17.1 percent. Source: Weighted national estimates from a readmissions analysis file derived from the Healthcare Cost and Utilization Project State Inpatient Databases, 2010, Agency for Healthcare Research and Quality.

Figure 2 All-cause 30-day readmission rates for schizophrenia and other psychotic conditions by age and insurance status, U.S. hospitals, 2010

Source: Weighted national estimates from a readmissions analysis file derived from the Healthcare Cost and Utilization Project (HCUP) State Inpatient Databases (SID), 2010, Agency for Healthcare Research and Quality (AHRQ).

Figure 2. All-cause 30-day readmission rates for schizophrenia and other psychotic conditions by age and insurance status, U.S. hospitals, 2010. This is a bar chart showing percent readmitted by age in years and by expected primary payer. Ages 1 through 17, 12.4 percent. Ages 18 through 44, 22.6 percent. Ages 45 through 64, 23.4 percent. Ages 65 and older, 18.8 percent. Medicare payer, 23.7 percent. Medicaid payer, 24.0 percent. Privately insured, 16.1 percent. Uninsured, 15.1 percent. Source: Weighted national estimates from a readmissions analysis file derived from the Healthcare Cost and Utilization Project State Inpatient Databases, 2010, Agency for Healthcare Research and Quality.

Figure 3 All-cause 30-day readmission rates for acute and unspecified renal failure by age and insurance status, U.S. hospitals, 2010

Source: Weighted national estimates from a readmissions analysis file derived from the Healthcare Cost and Utilization Project (HCUP) State Inpatient Databases (SID), 2010, Agency for Healthcare Research and Quality (AHRQ).

-- Indicates too few cases to report.

Figure 3. All-cause 30-day readmission rates for acute and unspecified renal failure by age and insurance status, U.S. hospitals, 2010. This is a bar chart showing percent readmitted by age in years and by expected primary payer. Ages 1 through 17, too few cases to report. Ages 18 through 44, 19.0 percent. Ages 45 through 64, 21.5 percent. Ages 65 and older, 22.1 percent. Medicare payer, 22.7 percent. Medicaid payer, 25.0 percent. Privately insured, 17.0 percent. Uninsured, 13.3 percent. Source: Weighted national estimates from a readmissions analysis file derived from the Healthcare Cost and Utilization Project State Inpatient Databases, 2010, Agency for Healthcare Research and Quality.

Figure 4 All-cause 30-day readmission rates for diabetes with complications by age and insurance status, U.S. hospitals, 2010

Source: Weighted national estimates from a readmissions analysis file derived from the Healthcare Cost and Utilization Project (HCUP) State Inpatient Databases (SID), 2010, Agency for Healthcare Research and Quality (AHRQ).

Figure 4. All-cause 30-day readmission rates for diabetes with complications by age and insurance status, U.S. hospitals, 2010. This is a bar chart showing percent readmitted by age in years and by expected primary payer. Ages 1 through 17, 7.2 percent. Ages 18 through 44, 22.6 percent. Ages 45 through 64, 19.9 percent. Ages 65 and older, 20.6 percent. Medicare payer, 23.6 percent. Medicaid payer, 23.5 percent. Privately insured, 13.6 percent. Uninsured, 14.1 percent. Source: Weighted national estimates from a readmissions analysis file derived from the Healthcare Cost and Utilization Project State Inpatient Databases, 2010, Agency for Healthcare Research and Quality.

Figure 5 All-cause 30-day readmission rates for complication of device, implant or graft by age and insurance status, U.S. hospitals, 2010

Source: Weighted national estimates from a readmissions analysis file derived from the Healthcare Cost and Utilization Project (HCUP) State Inpatient Databases (SID), 2010, Agency for Healthcare Research and Quality (AHRQ).

Figure 5. All-cause 30-day readmission rates for complication of device, implant, or graft by age and insurance status, U.S. hospitals, 2010. This is a bar chart showing percent readmitted by age in years and by expected primary payer. Ages 1 through 17, 25.5 percent. Ages 18 through 44, 23.4 percent. Ages 45 through 64, 19.9 percent. Ages 65 and older, 19.2 percent. Medicare payer, 21.4 percent. Medicaid payer, 25.4 percent. Privately insured, 15.7 percent. Uninsured, 15.6 percent. Source: Weighted national estimates from a readmissions analysis file derived from the Healthcare Cost and Utilization Project State Inpatient Databases, 2010, Agency for Healthcare Research and Quality.

Figure 1 shows that readmission rates for congestive heart failure were relatively uniform across age groups, ranging from 24.2 percent to 26.1 percent. The highest readmission rate was seen for patients with an expected payer of Medicaid (30.1 percent) compared to 25.0 percent for Medicare-covered patients, 19.5 percent for privately insured patients, and 17.1 percent for the uninsured.

Readmission rates for schizophrenia are shown in figure 2. The highest readmission rates were seen for patients aged 18–44 years (22.6 percent) and 45–64 years (23.4 percent). Readmission rates for patients with an expected payer of Medicare (23.7 percent) and Medicaid (24.0 percent) were about 50 percent higher than for other patients (15.1–16.1 percent).

Readmission rates for acute and unspecified renal failure are depicted in figure 3. Readmission rates were similar for all adult age groups (19.0–22.1 percent), but again were substantially higher for patients with an expected payer of Medicare (22.7 percent) or covered by Medicaid (25.0 percent) than for other patients (13.3–17.0 percent).

Figure 4 shows readmission rates for diabetes mellitus with complications. The highest readmission rate was for patients aged 18–44 years (22.6 percent), followed closely by patients aged 65 years and older (20.6 percent) and 45–64 years (19.9 percent). Readmission rates were nearly identical for patients covered by Medicare (23.6 percent) and Medicaid (23.5 percent); these rates were about 70 percent higher than rates for the privately insured and uninsured (13.6–14.1 percent).

Finally, figure 5 depicts readmission rates for patients with an index stay during which their principal diagnosis was complication of device, implant, or graft. The highest readmission rate was for children aged 1–17 years (25.5 percent). Similarly, the readmission rate for Medicaid-covered patients was 25.4 percent; this rate was nearly 20 percent higher than rates for Medicare (21.4 percent) and over 60 percent higher than those for privately insured and uninsured patients (15.6–15.7 percent).

Overall, across select conditions with high volume (more than 300,000 index stays) and high readmission rates (at least 20 percent), the 30-day readmission rate varied by age group and condition. For some conditions (complication of device, implant or graft), children had a higher readmission rate than adults; for other conditions (schizophrenia and other psychotic conditions, diabetes with complications), children had a lower readmission rate than adults. In terms of payer, patients with Medicare and Medicaid coverage consistently had higher readmission rates than patients with private insurance or those who were uninsured.

## Data Source

The estimates in this Statistical Brief are based on a readmissions analysis file that was created with the Healthcare Cost and Utilization Project (HCUP) State Inpatient Databases (SID). These databases include reliable, verified synthetic patient identifiers that can be used to track a person across hospitals within a State. Estimates were taken from HCUPnet, the online query system that provides free access to information from HCUP: http://hcupnet.ahrq.gov/. HCUPnet provides access to health statistics and information on hospital inpatient and emergency department utilization, and it includes analytic tables using the readmissions analysis file. HCUPnet provides additional detailed results and sortable tables that provide instant information on readmissions to the hospital within 30 days of discharge.

For 2010, readmissions data were available from 18 States: Alaska, Arkansas, California, Florida, Georgia, Hawaii, Louisiana, Massachusetts, Mississippi, Missouri, Nebraska, New Mexico, New York, South Carolina, Tennessee, Utah, Virginia, and Washington. These 18 States are geographically dispersed and accounted for 46 percent of the total U.S. resident population and 45 percent of the total U.S. hospitalizations. The readmissions analysis file included 14.0 million unweighted discharges.

The study population in this readmissions analysis file included discharges from community, non-rehabilitation, non-specialty hospitals. Weights for national estimates were developed using poststratification on hospital characteristics (Census region, urban-rural location, teaching capabilities, bed size, and control/ownership) and patient age groups.

## Definitions

### Diagnoses, ICD-9-CM, and Clinical Classifications Software (CCS)

For the index stay, the diagnoses examined in this Statistical Brief are based on the CCS for the principal diagnosis. The principal diagnosis is that condition established after study to be chiefly responsible for the patient’s admission to the hospital.

ICD-9-CM is the International Classification of Diseases, Ninth Revision, Clinical Modification, which assigns numeric codes to diagnoses. There are approximately 14,000 ICD-9-CM diagnosis codes.

CCS categorizes ICD-9-CM diagnoses into a manageable number of clinically meaningful categories.^11^ This “clinical grouper” makes it easier to quickly understand patterns of diagnoses. CCS categories identified as “Other” typically are not reported; these categories include miscellaneous, otherwise unclassifiable diagnoses that may be difficult to interpret as a group.

### Readmissions

The 30-day readmission rate is defined as the number of admissions for each condition for which there was at least one subsequent hospital admission within 30 days divided by the total number of admissions from January through November 2010. That is, when patients are discharged from the hospital, they are followed for 30 days in the data. If any readmission to the same or different hospital occurs during this time period, the admission is counted as a readmission. No more than one readmission is counted within the 30-day period, because the outcome measure assessed here is “percentage of admissions who are readmitted.” If a patient was transferred to a different hospital on the same day or was transferred within the same hospital, the two events were combined as a single stay and the second event was not counted as a readmission; that is, transfers were not considered a readmission. In the case of admissions for which there was more than one readmission in the 30-day period, the data presented in this Statistical Brief reflect the characteristics and costs of the first readmission.

Every qualifying hospital stay is counted as a separate index (starting point) admission. Thus, a single patient can be counted multiple times during the course of the January through November observation period. In addition, index admissions do not require a prior “clean period” with no hospitalizations; that is, a hospital stay may be a readmission for a prior stay and the index admission for a subsequent readmission. Admissions were disqualified from the analysis as index admissions if they could not be followed for 30 days for one of the following reasons: (1) admissions in which the patient died in the hospital, (2) admissions missing information on length of stay, and (3) admissions discharged in December 2010.

### Types of hospitals included in HCUP

HCUP is based on data from community hospitals, which are defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). HCUP data include obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded are long-term care, rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals.

### Payer (Insurance Status)

Payer is the expected payer for the hospital stay. To make coding uniform across all HCUP data sources, payer combines detailed categories into more general groups:

– Medicare: includes patients covered by fee-for-service and managed care Medicare
– Medicaid: includes patients covered by fee-for-service and managed care Medicaid. Patients covered by the State Children’s Health Insurance Program (SCHIP) may be included here. Because most State data do not identify SCHIP patients specifically, it is not possible to present this information separately.
– Private Insurance: includes Blue Cross, commercial carriers, and private health maintenance organizations (HMOs) and preferred provider organizations (PPOs)
– Other: includes Worker’s Compensation, TRICARE/CHAMPUS, CHAMPVA, Title V, and other government programs
– Uninsured: includes expected primary payer of “self-pay” and “no charge.”

For this Statistical Brief, a hierarchy was used to assign the payer category based on the primary and secondary expected payer:

- If the primary or secondary expected payer indicates Medicare, then the payer category is assigned to Medicare. This categorization includes patients who are dually eligible for Medicare and Medicaid under Medicare.
- If not Medicare and the primary or secondary expected payer indicates Medicaid, then the payer category is Medicaid.
- If not Medicare or Medicaid and the primary or secondary expected payer indicates private insurance, then the payer category is private.
- If not Medicare, Medicaid, or private and the primary expected payer indicates self-pay or no charge, then the payer category is uninsured.
- Stays for other types of payers are not reported in this Statistical Brief because this is a mixed payer group and small numbers.

For this Statistical Brief, categorization of the readmission counts by expected payer was based on the index stay.

## For More Information

For more information about HCUP, visit http://www.hcup-us.ahrq.gov/.

For additional HCUP statistics, visit HCUPnet, our interactive query system, at http://hcupnet.ahrq.gov/. HCUPnet provides ready-to-use tables on readmission rates by condition and procedure (using Clinical Classification Software categories), diagnosis related groups (DRGs), and major diagnostic categories (MDCs).

1 Boutwell A, Jencks S. It’s Not Six of One, Half-Dozen of the Other: A Comparative Analysis of Three Rehospitalization Measurement Systems for Massachusetts. 2011 AcademyHealth Annual Research Meeting and National Quality Forum.

2 3M Health Information Systems. (2008). Potentially Preventable Readmissions Classification System, Methodology Overview, Document number GRP-139.

3 Hospital Compare. Medicare Web site.

4 Boutwell AE, Johnson MB, Rutherford P, Watson SR, Vecchioni N, Auerbach BS, Griswold P, Noga P, Wagner C. (2011). An early look at a four-state initiative to reduce avoidable hospital readmissions (http://www.ncbi.nlm.nih.gov/pubmed/21734200). Health Aff (Millwood).

5 (2011). Partnership for Patients: Better Care, Lower Costs.

6 Jencks SF, Williams MV, Coleman EA. (2009). Rehospitalizations among patients in the Medicare fee-for-service program. N Engl J Med.

7 Stranges E, Barrett ML, Wier LM, Andrews RM. (2012). Readmissions for Heart Attack, 2009. HCUP Statistical Brief #140.

8 Elixhauser A, Au D, Podulka J. (2011). Readmissions for Chronic Obstructive Pulmonary Disease, 2008. HCUP Statistical Brief #121.

9 http://hcupnet.ahrq.gov

10 Two additional conditions met these criteria; however, these conditions are the subject of separate HCUP Statistical Briefs. (Chronic obstructive pulmonary disease: http://www.hcup-us.ahrq.gov/reports/statbriefs/sb121.jsp and Septicemia: forthcoming in 2013).

11 HCUP Clinical Classifications Software (CCS). Healthcare Cost and Utilization Project (HCUP).

## Appendix

All-cause 30-day readmissions and costs for selected diagnoses,^*^ U.S. hospitals, 2010

Principal diagnosis for index hospital stay (Clinical Classification Software [CCS] diagnosis category number and label) | | Number of index stays | 30-day all-cause readmissions
Principal diagnosis for index hospital stay (Clinical Classification Software [CCS] diagnosis category number and label) | | Number of index stays | Number of readmissions | Percent readmitted
Infectious and Parasitic Diseases
1 | Tuberculosis | 5,064 | 653 | 12.9
2 | Septicemia (except in labor) | 696,122 | 145,896 | 21.0
3 | Bacterial infection, unspecified site | 5,654 | 721 | 12.8
4 | Mycoses | 23,026 | 6,222 | 27.0
5 | HIV infection | 34,958 | 9,230 | 26.4
6 | Hepatitis | 37,480 | 11,593 | 30.9
7 | Viral infections | 56,477 | 5,849 | 10.4
10 | Immunizations and screening for infectious diseases | 7,128 | 1,034 | 14.5
Neoplasms
11 | Cancer of head and neck | 28,530 | 6,020 | 21.1
12 | Cancer of esophagus | 11,054 | 3,170 | 28.7
13 | Cancer of stomach | 19,528 | 5,111 | 26.2
14 | Cancer of colon | 89,183 | 14,388 | 16.1
15 | Cancer of rectum and anus | 39,395 | 8,090 | 20.5
16 | Cancer of liver and intrahepatic bile duct | 17,980 | 5,077 | 28.2
17 | Cancer of pancreas | 31,054 | 8,512 | 27.4
18 | Cancer of other GI organs, peritoneum | 18,461 | 4,379 | 23.7
19 | Cancer of bronchus, lung | 117,172 | 24,893 | 21.2
21 | Cancer of bone and connective tissue | 12,242 | 3,307 | 27.0
24 | Cancer of breast | 76,838 | 6,120 | 8.0
25 | Cancer of uterus | 35,278 | 3,923 | 11.1
26 | Cancer of cervix | 16,090 | 2,457 | 15.3
27 | Cancer of ovary | 22,064 | 4,753 | 21.5
28 | Cancer of other female genital organs | 6,132 | 1,025 | 16.7
29 | Cancer of prostate | 82,794 | 5,016 | 6.1
32 | Cancer of bladder | 30,244 | 6,465 | 21.4
33 | Cancer of kidney and renal pelvis | 42,028 | 5,074 | 12.1
35 | Cancer of brain and nervous system | 32,382 | 6,649 | 20.5
36 | Cancer of thyroid | 22,335 | 1,494 | 6.7
38 | Non-Hodgkin’s lymphoma | 34,769 | 12,712 | 36.6
39 | Leukemias | 31,157 | 13,008 | 41.8
40 | Multiple myeloma | 15,427 | 4,381 | 28.4
41 | Cancer, other primary | 6,146 | 1,781 | 29.0
42 | Secondary malignancies | 177,796 | 44,647 | 25.1
43 | Malignant neoplasm without specification of site | 6,636 | 1,670 | 25.2
44 | Neoplasms of unspecified nature or uncertain behavior | 42,002 | 9,551 | 22.7
45 | Maintenance chemotherapy, radiotherapy | 126,113 | 82,601 | 65.5
46 | Benign neoplasm of uterus | 156,836 | 6,186 | 3.9
Endocrine, Nutritional, and Metabolic Diseases and Immunity Disorders
48 | Thyroid disorders | 40,936 | 3,072 | 7.5
49 | Diabetes mellitus without complication | 20,776 | 1,776 | 8.5
50 | Diabetes mellitus with complications | 480,958 | 97,784 | 20.3
52 | Nutritional deficiencies | 9,845 | 2,355 | 23.9
54 | Gout and other crystal arthropathies | 17,506 | 2,710 | 15.5
55 | Fluid and electrolyte disorders | 396,551 | 73,721 | 18.6
56 | Cystic fibrosis | 10,518 | 1,366 | 13.0
Diseases of Blood and Blood-Forming Organs
59 | Anemia | 203,098 | 42,374 | 20.9
60 | Acute posthemorrhagic anemia | 27,199 | 5,239 | 19.3
61 | Sickle cell anemia | 87,326 | 27,837 | 31.9
62 | Coagulation and hemorrhagic disorders | 33,397 | 7,920 | 23.7
63 | Disease of white blood cells | 54,861 | 16,771 | 30.6
Mental Disorders
650 | Adjustment disorders | 49,073 | 3,980 | 8.1
651 | Anxiety disorders | 45,102 | 5,519 | 12.2
652 | Attention-deficit, conduct, and disruptive behavior disorders | 18,218 | 1,692 | 9.3
653 | Delirium, dementia, and amnestic and other cognitive disorders | 131,003 | 21,566 | 16.5
655 | Disorders diagnosed in infancy, childhood, or adolescence | 5,613 | 753 | 13.4
656 | Impulse control disorders, NEC | 12,204 | 1,652 | 13.5
657 | Mood disorders | 883,245 | 131,125 | 14.8
658 | Personality disorders | 5,436 | 1,316 | 24.2
659 | Schizophrenia and other psychotic disorders | 397,166 | 88,629 | 22.3
660 | Alcohol-related disorders | 245,289 | 45,033 | 18.4
661 | Substance-related disorders | 212,612 | 32,050 | 15.1
663 | Screening and history of mental health and substance abuse | 60,417 | 15,695 | 26.0
670 | Miscellaneous mental disorders | 43,193 | 4,189 | 9.7
Diseases of Nervous System and Sense Organs
76 | Meningitis | 32,909 | 2,565 | 7.8
77 | Encephalitis | 8,487 | 1,219 | 14.4
79 | Parkinson’s disease | 13,089 | 2,118 | 16.2
80 | Multiple sclerosis | 21,708 | 2,529 | 11.6
82 | Paralysis | 7,394 | 987 | 13.3
83 | Epilepsy, convulsions | 252,200 | 31,965 | 12.7
84 | Headache, including migraine | 70,782 | 7,373 | 10.4
85 | Coma, stupor, and brain damage | 16,823 | 2,740 | 16.3
89 | Blindness and vision defects | 5,364 | 521 | 9.7
90 | Inflammation, infection of eye | 15,984 | 1,201 | 7.5
92 | Otitis media and related conditions | 9,855 | 738 | 7.5
93 | Conditions associated with dizziness or vertigo | 69,022 | 4,964 | 7.2
Diseases of the Circulatory System
96 | Heart valve disorders | 100,327 | 20,613 | 20.5
97 | Peri-, endo-, and myocarditis, cardiomyopathy | 66,648 | 11,986 | 18.0
98 | Essential hypertension | 72,930 | 7,721 | 10.6
99 | Hypertension with complications and secondary hypertension | 211,243 | 45,309 | 21.4
100 | Acute myocardial infarction | 520,901 | 85,932 | 16.5
101 | Coronary atherosclerosis | 666,897 | 90,147 | 13.5
102 | Nonspecific chest pain | 601,899 | 61,465 | 10.2
103 | Pulmonary heart disease | 162,269 | 25,599 | 15.8
105 | Conduction disorders | 58,074 | 6,386 | 11.0
106 | Cardiac dysrhythmias | 705,616 | 104,607 | 14.8
107 | Cardiac arrest and ventricular fibrillation | 8,063 | 1,398 | 17.3
108 | Congestive heart failure, nonhypertensive | 847,073 | 209,017 | 24.7
109 | Acute cerebrovascular disease | 520,793 | 71,174 | 13.7
110 | Occlusion or stenosis of precerebral arteries | 111,833 | 11,877 | 10.6
112 | Transient cerebral ischemia | 166,904 | 16,436 | 9.8
113 | Late effects of cerebrovascular disease | 18,829 | 2,981 | 15.8
114 | Peripheral and visceral atherosclerosis | 162,792 | 28,031 | 17.2
115 | Aortic, peripheral, and visceral artery aneurysms | 73,143 | 11,247 | 15.4
116 | Aortic and peripheral arterial embolism or thrombosis | 26,104 | 5,381 | 20.6
118 | Phlebitis, thrombophlebitis and thromboembolism | 154,023 | 23,640 | 15.3
120 | Hemorrhoids | 30,467 | 4,003 | 13.1
Diseases of the Respiratory System
122 | Pneumonia | 924,160 | 144,894 | 15.7
123 | Influenza | 10,284 | 776 | 7.5
124 | Acute and chronic tonsillitis | 31,874 | 1,097 | 3.4
125 | Acute bronchitis | 78,848 | 7,461 | 9.5
127 | Chronic obstructive pulmonary disease and bronchiectasis | 606,186 | 126,443 | 20.9
128 | Asthma | 347,404 | 41,320 | 11.9
129 | Aspiration pneumonitis, food/vomitus | 147,837 | 31,772 | 21.5
130 | Pleurisy, pneumothorax, pulmonary collapse | 101,298 | 21,485 | 21.2
131 | Respiratory failure, insufficiency, arrest (adult) | 260,781 | 59,842 | 22.9
132 | Lung disease due to external agents | 5,477 | 966 | 17.6
Diseases of the Digestive System
135 | Intestinal infection | 207,083 | 36,451 | 17.6
136 | Disorders of teeth and jaw | 25,722 | 1,621 | 6.3
137 | Disease of mouth, excluding dental | 19,009 | 1,966 | 10.3
138 | Esophageal disorders | 125,280 | 16,921 | 13.5
139 | Gastroduodenal ulcer (except hemorrhage) | 42,462 | 6,170 | 14.5
140 | Gastritis and duodenitis | 99,130 | 15,355 | 15.5
142 | Appendicitis and other appendiceal conditions | 262,024 | 12,875 | 4.9
143 | Abdominal hernia | 174,459 | 19,885 | 11.4
144 | Regional enteritis and ulcerative colitis | 94,732 | 17,579 | 18.6
145 | Intestinal obstruction without hernia | 315,128 | 51,135 | 16.2
146 | Diverticulosis and diverticulitis | 289,097 | 35,461 | 12.3
147 | Anal and rectal conditions | 47,035 | 5,326 | 11.3
148 | Peritonitis and intestinal abscess | 25,219 | 6,315 | 25.0
149 | Biliary tract disease | 430,988 | 48,062 | 11.2
152 | Pancreatic disorders (not diabetes) | 282,159 | 49,936 | 17.7
153 | Gastrointestinal hemorrhage | 320,613 | 54,154 | 16.9
154 | Noninfectious gastroenteritis | 144,507 | 17,262 | 11.9
Diseases of the Genitourinary System
156 | Nephritis, nephrosis, renal sclerosis | 7,561 | 1,473 | 19.5
157 | Acute and unspecified renal failure | 326,586 | 70,756 | 21.7
158 | Chronic renal failure | 17,394 | 4,766 | 27.4
159 | Urinary tract infections | 522,921 | 84,858 | 16.2
160 | Calculus of urinary tract | 154,073 | 15,938 | 10.3
163 | Genitourinary symptoms and ill-defined conditions | 32,102 | 5,711 | 17.8
164 | Hyperplasia of prostate | 55,298 | 5,505 | 10.0
165 | Inflammatory conditions of male genital organs | 23,662 | 2,344 | 9.9
167 | Nonmalignant breast conditions | 19,482 | 1,668 | 8.6
168 | Inflammatory disease of female pelvic organs | 38,989 | 3,225 | 8.3
169 | Endometriosis | 33,918 | 1,621 | 4.8
170 | Prolapse of female genital organs | 105,048 | 2,847 | 2.7
171 | Menstrual disorders | 87,633 | 4,311 | 4.9
172 | Ovarian cyst | 36,491 | 2,374 | 6.5
173 | Menopausal disorders | 9,602 | 654 | 6.8
Complications of Pregnancy, Childbirth, and the Puerperium
180 | Ectopic pregnancy | 20,948 | 784 | 3.7
182 | Hemorrhage during pregnancy, abruptio placenta, placenta previa | 46,191 | 6,847 | 14.8
183 | Hypertension complicating pregnancy, childbirth and the puerperium | 230,927 | 22,091 | 9.6
184 | Early or threatened labor | 179,175 | 37,797 | 21.1
185 | Prolonged pregnancy | 250,122 | 3,591 | 1.4
186 | Diabetes or abnormal glucose tolerance complicating pregnancy | 84,725 | 5,384 | 6.4
187 | Malposition, malpresentation | 132,312 | 2,918 | 2.2
188 | Fetopelvic disproportion, obstruction | 65,609 | 1,255 | 1.9
189 | Previous C-section | 462,378 | 7,046 | 1.5
190 | Fetal distress and abnormal forces of labor | 170,752 | 3,893 | 2.3
191 | Polyhydramnios and other problems of amniotic cavity | 179,406 | 7,028 | 3.9
192 | Umbilical cord complication | 161,112 | 1,284 | 0.8
193 | Trauma to perineum and vulva | 610,073 | 5,046 | 0.8
196 | Normal pregnancy and/or delivery | 208,463 | 1,559 | 0.7
Diseases of the Skin and Subcutaneous Tissue
197 | Skin and subcutaneous tissue infections | 576,902 | 64,680 | 11.2
199 | Chronic ulcer of skin | 50,845 | 10,823 | 21.3
Diseases of the Musculoskeletal System and Connective Tissue
201 | Infective arthritis and osteomyelitis | 70,424 | 12,199 | 17.3
202 | Rheumatoid arthritis and related disease | 14,836 | 1,587 | 10.7
203 | Osteoarthritis | 872,661 | 42,241 | 4.8
205 | Spondylosis, intervertebral disc disorders, other back problems | 579,103 | 47,774 | 8.2
207 | Pathological fracture | 59,946 | 11,781 | 19.7
210 | Systemic lupus erythematosus and connective tissue disorders | 18,850 | 5,123 | 27.2
Congenital Anomalies
213 | Cardiac and circulatory congenital anomalies | 23,824 | 2,610 | 11.0
214 | Digestive congenital anomalies | 6,100 | 626 | 10.3
215 | Genitourinary congenital anomalies | 7,480 | 729 | 9.7
Injury and Poisoning
225 | Joint disorders and dislocations, trauma-related | 31,027 | 2,222 | 7.2
226 | Fracture of neck of femur (hip) | 291,847 | 38,668 | 13.2
227 | Spinal cord injury | 13,188 | 1,609 | 12.2
228 | Skull and face fractures | 45,409 | 3,164 | 7.0
229 | Fracture of upper limb | 136,326 | 10,895 | 8.0
230 | Fracture of lower limb | 234,607 | 23,540 | 10.0
232 | Sprains and strains | 29,538 | 2,356 | 8.0
233 | Intracranial injury | 162,589 | 18,304 | 11.3
234 | Crushing injury or internal injury | 85,422 | 7,744 | 9.1
235 | Open wounds of head, neck, and trunk | 29,547 | 2,028 | 6.9
236 | Open wounds of extremities | 38,921 | 2,847 | 7.3
237 | Complication of device, implant or graft | 596,062 | 121,036 | 20.3
238 | Complications of surgical procedures or medical care | 453,266 | 81,353 | 17.9
239 | Superficial injury, contusion | 40,973 | 4,975 | 12.1
240 | Burns | 34,452 | 3,431 | 10.0
241 | Poisoning by psychotropic agents | 60,590 | 6,496 | 10.7
242 | Poisoning by other medications and drugs | 107,558 | 13,426 | 12.5
243 | Poisoning by nonmedicinal substances | 15,356 | 1,121 | 7.3
Symptoms, Signs, and Ill-Defined Conditions
245 | Syncope | 235,483 | 24,686 | 10.5
246 | Fever of unknown origin | 53,785 | 9,322 | 17.3
247 | Lymphadenitis | 13,632 | 1,242 | 9.1
248 | Gangrene | 33,786 | 10,693 | 31.6
250 | Nausea and vomiting | 51,833 | 11,854 | 22.9
251 | Abdominal pain | 166,071 | 26,993 | 16.3
252 | Malaise and fatigue | 33,141 | 6,054 | 18.3
253 | Allergic reactions | 23,860 | 2,482 | 10.4
254 | Rehabilitation care, fitting of prostheses, adjustment of devices | 47,035 | 5,008 | 10.6

Source: Weighted national estimates from a readmissions analysis file derived from the Healthcare Cost and Utilization Project (HCUP) State Inpatient Databases (SID), 2010, Agency for Healthcare Research and Quality (AHRQ).

* Information is provided for diagnoses with 5,000 or more weighted index stays and 500 or more weighted readmissions. See text and Definitions for details on methods for calculating readmissions.