# Statistical Brief #151 Trends in Potentially Preventable Hospital Admissions among Adults and Children, 2005–2010

## Introduction

Improving the quality of health care while simultaneously containing costs continues to be a major priority for the nation, particularly for policymakers and public and private payers. One area where higher quality and lower costs coincide is potentially preventable hospital admissions—inpatient stays that could be prevented with high-quality primary and preventive care. High rates of these potentially preventable hospital admissions identify areas where possible improvements in the health care delivery system could be made to enhance patient outcomes and decrease costs. Positive changes in these rates over time may signal an improvement in the quality of ambulatory care, in access to timely and effective treatment of certain conditions for specific populations, or in patients’ adoption of healthy behaviors.

This Statistical Brief presents data from the Healthcare Cost and Utilization Project (HCUP) on changes in the rates of potentially preventable hospital admissions and their associated total hospital costs. It updates statistics previously reported for the 1997 through 2004 time period.^1^ Admission rates for selected chronic and acute conditions in adults and children for 2005 through 2010 were developed using the Agency for Healthcare Research and Quality (AHRQ) Prevention Quality Indicators (PQIs). The conditions examined for adults aged 18 years and older were related to diabetes, circulatory diseases, chronic respiratory diseases, and select acute conditions (bacterial pneumonia, dehydration, and urinary tract infection). The conditions examined for children younger than 18 years were diabetes, asthma, gastroenteritis, and urinary tract infection. All differences between estimates noted in the text are significant at the 0.05 level or better.

## Findings

Highlights

■ The total number of potentially preventable hospital admissions for adults and children decreased 6.2 percent and nearly 40 percent, respectively, between 2005 and 2010. The corresponding total hospital costs for adult and pediatric conditions decreased 2 percent and 32 percent, respectively.
■ For the same time period, rates of potentially preventable hospital admissions increased for short-term diabetes complications (23 percent) and hypertension (33 percent). The total hospital costs for these conditions increased by 32 percent and 62 percent, respectively.
■ The largest decreases in potentially preventable hospital admission rates between 2005 and 2010 were seen for angina without a procedure (50 percent), congestive heart failure (21 percent), bacterial pneumonia (30 percent), and dehydration (38 percent). Corresponding total hospital costs were reduced by more than 10 percent.
■ For children, the largest decrease in potentially preventable hospital admission rates between 2005 and 2010 were seen for pediatric gastroenteritis (64 percent) and pediatric urinary tract infection (19 percent). Related costs decreased 55% and 21%, respectively.

For the conditions examined here, the number of potentially preventable hospital admissions for adults decreased 6.2 percent from 4.1 million stays in 2005 to 3.9 million stays in 2010. Total hospital costs related to these potentially preventable admissions for adults decreased only 2 percent from $32.6 billion in 2005 to $31.9 billion in 2010.

The total number of potentially preventable hospital admissions for children decreased considerably more than those for adults—nearly 40 percent from approximately 300,000 to 185,000. The corresponding hospital costs declined about 32 percent.

### Changes in potentially preventable hospital admissions among adults with diabetes

Changes in hospital admission rates for adults with diabetes varied between 2005 and 2010 (figure 1). Between 2005 and 2010, there were no statistically significant changes in rates for long-term diabetes complications (i.e., renal, visual, neurological, and circulatory disorders), for diabetes-related lower extremity amputations, or for uncontrolled diabetes without complications. In contrast, rates for short-term diabetes complications (i.e., diabetic ketoacidosis, hyperosmolarity, and coma) significantly increased 23 percent.

Figure 1 Rates of hospital admissions for diabetes, adults older than 18 years

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2005–2010

* Differences in rates of admission between 2005 and 2010 for short-term diabetes complications were statistically significant at p<0.05. Rates were adjusted for patient age and sex.

Figure 1. Rates of admissions for diabetes, adults older than 18 years. Trendline chart; Long-term diabetes; 2005, 122; 2006, 127; 2007, 123; 2008, 121; 2009, 114; 2010, 116; Short-term diabetes*; 2005, 56; 2006, 60; 2007, 60; 2008, 61; 2009, 64; 2010, 69; Diabetes-related lower extremity amputations; 2005, 35; 2006, 35; 2007, 33; 2008, 33; 2009, 32; 2010, 33; Uncontrolled diabetes without complications; 2005, 20; 2006, 22; 2007, 21; 2008, 22; 2009, 22; 2010, 19; Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2005–2010. *Differences in rates of admission between 2005 and 2010 for short-term diabetes complications were statistically significant at p<0.05. Rates were adjusted for patient age and sex.

Total hospital costs (table 1) for potentially preventable hospital admissions related to diabetes increased nearly 12 percent from $5.7 billion in 2005 to $6.4 billion in 2010. The greatest increase in total hospital costs was for short-term diabetes complications, which increased 32 percent during this 6-year time period.

Table 1 Total hospital costs for preventable conditions, 2005 and 2010

Preventable conditions | Total hospital costs^*^ (in millions) | | Comparison between 2005–2010 (percentage change)
| 2005 | 2010
Adults (18 years and older) | $32,585 | $31,871 | −2.2%
Diabetes | $5,714 | $6,355 | +11.9%
Uncontrolled diabetes without Complications | $214 | $230^†^ | +7.5%
Short-term diabetes complications | $888 | $1,168^†^ | +31.5%
Long-term diabetes complications | $2,988 | $3,192 | +6.8%
Diabetes-related lower extremity amputations | $1,624 | $1,765^†^ | +8.7%
Circulatory diseases | $9,192 | $8,562 | −6.9%
Angina without procedure | $403 | $254^†^ | −37.0%
Congestive heart failure | $8,240 | $7,420^†^ | −10.0%
Hypertension | $549 | $888^†^ | +61.7%
Chronic respiratory diseases | $5,489 | $6,115 | +11.4%
Asthma | $1,781 | $1,906^†^ | +7.0%
Chronic obstructive pulmonary disease | $3,708 | $4,209^†^ | +13.5%
Acute conditions | $12,190 | $10,839 | −11.1%
Bacterial pneumonia | $8,115 | $6,723^†^ | −17.2%
Dehydration | $1,572 | $1,068^†^ | −32.1%
Urinary tract infection | $2,503 | $3,048^†^ | +21.8%
Children (Less than 18 years old) | $941 | $644 | −31.6%
Short-term diabetes complications (6–17 years) | $94 | $71^†^ | −24.5%
Pediatric asthma (2–17 years) | $381 | $315^†^ | −17.3%
Pediatric gastroenteritis (3 months to 17 years) | $326 | $148^†^ | −54.6%
Urinary tract infection (3 months to 17 years) | $140 | $110^†^ | −21.4%

* All costs are adjusted to 2010 dollars using the overall Consumer Price Index.

† p<0.05

### Changes in potentially preventable hospital admissions among adults with circulatory diseases

Between 2005 and 2010, potentially preventable hospital admission rates related to circulatory diseases in adults showed significant changes—some increasing and some decreasing (figure 2). For hypertension, the admission rate increased 33 percent. In contrast, the admission rates for angina without a procedure and for congestive heart failure decreased 49 percent and 21 percent, respectively.

Figure 2 Rates of hospital admissions for circulatory diseases, adults 18 years and older

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2005–2010

* All differences in rates of admission between 2005 and 2010 were statistically significant at p<0.05. Rates were adjusted for patient age and sex.

Figure 2. Rates of admissions for circulatory diseases, adults 18 years and older. Trendline chart; Congestive heart failure*; 2005, 422; 2006, 414; 2007, 382; 2008, 370; 2009, 362; 2010, 322; Hypertension*; 2005, 46; 2006, 51; 2007, 61; 2008, 59; 2009, 61; 2010, 62; Angina without procedure*; 2005, 36; 2006, 34; 2007, 29; 2008, 23; 2009, 22; 2010, 19; Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2005–2010. *All differences in rates of admission between 2005 and 2010 were statistically significant at p<0.05. Rates were adjusted for patient age and sex.

Between 2005 and 2010, the total hospital costs for potentially preventable circulatory disease admissions decreased about 7 percent (table 1). Total hospital costs for angina without a procedure decreased 37 percent, congestive heart failure costs decreased 10 percent, and hypertension hospitalization costs increased 62 percent.

### Changes in potentially preventable hospital admissions among adults with chronic respiratory diseases

Between 2005 and 2010, admission rates for adult asthma and chronic obstructive pulmonary disease (COPD) remained stable (figure 3), while costs increased. For asthma, the total hospital costs increased 7 percent; costs for COPD increased 14 percent (table 1).

Figure 3 Rates of hospital admissions for chronic respiratory diseases, adults 18 years and older

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2005–2010.

Both differences in rates of admission between 2005 and 2010 were not statistically significant at p<0.05. Rates were adjusted for patient age and sex.

Figure 3. Rates of admissions for chronic respiratory diseases, adults 18 years and older. Trendline chart; Long-term diabetes; 2005, 214; 2006, 199; 2007, 193; 2008, 229; 2009, 227; 2010, 213; Short-term diabetes*; 2005, 127; 2006, 124; 2007, 118; 2008, 125; 2009, 131; 2010, 119; Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2005–2010. Both differences in rates of admission between 2005 and 2010 were statistically significant at p<0.05. Rates were adjusted for patient age and sex.

### Changes in potentially preventable hospital admissions among adults with select acute conditions

Changes in hospitalization rates for potentially preventable hospital admissions among adults with acute conditions such as bacterial pneumonia, dehydration, and urinary tract infections varied widely between 2005 and 2010 (figure 4). The admission rate for bacterial pneumonia decreased 30 percent, whereas the rate for dehydration decreased 38 percent. In contrast, the rate for urinary tract infection showed a small but statistically significant 8 percent increase.

Figure 4 Rates of hospital admissions for acute conditions, adults 18 years and older

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2005–2010.

* All differences in rates of admission between 2005 and 2010 were statistically significant at p<0.05. Rates were adjusted for patient age and sex.

Figure 4. Rates of admissions for acute conditions, adults 18 years and older. Trendline chart; Bacterial Pneumonia*; 2005, 419; 2006, 370; 2007, 360; 2008, 340; 2009, 325; 2010, 296; Dehydration*; 2005, 180; 2006, 180; 2007, 184; 2008, 195; 2009, 193; 2010, 194; Urinary tract infection*; 2005, 118; 2006, 105; 2007, 104; 2008, 104; 2009, 88; 2010, 73; Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2005–2010. *All differences in rates of admission between 2005 and 2010 were statistically significant at p<0.05. Rates were adjusted for patient age and sex.

Between 2005 and 2010, total hospital costs decreased 17 percent for bacterial pneumonia and 32 percent for dehydration (table 1). Costs for urinary tract infection increased 22 percent.

### Changes in potentially preventable hospital admissions among children for select conditions

Between 2005 and 2010, pediatric potentially preventable hospital admissions for short-term diabetes complications and asthma did not change significantly (figure 5). Admission rates for pediatric gastroenteritis between 2005 and 2010 decreased 64 percent; rates for pediatric urinary tract infection decreased 19 percent (figure 5).

Figure 5 Rates of hospital admissions for pediatric preventable conditions

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2010

* The difference in rates of admission is statistically significant at p<0.05.

Figure 5. Rates of admissions for pediatric preventable conditions. Trendline chart; Pediatric gastroenteritis (3 months to 17 years)*; 2005, 190; 2006, 181; 2007, 139; 2008, 98; 2009, 99; 2010, 69; Pediatric asthma (2 to 17 years); 2005, 165; 2006, 144; 2007, 132; 2008, 118; 2009, 145; 2010, 130; Urinary tract infection (3 months to 17 years)*; 2005, 49; 2006, 45; 2007, 41; 2008, 41; 2009, 40; 2010, 40; Short-term diabetes complications (6 to 17 years); 2005, 36; 2006, 32; 2007, 29; 2008, 26; 2009, 28; 2010, 29; Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2005–2010. *Differences in rates of admission between 2005 and 2010 for gastroenteritis and urinary tract infection were statistically significant at p<0.05. Rates were adjusted for patient age and sex.

Total hospital costs for short-term diabetes complications among children decreased 25 percent (table 1). Similarly, total hospital costs for pediatric asthma decreased 17 percent, pediatric gastroenteritis costs decreased 55 percent, and urinary tract infection costs decreased 21 percent.

## Data Source

The estimates in this Statistical Brief are based upon data from the Healthcare Cost and Utilization Project (HCUP) 2010 Nationwide Inpatient Sample (NIS). Historical data were drawn from the 2005–2010 NIS. The statistics were generated from HCUPnet, a free, online query system that provides users with immediate access to the largest set of publicly available, all-payer national, regional, and State-level hospital care databases from HCUP.

## Definitions

### Types of hospitals included in HCUP

HCUP is based on data from community hospitals, defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). HCUP data include obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded are long-term care, rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. However, if a patient received long-term care, rehabilitation, or treatment for psychiatric or chemical dependency conditions in a community hospital, the discharge record for that stay will be included in the NIS.

### Unit of analysis

The unit of analysis is the hospital discharge (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the hospital multiple times in one year will be counted each time as a separate “discharge” from the hospital.

### Costs and charges

Total hospital charges were converted to costs using HCUP Cost-to-Charge Ratios based on hospital accounting reports from the Centers for Medicare & Medicaid Services (CMS).^2^Costs will reflect the actual expenses incurred in the production of hospital services, such as wages, supplies, and utility costs; charges represent the amount a hospital billed for the case. For each hospital, a hospital-wide cost-to-charge ratio is used. Hospital charges reflect the amount the hospital billed for the entire hospital stay and do not include professional (physician) fees. For the purposes of this Statistical Brief, costs are reported to the nearest hundred.

Mean cost per day is calculated as the mean cost per stay divided by the mean length of stay.

### Prevention Quality Indicators

The Prevention Quality Indicators (PQIs; version 4.1), a component of the AHRQ Quality Indicators (QIs), are a set of measures that can be used with hospital inpatient discharge data to identify access to and quality of care for “ambulatory care-sensitive conditions.” These are conditions for which good outpatient care can potentially prevent the need for hospitalization or for which early intervention can prevent complications or more severe disease. PQI rates can also be affected by other factors such as disease prevalence. The PQIs are adjusted for age and sex.

Further information on the AHRQ QIs, including documentation and free software downloads, is available at http://www.qualityindicators.ahrq.gov/. It also includes information on the Pediatric Quality Indicators (PDIs, formerly referred to as PedQIs), which includes measures of potentially preventable hospitalizations for children for asthma, gastroenteritis, diabetes short-term complications, and perforated appendix. Additional information on how the QI software was applied to the HCUP data for the statistics reported in this Statistical Brief is available in Coffey, et al., 2012^3^.

## For More Information

For more information about HCUP, visit http://www.hcup-us.ahrq.gov/.

For additional HCUP statistics, visit HCUPnet, our interactive query system, at http://hcupnet.ahrq.gov/.

For information on other hospitalizations in the United States, download HCUP Facts and Figures: Statistics on Hospital-Based Care in the United States in 2009, located at http://www.hcupus.ahrq.gov/reports.jsp.

For a detailed description of HCUP, more information on the design of the NIS, and methods to calculate estimates, please refer to the following publications:

Introduction to the HCUP Nationwide Inpatient Sample, 2009. Online. May 2011. U.S. Agency for Healthcare Research and Quality. Available at http://hcup-us.ahrq.gov/db/nation/nis/NIS_2009_INTRODUCTION.pdf. (Accessed January 29, 2013).

Houchens RL, Elixhauser A. Using the HCUP Nationwide Inpatient Sample to Estimate Trends. (Updated for 1988–2004). HCUP Methods Series Report #2006–05. Online. August 18, 2006. U.S. Agency for Healthcare Research and Quality. Available at http://www.hcup-us.ahrq.gov/reports/methods/2006_05_NISTrendsReport_1988-2004.pdf. (Accessed January 29, 2013).

Coffey R, Barrett, M, Houchens R, Moy E, Andrews R, Coenen N. Methods Applying AHRQ Quality Indicators to Healthcare Cost and Utilization Project (HCUP) Data for the Eleventh (2013) National Healthcare Quality Report (NHQR) and National Healthcare Disparities Report (NHDR). HCUP Methods Series Report #2012-03. U.S. Agency for Healthcare Research and Quality. Available: http://www.hcupus.ahrq.gov/reports/methods/methods.jsp. (Accessed March 7, 2013).

1 Russo CA, Jiang HJ, Barrett M. Trends in Potentially Preventable Hospitalizations among Adults and Children, 1997–2004. HCUP Statistical Brief #36. August 2007. Agency for Healthcare Research and Quality, Rockville, MD. http://www.hcupus.ahrq.gov/reports/statbriefs/sb36.pdf (Accessed March 12, 2013).

2 HCUP Cost-to-Charge Ratio Files (CCR). Healthcare Cost and Utilization Project (HCUP). 2001–2009. U.S. Agency for Healthcare Research and Quality, Rockville, MD. Available at http://www.hcup-us.ahrq.gov/db/state/costtocharge.jsp. Updated August 2011. (Accessed March 6, 2013).

3 Coffey R, Barrett, M, Houchens R, Moy E, Andrews R, Coenen N. Methods Applying AHRQ Quality Indicators to Healthcare Cost and Utilization Project (HCUP) Data for the Eleventh (2013) National Healthcare Quality Report (NHQR) and National Healthcare Disparities Report (NHDR). HCUP Methods Series Report #2012-03. U.S. Agency for Healthcare Research and Quality. Available: http://www.hcup-us.ahrq.gov/reports/methods/methods.jsp. (Accessed March 12, 2013).