# Statistical Brief #149 Most Frequent Procedures Performed in U.S. Hospitals, 2010

## Introduction

Most hospitalizations involve one or more procedures, which can range from simple vaccinations to complex surgical procedures. The principal procedure is the procedure that is performed for definitive treatment (e.g., an appendectomy), but procedures can also be performed to make a diagnosis (e.g., tissue samples or exploratory surgery). Hospitalizations usually involve more than one procedure, which together constitute the all-listed procedures performed during a hospital stay.

This Statistical Brief presents data from the Healthcare Cost and Utilization Project (HCUP) on the most common all-listed procedures performed during hospital stays in the United States in 2010, overall and by patient age. Changes between 1997 and 2010 in the number of stays and the rate of hospitalization in the population are presented for hospital stays with the most common procedures performed in 2010. All differences between estimates noted in the text are statistically significant at the .001 level or better.

## Findings

Highlights

■ Medical procedures were performed in 63 percent of the 39 million U.S. hospital stays in 2010.
■ The rate of hospitalization with procedures has remained relatively stable at about 800 per 10,000 population from 1997 to 2010.
■ Blood transfusion was the most common procedure performed during hospitalizations in 2010 (11 percent of hospital stays with a procedure), and it was common among all age groups except infants.
■ The most common types of procedures performed during hospitalizations in 2010 were associated with maternal and newborn stays or cardiovascular and musculoskeletal conditions.
■ Cesarean section was the most common major operating room procedure performed and the rate of hospitalization with Cesarean section increased by 41 percent between 1997 and 2010.
■ Although diagnostic cardiac catheterization was the fifth most common procedure in 2010, the rate of hospitalization with this procedure decreased 23 percent since 1997.
■ Rates of hospitalization with knee replacement and spinal fusion approximately doubled between 1997 and 2010.
■ Indwelling catheter was the most rapidly growing procedure between 1997 and 2010—the rate of hospitalization with this procedure more than tripled.

### Most frequent all-listed procedures performed during hospital stays, 2010

Table 1 shows the most frequent all-listed procedures performed during hospital stays in 2010, as well as the change in the rate of hospitalizations with these procedures since 1997. Procedures were performed in 63 percent of the 39 million hospital stays in the United States in 2010. The rate of hospitalizations with procedures has remained relatively stable at about 800 per 10,000 population from 1997 to 2010.

Table 1 Number of stays, stays per 10,000 population, and percentage change in rate of the most frequent all-listed procedures for hospital stays, 1997 and 2010

All-listed CCS procedures | Number of stays with the procedure in thousands | | Stays with the procedure per 10,000 population (rate) | | Percentage change in rate
All-listed CCS procedures | 1997 | 2010 | 1997 | 2010 | 1997–2010
All stays (with and without procedures) | 34,681 | 39,008 | 1,272 | 1,261 | −1%
All stays with any procedure | 21,257 | 24,740 | 780 | 800 | 3%
Percentage of all stays with a procedure | 61% | 63%
Blood transfusion | 1,098 | 2,815 | 40 | 91 | 126%
Prophylactic vaccinations and inoculations | 567 | 1,837 | 21 | 59 | 185%
Respiratory intubation and mechanical ventilation | 919 | 1,638 | 34 | 53 | 57%
Repair of current obstetric laceration | 1,137 | 1,292 | 42 | 42 | 0%
Diagnostic cardiac catheterization; coronary arteriography | 1,461 | 1,283 | 54 | 41 | −23%
Cesarean section | 800 | 1,278 | 29 | 41 | 41%
Upper gastrointestinal endoscopy; biopsy | 1,105 | 1,206 | 41 | 39 | −4%
Circumcision | 1,164 | 1,150 | 43 | 37 | −13%
Artificial rupture of membranes to assist delivery | 853^*^ | 917 | 31 | 30 | −5%
Fetal monitoring | 1,002 | 875 | 37 | 28 | −23%
Diagnostic ultrasound of heart (echocardiogram) | 632 | 858 | 23 | 28 | 20%
Hemodialysis | 473 | 850 | 17 | 27 | 58%
Arthroplasty knee | 329 | 730 | 12 | 24 | 96%
Enteral and parenteral nutrition | 277 | 613 | 10 | 20 | 95%
Percutaneous transluminal coronary angioplasty (PTCA) | 581 | 562 | 21 | 18 | −15%
Laminectomy; excision intervertebral disc | 425 | 532 | 16 | 17 | 10%
Colonoscopy and biopsy | 531 | 528 | 19 | 17 | −12%
Spinal fusion | 202 | 492 | 7 | 16 | 115%
Incision of pleura; thoracentesis; chest drainage | 349 | 475 | 13 | 15 | 20%
Hip replacement; total and partial | 291 | 456 | 11 | 15 | 38%

CCS: Clinical Classifications Software

* The number of stays in 1997 for artificial rupture of membranes to assist delivery may differ from previously reported data because of a correction that has been made to the CCS procedure code.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 1997 and 2010

Blood transfusion was the most common all-listed procedure performed during hospitalizations in 2010 (11 percent of stays with a procedure); the rate of hospitalization with blood transfusion has more than doubled since 1997.

Six of the most common procedures performed were associated with maternal and newborn hospitalizations—prophylactic vaccinations and inoculations, repair of current obstetric laceration, Cesarean section, circumcision, artificial rupture of membranes to assist delivery, and fetal monitoring. Cesarean section was the most common major operating room procedure performed in 2010 (41 stays per 10,000 population), and the rate of hospitalization with Cesarean section increased 41 percent since 1997.

Four cardiovascular procedures—diagnostic cardiac catheterization, diagnostic ultrasound of the heart (echocardiogram), hemodialysis, and percutaneous transluminal coronary angioplasty (PTCA)—were frequently performed in 2010. Although diagnostic cardiac catheterization was the fifth most common procedure in 2010, the rate of hospitalization with this procedure decreased 23 percent since 1997.

Musculoskeletal procedures also were frequently performed during hospital stays. Rates in 2010 for hospitalizations with knee arthroplasty (24 stays per 10,000 population) and spinal fusion (16 stays per 10,000 population) approximately doubled since 1997; the rate of hospitalization with hip replacement (15 stays per 10,000 population) increased 38 percent.

### All-listed procedures performed during hospital stays with the most rapid growth, 1997–2010

Although the hospitalization rate for all stays and for stays during which any procedure was performed remained stable between 1997 and 2010, the hospitalization rate for stays during which some specific procedures were performed experienced rapid growth (table 2). Seven of the most rapidly growing all-listed procedures were also among those most frequently performed during hospital stays: prophylactic vaccinations and inoculations, blood transfusion, spinal fusion, knee arthroplasty, enteral and parenteral nutrition, hemodialysis, and respiratory intubation and mechanical ventilation.

Table 2 Number of stays, stays per 10,000 population, and percentage change in rate for procedures with the most rapid growth, 1997 and 2010

All-listed CCS procedures | Number of stays with the procedure in thousands | | Stays with the procedure per 10,000 population (rate) | | Percentage change in rate
All-listed CCS procedures | 1997 | 2010 | 1997 | 2010 | 1997–2010
All stays (with and without procedures) | 34,681 | 39,008 | 1,272 | 1,261 | −1%
All stays with any procedure | 21,257 | 24,740 | 780 | 800 | 3%
Procedures with most rapid growth in stays per population^*^
Indwelling catheter | 60 | 214 | 2 | 7 | 213%
Prophylactic vaccinations and inoculations | 567 | 1,837 | 21 | 59 | 185%
Blood transfusion | 1,098 | 2,815 | 40 | 91 | 126%
Spinal fusion | 202 | 492 | 7 | 16 | 115%
Abdominal paracentesis | 117 | 264 | 4 | 9 | 99%
Incision and drainage; skin and subcutaneous tissue | 118 | 265 | 4 | 9 | 97%
Arthroplasty knee | 329 | 730 | 12 | 24 | 96%
Enteral and parenteral nutrition | 277 | 613 | 10 | 20 | 95%
Arterio- or venogram (not heart and head) | 143 | 286 | 5 | 9 | 76%
Hemodialysis | 473 | 850 | 17 | 27 | 58%
Respiratory intubation and mechanical ventilation | 919 | 1,638 | 34 | 53 | 57%

CCS: Clinical Classifications Software

* Includes only procedures with at least 100,000 stays in either 2010 or 1997

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 1997 and 2010

Indwelling catheter was the most rapidly growing procedure between 1997 and 2010; the rate of hospitalization with this minor procedure more than tripled during this period (from 2 to 7 stays per 10,000 population). The rate of hospitalization with prophylactic vaccinations and inoculations, blood transfusion, and spinal fusion more than doubled between 1997 and 2010.

### Most frequent all-listed procedures performed during hospital stays by patient age, 2010

Table 3 highlights the 5 most frequent procedures performed during hospitalizations in 2010 by patient age group, as well as the change in the rate of hospitalization with these procedures since 1997.

Table 3 Number of stays, stays per 10,000 population, and percentage change in rate of the most frequent all-listed procedures for hospital stays by age, 1997 and 2010

Age group and all-listed CCS procedures | Number of stays in thousands | | Stays per 10,000 population | | Percentage change in rate
Age group and all-listed CCS procedures | 1997 | 2010 | 1997 | 2010 | 1997–2010
All ages, total stays | 34,681 | 39,008 | 1,272 | 1,261 | −1%
< 1 year, total stays | 4,436 | 4,521 | 11,825 | 11,438 | −3%
Prophylactic vaccinations and inoculations | 549 | 1,472 | 1,464 | 3,725 | 155%
Circumcision | 1,159 | 1,147 | 3,090 | 2,902 | −6%
Respiratory intubation and mechanical ventilation | 164 | 200 | 436 | 507 | 16%
Enteral and parenteral nutrition | 39 | 138 | 104 | 350 | 235%
Diagnostic spinal tap | 147 | 91 | 392 | 229 | −41%
1–17 years, total stays | 1,821 | 1,754 | 271 | 250 | −8%
Appendectomy | 74 | 88 | 11 | 13 | 13%
Blood transfusion | 26 | 67 | 4 | 10 | 144%
Cancer chemotherapy | 43 | 52 | 6 | 7 | 15%
Repair of current obstetric laceration | 58 | 48 | 9 | 7 | −21%
Respiratory intubation and mechanical ventilation | 30 | 45 | 4 | 6 | 42%
18–44 years, total stays | 9,444 | 9,706 | 850 | 859 | 1%
Cesarean section | 773 | 1,249 | 70 | 111 | 59%
Repair of current obstetric laceration | 1,079 | 1,242 | 97 | 110 | 13%
Artificial rupture of membranes to assist delivery | 808 | 886 | 73 | 78 | 8%
Fetal monitoring | 952 | 845 | 86 | 75 | −13%
Blood transfusion | 147 | 346 | 13 | 31 | 133%
45–64 years, total stays | 6,496 | 9,755 | 1,154 | 1,193 | 3%
Blood transfusion | 247 | 797 | 44 | 97 | 122%
Diagnostic cardiac catheterization; coronary arteriography | 578 | 564 | 103 | 69 | −33%
Respiratory intubation and mechanical ventilation | 186 | 488 | 33 | 60 | 80%
Upper gastrointestinal endoscopy; biopsy | 275 | 400 | 49 | 49 | 0%
Hemodialysis | 154 | 337 | 27 | 41 | 51%
65–84 years, total stays | 10,121 | 10,169 | 3,319 | 2,913 | −12%
Blood transfusion | 514 | 1,181 | 169 | 338 | 101%
Respiratory intubation and mechanical ventilation | 366 | 573 | 120 | 164 | 37%
Diagnostic cardiac catheterization; coronary arteriography | 738 | 563 | 242 | 161 | −33%
Upper gastrointestinal endoscopy; biopsy | 530 | 462 | 174 | 132 | −24%
Arthroplasty knee | 201 | 382 | 66 | 109 | 66%
85+ years, total stays | 2,362 | 3,103 | 6,049 | 5,608 | −7%
Blood transfusion | 138 | 373 | 353 | 675 | 91%
Respiratory intubation and mechanical ventilation | 65 | 133 | 168 | 240 | 44%
Upper gastrointestinal endoscopy; biopsy | 122 | 129 | 313 | 233 | −26%
Diagnostic ultrasound of heart (echocardiogram) | 65 | 90 | 165 | 162 | −2%
Treatment; fracture or dislocation of hip and femur | 87 | 87 | 222 | 157 | −29%

CCS: Clinical Classifications Software

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 1997 and 2010

Although some procedures varied by age group, others were consistent across age groups. Blood transfusion was the most common procedure performed during hospital stays for adults ages 45–64, 65–84, and 85 and older in 2010, and the rate of hospitalization with transfusion approximately doubled from 1997 for each of these age groups. Blood transfusion also was 1 of the 5 most common procedures in 2010 among hospitalized children ages 1–17 and adults ages 18–44.

Respiratory intubation and mechanical ventilation also was a common procedure for all age groups except adults ages 18–44. The rate of hospitalization with respiratory intubation and mechanical ventilation grew rapidly between 1997 and 2010 for adults ages 45–64 (80 percent), ages 65–84 (37 percent), and age 85 and older (44 percent).

The most common procedures performed on hospitalized infants in 2010 were routine procedures, such as vaccinations and circumcision. The rate of infant hospitalization with vaccinations increased 155 percent since 1997. The rate of hospitalization with enteral and parenteral nutrition also grew rapidly for infants (235 percent). Appendectomy was the most frequent procedure performed in 2010 during hospital stays among children ages 1–17 (13 stays per 10,000 population).

Among adults ages 18–44, 4 of the top 5 procedures were related to pregnancy and childbirth: Cesarean section, repair of current obstetric laceration, artificial rupture of membranes to assist delivery, and fetal monitoring. The rate of hospitalization with Cesarean section increased 59 percent; however, the rates of hospitalization with repair of current obstetric laceration and artificial rupture of membranes to assist delivery remained stable between 1997 and 2010.

Among adults age 45 and older, cardiovascular and musculoskeletal procedures were common. Diagnostic cardiac catheterization was the second most common procedure among hospitalized adults ages 45–64 and the third most common procedure among adults ages 65–84 in 2010. The rate of hospitalization with this procedure decreased 33 percent for both age groups since 1997. Diagnostic ultrasound of the heart (echocardiogram) was the fourth most common procedure among adults age 85 and older. In terms of musculoskeletal procedures, knee arthroplasty was the fifth most common procedure among hospitalized adults ages 65–84; the rate of hospitalization with this procedure increased 66 percent since 1997. Treatment of a fractured or dislocated hip was the fifth most common procedure among hospitalized adults age 85 and older; the rate of hospitalization for this procedure decreased 29 percent since 1997.

## Data Source

The estimates in this Statistical Brief are based upon data from the HCUP 2010 NIS. Historical data were drawn from the 1997 NIS. Supplemental sources included data on national population estimates from “Intercensal Estimates of the Resident Population by Single Year of Age, Sex, Race, and Hispanic Origin for the United States: April 1, 2000 to July 1, 2010,” Population Division, U.S. Census Bureau, Release date: September 2011. (http://www.census.gov/popest/data/intercensal/national/nat2010.html).

Supplemental sources also included data on national population estimates from “Intercensal Estimates of the United States Resident Population by Age and Sex, 1990–2000: Selected Months,” Population Division, U.S. Census Bureau, Release date: August 2004. (http://www.census.gov/popest/data/intercensal/national/index.html).

Many hypothesis tests were conducted for this Statistical Brief. Thus, to decrease the number of false-positive results, we reduced the significance level to .001 for individual tests.

## Definitions

### Procedures, ICD-9-CM, and Clinical Classifications Software (CCS)

The principal procedure is the procedure that is performed for definitive treatment rather than performed for diagnostic or exploratory purposes (i.e., the procedure that was necessary to take care of a complication). If two procedures appear to meet this definition, the procedure most related to the principal diagnosis is selected as the principal procedure. All-listed procedures include all procedures performed during the hospital stay whether for definitive treatment or for diagnostic or exploratory purposes.

ICD-9-CM is the International Classification of Diseases, Ninth Revision, Clinical Modification, which assigns numeric codes to procedures. There are about 4,000 ICD-9-CM procedure codes.

CCS categorizes procedure codes into clinically meaningful categories.^1^ This “clinical grouper” makes it easier to quickly understand patterns of procedure use. CCS categories identified as “Other” are typically not reported; these categories include miscellaneous, otherwise unclassifiable procedures that may be difficult to interpret as a group.

### Types of hospitals included in HCUP

HCUP is based on data from community hospitals, defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). HCUP data include obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded are long-term care, rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. However, if a patient received long-term care, rehabilitation, or treatment for psychiatric or chemical dependency conditions in a community hospital, the discharge record for that stay will be included in the NIS.

### Unit of analysis

The unit of analysis is the hospital discharge (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the hospital multiple times in one year will be counted each time as a separate “discharge” from the hospital.

## For More Information

For more information about HCUP, visit http://www.hcup-us.ahrq.gov/.

For additional HCUP statistics, visit HCUPnet, our interactive query system, at http://hcupnet.ahrq.gov/.

For information on other hospitalizations in the United States, download HCUP Facts and Figures: Statistics on Hospital-Based Care in the United States in 2009, located at http://www.hcup-us.ahrq.gov/reports.jsp.

For a detailed description of HCUP, more information on the design of the NIS, and methods to calculate estimates, please refer to the following publications:

Introduction to the HCUP Nationwide Inpatient Sample, 2010. Online. May 2012. U.S. Agency for Healthcare Research and Quality. Available at http://www.hcup-us.ahrq.gov/db/nation/nis/NISIntroduction2010.pdf. (Accessed September 18, 2012).

Houchens R, Elixhauser A. Final Report on Calculating Nationwide Inpatient Sample (NIS) Variances, 2001. HCUP Methods Series Report #2003-2. Online. June 2005 (revised June 6, 2005). U.S. Agency for Healthcare Research and Quality. Available at http://www.hcup-us.ahrq.gov/reports/CalculatingNISVariances200106092005.pdf. (Accessed September 18, 2012).

Houchens RL, Elixhauser A. Using the HCUP Nationwide Inpatient Sample to Estimate Trends. (Updated for 1988–2004). HCUP Methods Series Report #2006–05. Online. August 18, 2006. U.S. Agency for Healthcare Research and Quality. Available at http://www.hcup-us.ahrq.gov/reports/methods/2006_05_NISTrendsReport_1988-2004.pdf. (Accessed September 18, 2012).

1 HCUP Clinical Classifications Software (CCS). Healthcare Cost and Utilization Project (HCUP). U.S. Agency for Healthcare Research and Quality, Rockville, MD. Available at http://www.hcup-us.ahrq.gov/toolssoftware/ccs/ccs.jsp. Updated March 2012. (Accessed September 18, 2012).