# Statistical Brief #144 Overview of Hospital Stays in the United States, 2010

## Introduction

Inpatient hospital care is a significant component of the health care system, accounting for nearly one-third of health care expenditures in the United States in 2009.^1^ The demand for hospital care is expected to increase simply based on an overall increase in population. Demographic changes in the population also may have an impact on inpatient admissions. For example, the aging baby boom generation may increase the demand for hospital care, since older individuals require hospitalization more frequently.^2^ Additionally, the health condition of Americans has been deteriorating, with nearly one-third of U.S. adults being obese and nearly half of adults having a chronic illness, including heart disease and diabetes.^3^ However, increased use of chronic disease management programs, a shift to outpatient procedures, and efforts to reduce unnecessary hospitalizations may offset other factors driving the demand for inpatient hospital care.

This Statistical Brief presents data from the Healthcare Cost and Utilization Project (HCUP) on characteristics of stays in community hospitals in the United States in 2010. The number and distribution of stays in 2010 are stratified by primary payer and patient discharge status. Changes between 1997 and 2010 are also presented. All differences between estimates noted in the text are statistically significant at the .001 level or better.

## Findings

Highlights

■ The total number of hospital stays in the United States increased 12 percent between 1997 and 2010, but the rate of hospitalization remained stable at about 1,260–1,270 stays per 10,000 population.
■ The average length of stay decreased 5 percent from 4.9 days in 1997 to 4.7 days in 2010.
■ Aggregate inflation-adjusted hospital costs were $375.9 billion in 2010—a 62 percent increase since 1997. Average costs per stay increased 45 percent to $9,700 in 2010.
■ In 2010, more than half of hospital stays were billed to Medicare and Medicaid.
■ Private insurance was the second most common primary payer in 2010 at 32 percent of hospital stays, a decrease from 39 percent in 1997.
■ The number of hospital stays covered by Medicaid grew at nearly four times the rate of all stays between 1997 and 2010, and the number of uninsured hospital stays increased at more than three times the rate of all stays.
■ The majority of hospital discharges in 2010 were routine (71 percent).
■ Discharge against medical advice represented only 1 percent of all hospital stays, but increased 47 percent between 1997 and 2010.
■ Discharge to home health care represented 11 percent of all stays, but increased 79 percent during this time period.
■ Medicaid and uninsured hospital stays accounted for over half of discharges against medical advice, but only about one-quarter of stays with other types of discharge.

### Overall characteristics of stays in U.S. hospitals, 1997–2010

Table 1 shows characteristics of stays in U.S. community hospitals in 1997 and 2010. The total number of hospital stays increased 12 percent, from 34.7 million in 1997 to 39 million in 2010, but the rate of hospitalization remained stable at roughly 1,260–1,270 stays per 10,000 population. The average length of stay decreased 5 percent from 4.9 days in 1997 to 4.7 days in 2010.

Table 1 Characteristics of U.S. community hospitals, 1997 and 2010

Utilization, charges, and costs | 1997 | 2010
Stays
Total stays in millions | 34.7 | 39.0
Number of stays per 10,000 population | 1,272 | 1,261
Total days of care in millions | 169.4 | 181.7
Average length of stay in days | 4.9 | 4.7
Percentage of discharges from:
Metropolitan hospitals | 84% | 87%
Teaching hospitals | 41% | 48%
Hospital ownership
Non-Federal government hospitals | 14% | 14%
Private not-for-profit hospitals | 73% | 72%
Private for-profit hospitals | 13% | 13%
Charges and costs^*^
Average charges per stay | $14,800 | $33,100
Average costs per stay | $6,700 | $9,700
Total aggregate costs in billions | $232.3 | $375.9

* Charges per stay, costs per stay, and aggregate costs in 1997 are inflation-adjusted to 2010 dollars.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 1997 and 2010

The national distribution of discharges by hospital location (metropolitan versus non-metropolitan) and hospital ownership remained unchanged between 1997 and 2010. Most stays (87 percent; not significantly different from the 1997 value) occurred in metropolitan hospitals and nearly three-quarters of stays occurred in private not-for-profit hospitals. Nearly half of stays (48 percent) occurred in teaching hospitals in 2010, an increase from 41 percent in 1997.

Aggregate hospital—costs the actual expenses incurred for producing services were—$375.9 billion in 2010; this was a 62 percent increase since 1997. Costs per stay increased 45 percent to $9,700 in 2010. Charges per stay—what hospitals bill patients for their rooms, nursing care, diagnostic tests, procedures, and other services—more than doubled between 1997 and 2010 to $33,100. All costs and charges are adjusted for inflation.

### Hospital stays by expected primary payer, 1997–2010

In 2010, more than half of stays (58 percent) were billed to Medicare and Medicaid (figure 1). Although the percentage of stays billed to Medicare remained stable (36–37 percent) between 1997 and 2010, the percentage billed to Medicaid increased from 16 percent to 21 percent. Private insurance was the second most common primary payer but its share of stays fell from 39 percent in 1997 to 32 percent of stays in 2010. The share of uninsured stays and stays billed to other payers remained stable between 1997 and 2010.

Figure 1 Number and distribution of hospital stays by expected primary payer, 1997–2010

Note: Bar segments representing 4 percent or less are not labeled.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 1997, 2003, and 2010

Figure 1. Number and distribution of hospital stays by expected primary payer, 1997-2010. Stacked column chart; number of stays in millions in the years 1997, 2003, and 2010. In 1997, by expected primary payer: Percentage of stays by payer from total number of 34.7 million; Other, 4%; Uninsured, 5%; Private insurance, 39%; Medicaid, 16%; Medicare, 36%. In 2003, by expected primary payer: Percentage of stays by payer from total number of 38.2 million; Other, 3%; Uninsured, 5%; Private insurance, 37%; Medicaid, 18%; Medicare, 37%. In 2010, by expected primary payer: Percentage of stays by payer from total number of 39.0 million; Other, 3%; Uninsured, 6%; Private insurance, 32%; Medicaid, 21%; Medicare, 37%.

The number of stays with Medicaid as the primary payer experienced the most rapid growth (47 percent) between 1997 and 2010—nearly four times the rate of all stays (figure 2). Although it accounted for a small and stable share of all stays between 1997 and 2010 (5–6 percent of stays), the number of uninsured stays increased 40 percent during this period, which was more than three times the rate of all stays. Medicare stays increased 15 percent since 1997; the number of stays billed to private insurance and other payers remained relatively stable.

Figure 2 Change in the number of hospital stays by expected primary payer, 1997–2010

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 1997 and 2010

Figure 2. Change in the number of hospital stays by expected primary payer, 1997-2010. Bar chart, percentage change, Medicaid, 47%; Uninsured, 40%; Medicare, 15%; All stays, 12%; Other, 4%; Private insurance, -7%.

### Hospital stays by discharge status, 1997–2010

Nearly three-quarters of all hospital stays were routinely discharged in 2010 (figure 3). Discharge to follow-on care was also common: discharge to long-term care accounted for 13 percent of stays, and discharge to the home with home health care accounted for 11 percent of stays. The remaining circumstances—discharge to another short-term hospital; in-hospital deaths; and discharge against medical advice, which occurs when patients check themselves out of the hospital against the advice of their physician—each accounted for 2 percent or less of stays.

Figure 3 Distribution of hospital stays by discharge status, 2010

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2010

Figure 3. Distribution of hospital stays by discharge status, 2010. Pie chart, total of 39.0 million stays, Routine, 71%, Long-term care and other facilities, 13%, Home health care, 11%, Another short-term hospital, 2%, In-hospital deaths, 2%, Against medical advice, 1%.

The number of stays discharged to follow-on care increased between 1997 and 2010: discharge to home health care increased 79 percent and discharge to long-term care increased 37 percent (figure 4). Although discharges against medical advice accounted for only 1 percent of all stays, they increased 47 percent between 1997 and 2010. In-hospital deaths, which were also a small share of all stays (2 percent), decreased 13 percent during this period.

Figure 4 Change in the number of hospital stays by discharge status, 1997–2010

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 1997 and 2010

Figure 4. Change in the number of hospital stays by discharge status, 1997-2010. Bar chart; percentage change, In-hospital deaths, -13%, Another short-term hospital, -1%, Routine, 4%, All stays, 12%, Long-term care and other facilities, 37%, Against medical advice, 47%, Home health care, 79%.

In 2010, the most common payer for patients discharged against medical advice was Medicaid (32 percent of stays), but Medicaid was the third most common payer for all other stays (21 percent of stays) (figure 5). Uninsured stays accounted for 20 percent of discharges against medical advice, which was more than three times the uninsured share of all other stays (6 percent). Together, Medicaid and uninsured stays accounted for over half of discharges against medical advice (52 percent), but only about one-quarter of stays with other types of discharges (27 percent).

Figure 5 Distribution of discharges against medical advice and all other hospital stays by payer, 2010

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2010

Figure 5. Distribution of discharges against medical advice and all other hospital stays by payer, 2010. Stacked bar chart; Discharges against medical advice, 28% Medicare, 32% Medicaid, 16% Private insurance, 20% Uninsured, 4% Other, All other stays, 37% Medicare, 21% Medicaid, 32% Private insurance, 6% Uninsured, 3% Other.

Medicare was the second most common primary payer for discharges against medical advice (28 percent of stays) but the most common primary payer for all other stays (37 percent of stays). Private insurance was the fourth most common payer for discharges against medical advice (16 percent of stays) but the second most common primary payer for all other stays (32 percent of stays).

## Data Source

The estimates in this Statistical Brief are based upon data from the HCUP 2010 NIS. Historical data were drawn from the 1997 NIS and the 2003 NIS. Supplemental sources included data on national population estimates from “Intercensal Estimates of the Resident Population by Single Year of Age, Sex, Race, and Hispanic Origin for the United States: April 1, 2000 to July 1, 2010,” Population Division, U.S. Census Bureau, Release date: September 2011. (http://www.census.gov/popest/data/intercensal/national/nat2010.html).

Supplemental sources also included data on national population estimates from “Intercensal Estimates of the United States Resident Population by Age and Sex, 1990–2000: Selected Months,” Population Division, U.S. Census Bureau, Release date: August 2004. (http://www.census.gov/popest/data/intercensal/national/index.html).

Many hypothesis tests were conducted for this Statistical Brief. Thus, to decrease the number of false-positive results, we reduced the significance level to .001 for individual tests.

## Definitions

### Types of hospitals included in HCUP

HCUP is based on data from community hospitals, defined as short-term, non-Federal, general and other hospitals, excluding hospital units of other institutions (e.g., prisons). HCUP data include obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded are long-term care, rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. However, if a patient received long-term care, rehabilitation, or treatment for psychiatric or chemical dependency conditions in a community hospital, the discharge record for that stay will be included in the NIS.

### Unit of analysis

The unit of analysis is the hospital discharge (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the hospital multiple times in one year will be counted each time as a separate “discharge” from the hospital.

### Costs and charges

Total hospital charges were converted to costs using HCUP Cost-to-Charge Ratios based on hospital accounting reports from the Centers for Medicare & Medicaid Services (CMS).^4^Costs will reflect the actual expenses incurred in the production of hospital services, such as wages, supplies, and utility costs; charges represent the amount a hospital billed for the case. For each hospital, a hospital-wide cost-to-charge ratio is used. Hospital charges reflect the amount the hospital billed for the entire hospital stay and do not include professional (physician) fees. For the purposes of this Statistical Brief, costs are reported to the nearest hundred.

### Hospital location

The classification of whether a hospital is in a metropolitan area (“urban”) or nonmetropolitan area (“rural”) is defined from the American Hospital Association (AHA) Annual Survey, using the 1993 U.S. Office of Management and Budget definition.

### Payer

Payer is the expected primary payer for the hospital stay. To make coding uniform across all HCUP data sources, payer combines detailed categories into more general groups:

– Medicare: includes fee-for-service and managed care Medicare patients
– Medicaid: includes fee-for-service and managed care Medicaid patients. Patients covered by the State Children’s Health Insurance Program (SCHIP) may be included here. Because most State data do not identify SCHIP patients specifically, it is not possible to present this information separately.
– Private Insurance: includes Blue Cross, commercial carriers, and private HMOs and PPOs
– Other: includes Worker’s Compensation, TRICARE/CHAMPUS, CHAMPVA, Title V, and other government programs
– Uninsured: includes an insurance status of “self-pay” and “no charge.”

When more than one payer is listed for a hospital discharge, the first-listed payer is used.

### Discharge status

Discharge status indicates the disposition of the patient at discharge from the hospital and includes the following six categories: routine (to home); transfer to another short-term hospital; other transfers (including skilled nursing facility, intermediate care, and another type of facility such as a nursing home); home health care; against medical advice (AMA); or died in the hospital.

## For More Information

For more information about HCUP, visit http://www.hcup-us.ahrq.gov/.

For additional HCUP statistics, visit HCUPnet, our interactive query system, at http://hcupnet.ahrq.gov/.

For information on other hospitalizations in the United States, download HCUP Facts and Figures: Statistics on Hospital-Based Care in the United States in 2009, located at http://www.hcup-us.ahrq.gov/reports.jsp.

For a detailed description of HCUP, more information on the design of the NIS, and methods to calculate estimates, please refer to the following publications:

Introduction to the HCUP Nationwide Inpatient Sample, 2010. Online. May 2012. U.S. Agency for Healthcare Research and Quality. Available at http://www.hcup-us.ahrq.gov/db/nation/nis/NISIntroduction2010.pdf. (Accessed September 5, 2012).

Houchens R, Elixhauser A. Final Report on Calculating Nationwide Inpatient Sample (NIS) Variances, 2001. HCUP Methods Series Report #2003-2. Online. June 2005 (revised June 6, 2005). U.S. Agency for Healthcare Research and Quality. Available at http://www.hcup-us.ahrq.gov/reports/CalculatingNISVariances200106092005.pdf. (Accessed September 5, 2012).

Houchens RL, Elixhauser A. Using the HCUP Nationwide Inpatient Sample to Estimate Trends. (Updated for 1988–2004). HCUP Methods Series Report #2006–05. Online. August 18, 2006. U.S. Agency for Healthcare Research and Quality. Available at http://www.hcup-us.ahrq.gov/reports/methods/2006_05_NISTrendsReport_1988-2004.pdf. (Accessed September 5, 2012).

1 Kashihara, D and Carper, K. National Health Care Expenses in the U.S.Civilian Noninstitutionalized Population, 2009. Statistical Brief #355. January 2012. Agency for Healthcare Research and Quality, Rockville, MD. http://www.meps.ahrq.gov/mepsweb/data_files/publications/st355/stat355.pdf (Accessed August 16, 2012).

2 Wier LM (Thomson Reuters), Pfuntner A (Thomson Reuters), Maeda J (Thomson Reuters), Stranges E (Thomson Reuters), Ryan K (Thomson Reuters), Jagadish P (AHRQ), Collins Sharp B (AHRQ), Elixhauser A (AHRQ). HCUP Facts and Figures: Statistics on Hospital-Based Care in the United States, 2009. Rockville, MD: Agency for Healthcare Research and Quality, 2011 (http://www.hcup-us.ahrq.gov/reports.jsp). (Accessed August 16, 2012).

3 Spotlight on Prevention: Why strategies that make us healthier are key to health reform. Online. Robert Wood Johnson Foundation. Available at http://www.rwjf.org/healthpolicy/publichealth/product.jsp?id=45408. (Accessed August 16, 2012).

4 HCUP Cost-to-Charge Ratio Files (CCR). Healthcare Cost and Utilization Project (HCUP). 2001–2009. U.S. Agency for Healthcare Research and Quality, Rockville, MD. Available athttp://www.hcup-us.ahrq.gov/db/state/costtocharge.jsp. Updated August 2011. (Accessed August 16, 2012).