# Statistical Brief #143 Emergency Department Visits for Dental-Related Conditions, 2009

## Introduction

Tooth decay is one of the most prevalent chronic diseases worldwide and the most common medical condition among children in the United States.^1, 2, 3^ People are susceptible to dental-related conditions throughout their lifetimes,^4^ and most oral diseases tend to be progressive and cumulative without intervention.^4^ Therefore, untreated tooth decay could result in loss of teeth and difficulty eating, and it can even lead to death.^6^ The cost of dental visits in the emergency department (ED) is high. For example, dental visits to the ED totaled $23 million in Georgia in 2007 and nearly $88 million in Florida in 2010.^5^

This Statistical Brief presents nationwide data from the Healthcare Cost and Utilization Project (HCUP) on ED visits for treatment of dental-related conditions in 2009. Patient characteristics of ED visits for dental care are described, and dental visits that resulted in a hospital admission are compared to treat-and-release ED visits. Patient demographics (sex, age, patient residence, and community income level), primary expected payer, patient-to-dentist ratios, and the most common dental conditions are described. Figures highlight differences that were statistically significant. All differences between subgroup estimates noted in the text are statistically significant at the 0.05 probability level or better.

## Findings

Highlights

■ In 2009, over 900,000 emergency department (ED) visits and nearly 13,000 hospital inpatient stays were related to dental conditions. Between 2006 and 2009, the incidence of ED visits for patients seeking dental treatment increased by 16 percent, rising from 874,000 to 936,432 visits.
■ Dental caries (cavities) was the first-listed diagnosis for 42 percent of the ED visits. Dental abscess was the principal diagnosis for 63 percent of the inpatient stays.
■ Persons aged 18–44 years accounted for nearly 62 percent of dental-related ED visits (611 per 100,000 population).
■ Dental-related ED visit rates were more than twice in rural areas than in large metropolitan areas.
■ Dental-related ED visits were four times higher among patients from the lowest income communities than for patients in the highest income communities.
■ For individuals utilizing the ED for dental conditions, the major payer for hospitalized patients was Medicaid, followed by private insurance. Nearly half (42 percent) of treat-and-release patients seen for dental conditions in the ED were uninsured.
■ Use of the ED for dental conditions increased as the ratio of patients to dentists increased from <1500:1 (216 per 100,000) to 5000:1 (437 per 100,000), indicating that poorer access to dental care providers was related to increased use of EDs for dental conditions.

### Overall population

Table 1 contains demographic statistics for dental-related conditions in the ED. In 2009, there were 936,482 ED visits with dental conditions as a first-listed diagnosis—up from 874,000 in 2006. For the vast majority (98 percent) of these ED visits, patients were treated and released; only 2 percent resulted in hospitalization.

Table 1 Dental-related conditions in the emergency department, U.S., 2009

| ED visits related to dental conditions | | | All other ED visits
| Total ED visits | Treat-and-release ED visits | Hospital admissions from the ED | All other ED visits
Number of ED visits | 936,482 | 923,720 | 12,762 | 127,795,823
| Rate per 100,000 population
ED visits | 305 | 301 | 4.2 | 41,706
Patient sex
Males | 304 | 300 | 4.2 | 37,957
Females | 306 | 302 | 4.1 | 45,238
Age group
0–17 | 110 | 108 | 2.7 | 38,225
18–44 | 611 | 605 | 5.7 | 44,664
45–64 | 184 | 180 | 3.8 | 34,435
65–84 | 46 | 43 | 3.1 | 48,589
85 years and older | 33 | 29 | 3.9 | 79,118
Patient residence
Large metropolitan areas–at least one million residents | 217 | 213 | 3.9 | 37,447
Small metropolitan areas–less than one million residents | 369 | 365 | 4.7 | 43,541
Micropolitan | 478 | 474 | 4.9 | 50,196
Not metropolitan or micropolitan (rural) | 480 | 476 | 4.3 | 55,901
Community income level
1–lowest | 452 | 448 | 4.7 | 52,892
2–low | 387 | 381 | 5.8 | 46,749
3–moderate | 238 | 235 | 3.3 | 35,668
4–highest | 111 | 109 | 2.2 | 27,146
Ratio of patients to dentists
<1500 (desirable) | 216 | 212 | 4.2 | NA
1500–2000 | 326 | 321 | 5.3 | NA
2000–3000 | 336 | 333 | 2.9 | NA
3000–4000 (poor) | 447 | 443 | 3.6 | NA
>4000/1 (HPSA)^*^ | 382 | 379 | 3.1 | NA

Source: AHRQ, Center for Delivery, Organization and Markets, Healthcare Cost and Utilization Project, Nationwide Emergency Department Sample, 2009

* HPSA = Health Provider Shortage Area

Due to rounding, total ED visits may not equal the sum of treat-and-release visits plus hospital admissions from the ED.

There were 305 ED visits per 100,000 population in 2009. On average, there were 2,566 ED visits related to dental conditions every day, of which 35 resulted in hospital admission.

### Dental-related ED visits compared to all other ED visits by sex and age

Table 1 shows that males and females had similar ED visit and hospitalization rates for dental conditions.

About 62 percent of patients with dental-related ED visits were 18–44 years old (figure 1). Persons in this age group had the majority of ED visits for dental-related conditions among those who were treated and released and those who were hospitalized from the ED.

Figure 1 ED visits for dental conditions compared to all other ED visits, by age, 2009

Source: AHRQ, Center for Delivery, Organization and Markets, Healthcare Cost and Utilization Project, Nationwide Emergency Department Sample, 2009

Figure 1. ED visits for dental conditions compared to all other ED visits, by age, 2009. Two pie charts; first chart, Total ED visits related to dental conditions; ages 0 to 17, 11%; ages 18 to 44, 62%; ages 45 to 64, 19%; ages 65 to 84, 5%; 85 years and older, 3%; Second chart, All other ED visits; ages 0 to 17, 16%; ages 18 to 44, 18%; ages 45 to 64, 14%; ages 65 to 84, 20%; 85 years and older, 32%; Source: AHRQ, Center for Delivery, Organization and Markets, Healthcare Cost and Utilization Project, Nationwide Emergency Department Sample, 2009

Figure 2 further examines the age composition of dental-related ED visits for patients 15–44 years old. Those who were 25–29 years old had the highest rate of ED utilization for dental conditions (890 per 100,000 persons), followed by those who were 20–24 years old (766 per 100,000 persons) and 30–34 years old (660 per 100,000 persons).

Figure 2 Dental-related ED visits for 15–44 year olds, rate per 100,000 population, 2009

Source: AHRQ, Center for Delivery, Organization and Markets, Healthcare Cost and Utilization Project, Nationwide Emergency Department Sample, 2009

Figure 2. Dental-related ED visits for 15–44 year olds, rate per 100,000 population, 2009. Column bar chart; ED visits per 100,000: ages 15 to 19, 211; ages 20 to 24, 766; ages 25 to 29, 890; ages 30 to 34, 660; ages 35 to 39, 473; ages 40 to 44, 381; Source: AHRQ, Center for Delivery, Organization and Markets, Healthcare Cost and Utilization Project, Nationwide Emergency Department Sample, 2009

### ED visits and inpatient stays related to dental issues by payer

Figure 3 Illustrates the payer mix of dental-related ED visits compared to all other ED visits. Most ED visits for dental-related conditions were covered by Medicaid (30 percent) or were uninsured (40 percent).

Figure 3 Expected pay source for dental-related ED visits compared to all other ED visits, 2009

Source: AHRQ, Center for Delivery, Organization and Markets, Healthcare Cost and Utilization Project, Nationwide Emergency Department Sample, 2009

Figure 3. Expected pay source for dental-related ED visits compared to all other ED visits, 2009. Two pie charts; first chart, Total ED visits related to dental conditions; Medicare, 7%; Medicaid, 30%; Private, 19%; Uninsured, 40%; Other, 4%; Second chart, All other ED visits; Medicare, 20%; Medicaid, 25%; Private, 33%; Uninsured, 17%; Other, 5%; Source: AHRQ, Center for Delivery, Organization and Markets, Healthcare Cost and Utilization Project, Nationwide Emergency Department Sample, 2009

Figure 4 compares the expected pay source for treat-and-release ED visits for dental conditions to ED visits that resulted in a hospital admission. Figure 4 shows that 41 percent of dental-related treat-and-release ED visits were uninsured. Among the visits resulting in hospital admission, the most common payer was Medicaid (27 percent), followed by private insurance (26 percent), while 20 percent were uninsured.

Figure 4 Expected payer for ED patients admitted into the hospital compared to those who were discharged with dental-related conditions, 2009

Source: AHRQ, Center for Delivery, Organization and Markets, Healthcare Cost and Utilization Project, Nationwide Emergency Department Sample, 2009

Figure 4. Expected payer for ED patients admitted into the hospital compared to those who were discharged with dental-related conditions, 2009. Two pie charts; first chart, Treat and release ED visits related to dental conditions; Medicare, 7%; Medicaid, 30%; Private, 18%; Uninsured, 41%; Other, 4%; Second chart, Admissions related to dental conditions; Medicare, 17%; Medicaid, 27%; Private, 26%; Uninsured, 20%; Other, 10%; Source: AHRQ, Center for Delivery, Organization and Markets, Healthcare Cost and Utilization Project, Nationwide Emergency Department Sample, 2009

### Dental-related ED visits compared to all other ED visits, by community income level

Patients residing in communities with the lowest income levels had the highest number of visits to the ED for dental conditions, as shown in table 1. Furthermore, the number of dental-related ED visits decreased as community income level increased. Compared to the highest income communities, dental-related ED visits were four times higher among patients from the lowest income communities.

### ED visits and inpatient stays related to dental problems by patient residence

Table 1 shows that dental-related ED visits were more common in rural areas than in urban areas. There were 480 dental-related ED visits per 100,000 in rural areas—more than twice as high as in the largest urban areas (217 dental-related ED visits per 100,000).

### Total dental-related ED visits by availability of dental-care providers

Figure 5 shows generally higher rates of dental-related ED visits in areas with more patients per dentist. For example, in areas with 3000–4000 patients per dentist, there were 447 dental-related ED visits per 100,000 population, compared to 216 dental-related ED visits in areas with the most dentists (<1500 patients per dentist).

Figure 5 Dental-related ED visits per 100,000 population by patient-to-dentist ratio, 2009

Source: AHRQ, Center for Delivery, Organization and Markets, Healthcare Cost and Utilization Project, Nationwide Emergency Department Sample, 2009

HPSA = Health Provider Shortage Area

Figure 5. Dental-related ED visits per 100,000 population by patient-to-dentist ratio, 2009. Column bar chart; utilization rates per 100,000; patient-dentist ratio: Less than 1500 (desirable), 216; 1500–2000, 326; 2000–3000, 336; 3000–4000 (poor), 447; Greater than 4000 (HPSA), 382; Source: AHRQ, Center for Delivery, Organization and Markets, Healthcare Cost and Utilization Project, Nationwide Emergency Department Sample, 2009.

### Dental-related conditions seen in the ED

Table 2 shows the top five dental-related diagnoses made in the ED. Dental caries (cavities) were the most frequently listed dental condition (41.8 percent). This diagnosis was followed closely by dental abscess (37.4 percent), an infection that typically originates from dental caries. Table 3 compares the diagnoses for dental-related treat-and-release visits to those from ED visits that resulted in a hospital admission. Abscess was more common among patients admitted to the hospital, comprising 63.0 percent of this group.

Table 2 The top five most common dental conditions seen in the ED, U.S., 2009

Principal or first-listed diagnosis | Number of visits | Percentage
Dental caries | 389,600 | 41.8
Abscess | 349,000 | 37.4
Periodontitis | 95,400 | 10.2
Gingival disorders | 49,700 | 5.3
Disorders of development & eruption | 27,300 | 2.9

Source: AHRQ, Center for Delivery, Organization and Markets, Healthcare Cost and Utilization Project, Nationwide Emergency Department Sample, 2009

Table 3 The top five dental conditions for treat-and-release ED visits and those that resulted in hospital admission, U.S., 2009

Treat-and-release visits | Principal or first-listed diagnosis | Number of visits | Percentage
Treat-and-release visits | Dental caries | 387,600 | 42.0
Treat-and-release visits | Abscess | 341,200 | 37.0
Treat-and-release visits | Periodontitis | 93,300 | 10.0
Treat-and-release visits | Gingival disorders | 49,200 | 5.0
Treat-and-release visits | Disorders of development & eruption | 27,200 | 3.0
Treat-and-release visits | Total | 920,800 | 100.0
Visits that result in hospital admission
Visits that result in hospital admission | Abscess | 7,800 | 63.0
Visits that result in hospital admission | Dental caries | 2,000 | 16.0
Visits that result in hospital admission | Periodontitis | 2,000 | 16.0
Visits that result in hospital admission | Gingival disorders | 400 | 3.0
Visits that result in hospital admission | Disorders of development & eruption | 100 | 1.0
Visits that result in hospital admission | Total | 12,500 | 100.0

Source: AHRQ, Center for Delivery, Organization and Markets, Healthcare Cost and Utilization Project, Nationwide Emergency Department Sample, 2009

## Data Source

The estimates in this Statistical Brief are based upon data from the HCUP 2009 NEDS. Supplemental sources included data from the U.S. Census Bureau, Population Division, Annual Estimates of the Population for the United States, Regions, and Divisions and U.S. Census Bureau, Current Population Reports, P60-226, Coverage by Type of Health Insurance and Claritas Population Estimates, 2009. Data on Health Provider Shortage Areas was derived from the Area Resource File (ARF) made available through the Health Resources and Services Administration (HRSA): http://bhpr.hrsa.gov/shortage/hpsas/designationcriteria/dentalhpsaoverview.html.

## Definitions

### Diagnoses, ICD-9-CM, and Clinical Classifications Software (CCS)

The principal diagnosis is that condition established after study to be chiefly responsible for the patient’s admission to the hospital. The first-listed diagnosis for the ED visit may not be the principal diagnosis; it may just be the first-listed diagnosis on the record.

ICD-9-CM is the International Classification of Diseases, Ninth Revision, Clinical Modification, which assigns numeric codes to diagnoses. There are about 14,000 ICD-9-CM diagnosis codes.

CCS categorizes ICD-9-CM diagnoses into a manageable number of clinically meaningful categories.^7^ This “clinical grouper” makes it easier to quickly understand patterns of diagnoses. CCS categories identified as “Other” are typically not reported; these categories include miscellaneous, otherwise unclassifiable diagnoses that may be difficult to interpret as a group.

### Case definition

The ICD-9-CM codes defining dental conditions include diagnosis codes in the following range: ICD-9-CM 520-523.9.

### Types of hospitals included in HCUP

HCUP is based on data from community hospitals, defined as short-term, non-Federal, general and other hospitals, excluding hospital units of other institutions (e.g., prisons). HCUP data include obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded are long-term care, rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. However, if a patient received long-term care, rehabilitation, or treatment for psychiatric or chemical dependency conditions in a community hospital, the discharge record for that stay will be included in the NIS.

### Unit of analysis

The unit of analysis is the ED visit or hospital discharge, not a person or patient. This means that a person who is seen in the ED or admitted to the hospital multiple times in one year will be counted each time as a separate ED visit or “discharge” from the hospital.

### Location of patients’ residence

Place of residence is based on the urban-rural classification scheme for U.S. counties developed by the National Center for Health Statistics (NCHS):

– Large Central Metropolitan: Central counties of metropolitan areas with 1 million or more residents
– Large Fringe Metropolitan: Fringe counties of counties of metropolitan areas with 1 million or more residents
– Medium Metropolitan: Counties in metropolitan areas of 250,000–999,999 residents
– Small Metropolitan: Counties in metropolitan areas of 50,000–249,999 residents
– Micropolitan: Nonmetropolitan counties, i.e., a nonmetropolitan county with an area of 10,000 or more residents
– Non-core: Nonmetropolitan and nonmicropolitan counties.

### Median community-level income

Median community-level income is the median household income of the patient’s ZIP Code of residence. The cut-offs for the quartile designation are determined using ZIP Code demographic data obtained from Claritas. The income quartile is missing for homeless and foreign patients.

### Payer

Payer is the expected primary payer for the hospital stay. To make coding uniform across all HCUP data sources, payer combines detailed categories into more general groups:

– Medicare: includes fee-for-service and managed care Medicare patients
– Medicaid: includes fee-for-service and managed care Medicaid patients. Patients covered by the State Children’s Health Insurance Program (SCHIP) may be included here. Because most State data do not identify SCHIP patients specifically, it is not possible to present this information separately.
– Private Insurance: includes Blue Cross, commercial carriers, and private HMOs and PPOs
– Other: includes Worker’s Compensation, TRICARE/CHAMPUS, CHAMPVA, Title V, and other government programs
– Uninsured: includes an insurance status of “self-pay” and “no charge.”

When more than one payer is listed for a hospital discharge, the first-listed payer is used.

## For More Information

Visit http://www.hcup-us.ahrq.gov/. For additional HCUP statistics, visit HCUPnet, our interactive query system, at http://hcupnet.ahrq.gov/.

For information on other hospitalizations in the United States, download HCUP Facts and Figures: Statistics on Hospital-Based Care in the United States in 2009, located at http://www.hcup-us.ahrq.gov/reports.jsp.

For a detailed description of HCUP, and more information on the design of the NEDS, please refer to the following publication:

Introduction to the HCUP Nationwide Emergency Department Sample, 2009. Online. September 2011. U.S. Agency for Healthcare Research and Quality. Available at http://hcup-us.ahrq.gov/db/nation/neds/NEDS2009Introductionv3.pdf. (Accessed March 15, 2012).

1 Peres, K. G., Peres, M. A., Araujo, C. L., & Menezes, A. M. (2009). Social and dental status along the life course and oral health impacts. BioMed Central, 1–10.

2 National Institute of Dental and Craniofacial Research. (2000). Oral health in America: A Report of the Surgeon General. Rockville: U.S. Department of Health and Human Services.

3 Selwitx RH, Ismail AI, Pitts NB. (2007). Dental caries. Lancet.

4 World Health Organization. “Priority Action Areas,” Oral Health, 2012, http://www.who.int/oral_health/action/groups/en/index1.html.

5 Institute of Medicine. (2011) Advancing Oral Health in America. Washington, DC: National Academy of Sciences. Available at http://www.iom.edu/~/media/Files/Report%20Files/2011/Advancing-Oral-Health-in-America/Advancing%20Oral%20Health%202011%20Report%20Brief.pdf.

6 The Pew Center on States. (2011) The State of Children’s Dental Health: Making Coverage Matter. Washington, DC: The Pew Charitable Trusts. Available at http://www.pewstates.org/uploadedFiles/PCS_Assets/2011/The_State_of_Childrens_Dental_health.pdf.

7 HCUP Clinical Classifications Software (CCS). Healthcare Cost and Utilization Project (HCUP). U.S. Agency for Healthcare Research and Quality, Rockville, MD. Available at http://www.hcup-us.ahrq.gov/toolssoftware/ccs/ccs.jsp. Updated March 2012. (Accessed November 15, 2012).