# Statistical Brief #139 Emergency Department Visits and Hospital Admissions for Kidney Stone Disease, 2009

## Introduction

Kidney stone disease (also known as urolithiasis) represents a significant health care expenditure for the United States. The lifetime prevalence of experiencing kidney stone disease has been estimated to be 13 percent for men and 7 percent for women^1^ though these numbers are on the rise.^2^ Furthermore, the likelihood of reoccurrence has been estimated to be as high as 50 percent within 5 years of the initial event.^3^

Kidney stone disease is frequently treated in the emergency department (ED) due to the pain associated with the condition. Most commonly, patients experience severe flank and lower back pain which may radiate down to the groin. Additional symptoms may include blood in the urine (hematuria), nausea and vomiting.^4^

The decision on how to treat kidney stone disease depends on the severity and location of the stone(s).^5,6^ Small stones, several millimeters in size, often pass without intervention and are often treated with pain medication and observation. Conversely, large stones or those causing significant side effects such as infection, renal (kidney) failure or severe pain require surgical intervention.^3^

The purpose of this Statistical Brief is to analyze ED visits and hospital admissions related to kidney stone disease and to further characterize the frequency of visits to the ED and hospital over time.

In this Statistical Brief we use the term kidney stone disease to represent all stones in the urinary tract. However, stones of the urinary tract can actually be located in several different anatomic locations. Upper urinary tract stones refer to those located in the kidney or ureter (the tube connecting the kidney to the bladder). Lower urinary tract stones refer to those stones located in the bladder or urethra (the tube that allows urine to pass out of the body).

## Findings

Highlights

■ In 2009, there were approximately 1.3 million ED visits for kidney stone disease. On average, there were over 3,600 ED visits for kidney stone disease every day.
■ Rates of ED visits for kidney stone disease have increased 20 percent between 2005 and 2009, from 372 per 100,000 people to 441 per 100,000 people. Rates of hospitalization for kidney stone disease increased 14 percent over the same time period, from 111 per 100,000 people in 2005 to 126 per 100,000 people in 2009.
■ Approximately 20 percent of ED visits for kidney stone disease resulted in a hospitalization; older patients were more likely to be admitted than younger patients.
■ There was a significant rise in the percent of kidney stone-related disease ED visits during the hottest months of the year, particularly in July and August.
■ People living in rural areas were more likely to have an ED visit for kidney stone disease (580 per 100,000 people) than people living in the most urban areas (351 per 100,000) people. However the people in urban areas (25 percent) were more likely to be hospitalized after their ED visit than people in rural areas (14 percent).

In 2009 there were approximately 1.3 million ED visits related to kidney stone disease (table 1). This translates to an average of 3,642 ED visits for kidney stone disease each day. The majority of these visits were treated and released in the ED, while about 20 percent resulted in a hospitalization.

Table 1 Frequency of kidney stone disease visits to the ED, 2009

| All ED visits related to kidney stone disease | Treat and release ED visits related to kidney stone disease | ED visits related to kidney stone disease resulting in a hospitalization
Total number of visits | 1,329,200 | 1,067,900 | 261,300
Principal Diagnosis | 950,200 | 838,100 | 112,100
Not principal Diagnosis | 379,000 | 229,800 | 149,200
Average number of ED visits per day in the U.S. | 3,600 | 2,900 | 700
Rate/100,000 population males per year | 500 | 400 | 100
Rate/100,000 population females per year | 400 | 300 | 100

Source: Agency for Healthcare Research and Quality, Healthcare Cost and Utilization Project, Nationwide Emergency Department Sample, 2009

More than 70 percent of all ED visits related to kidney stone disease had a documented principal diagnosis related to kidney stone disease. Among those with a principal diagnosis of kidney stone disease, the probability of being admitted to the hospital from the ED was 12 percent, while among those without principal diagnosis of kidney stone disease the probability being admitted was significantly higher, 39 percent.

Men (497 per 100,000) were more likely than women (369 per 100,000) to have an ED visit for kidney stone disease. Approximately 43 percent of all kidney stone-related ED visits were for women (table 3). However men and women had identical rates of ED visits resulting in a hospitalization (85 per 100,000).

Table 3 Characteristics of kidney stone disease ED visits, 2009

| All ED visits related to kidney stone disease | Treat and release ED visits related to kidney stone disease | ED visits related to kidney stone disease resulting in a hospitalization
Patient Characteristics
Percentage female | 43.3 | 41.4 | 50.9
Mean Age | 45.9 | 43.6 | 55.5
Percentage died during visit | 0.2 | 0.0 | 0.8
Age group (number per 100,000 people)
<=4 | 2 | 1 | 1
5–17 | 42 | 37 | 6
18–25 | 398 | 357 | 41
26–34 | 630 | 561 | 69
35–44 | 682 | 591 | 91
45–54 | 606 | 502 | 104
55–64 | 571 | 436 | 135
65–74 | 554 | 361 | 193
75–84 | 510 | 242 | 268
85+ | 494 | 158 | 336
Patient location (number per 100,000 people)
Central metropolitan, large | 351 | 263 | 88
Fringe metropolitan, large | 398 | 308 | 91
Metropolitan, medium | 479 | 398 | 80
Metropolitan, small | 471 | 393 | 79
Micropolitan | 515 | 435 | 80
Rural | 580 | 501 | 79
Payer (percentage)
Medicare | 17.7 | 12.7 | 38.2
Medicaid | 12.1 | 11.7 | 13.6
Private | 49.6 | 53.0 | 35.9
Self-pay | 16.0 | 18.0 | 8.0
Other | 4.5 | 4.6 | 4.2
Hospital region (rate per 100,000)
Northeast | 395 | 293 | 102
Midwest | 469 | 378 | 91
South | 490 | 402 | 87
West | 339 | 276 | 63

Source: Agency for Healthcare Research and Quality, Healthcare Cost and Utilization Project, Nationwide Emergency Department Sample, 2009

The vast majority of ED visits for kidney stone disease were related to a stone in the upper urinary tract (table 2), with 55 percent in the kidney and 49 percent in the ureter. (The sum of the specific locations of stones is more than the overall total because the same patient can have stones in multiple locations.) About 2 percent of ED visits for kidney stone disease involved a stone in the lower urinary tract (bladder and urethra).

Table 2 Anatomic location of kidney stone disease visits to the ED, 2009

| All ED visits related to kidney stone disease | Treat and release ED visits related to kidney stone disease | ED visits related to kidney stone disease resulting in a hospitalization
Kidney | 733,300 | 579,500 | 153,700
Ureter | 657,300 | 530,300 | 127,100
Urinary calculus, unspecified^1^ | 15,400 | 13,200 | 2,200
Lower urinary tract^2^ | 28,900 | 18,600 | 10,300

1 Includes uric acid nephrolithiasis (274.11) ED visits

2 Refers to the bladder and urethra

Source: Agency for Healthcare Research and Quality, Healthcare Cost and Utilization Project, Nationwide Emergency Department Sample, 2009

Kidney stone disease ED visits for children and adolescents were rare (table 3). The highest rates of ED visits for kidney stone disease were experienced by persons between the ages of 26 and 64 years, with the highest rates in the 35–44 year age group. Rates of ED visits for kidney stone disease leading to a hospital admission increased uniformly as age increased. The mean age of patients among all ED visits with kidney stone disease was 45.9 years, but patients who were admitted to hospital averaged 55.5 years. This indicates that even though the overall frequency of ED visits for kidney stones decreases with age, the likelihood of a hospital admission as a result of the ED visit increases with age.

ED visits for kidney stone disease were more common among people living in rural areas than among people living in urban areas. In large central metropolitan areas the kidney stone disease ED rate per 100,000 people was 351 per 100,000 people compared to 580 per 100,000 people in rural areas. However, people from large central metropolitan and large fringe metropolitan areas had the highest admission rates from the ED (88 and 91 per 100,000 people respectively), while those from rural, micropolitan, and small metropolitan areas (79, 80, and 79 per 100,000 people respectively) had the lowest admissions rates.

Private insurance was the most common principal payer of kidney stone disease ED visits (50 percent). Medicare was the primary payer for 18 percent of kidney stone disease ED visits overall, but 38 percent of patients admitted to the hospital were covered by Medicare.

ED visits for kidney stone disease were most frequent in the South and Midwest regions at 490 and 469 per 100,000 people respectively, compared to the Northeast and West (395 and 339 per 100,000 people). However, among ED visits leading to a hospitalization, the Northeast (102 per 100,000 people) had the highest rate while the West (63 per 100,000 people) had the lowest rate.

ED visits for kidney stone disease rarely ended in death (0.2 percent).

Table 4 shows the most frequent hospital procedures performed among patients admitted to the hospital following an ED visit with a principal diagnosis of kidney stone disease. Multiple procedures may have been performed during each hospitalization; however, it is possible that definitive treatment of kidney stone disease took place subsequent to the hospitalization and was not captured in our data set.

Table 4 Top 10 procedures performed during hospitalizations following an ED visit with a principal diagnosis of kidney stone disease

Procedure (ICD-9 procedure code) | Number of visits with procedure performed during hospitalization after ED visit for kidney stone disease | Percentage of hospitalizations during which a procedure was performed (denominator=112,100)
Any procedure performed | 78,500 | 70.0
Any top 10 procedure performed | 75,100 | 66.9
Ureteral catheterization (598) | 59,800 | 53.3
Retrograde pyelogram (8774) | 34,200 | 30.5
Transurethral removal of obstruction from ureter and renal pelvis (560) | 32,700 | 29.2
Other cystoscopy (5732) | 15,100 | 13.4
Ureteroscopy (5631) | 10,400 | 9.2
Extracorporeal shockwave lithotripsy of the kidney, ureter, and/or bladder (9851) | 5,300 | 4.8
Computerized axial tomography of abdomen (8801) | 4,500 | 4.0
Percutaneous nephrostomy without fragmentation (5503) | 2,700 | 2.4
Ultrasonic fragmentation of urinary stones (5995) | 1,900 | 1.7
Transurethral clearance of bladder (570) | 1,800 | 1.6

Source: Agency for Healthcare Research and Quality, Healthcare Cost and Utilization Project, Nationwide Emergency Department Sample, 2009 and the Nationwide Inpatient Sample, 2009

Figure 1 displays the monthly number of ED visits for kidney stone disease. There were significantly more ED visits during the hottest months of year, July and August. The number of visits per month varied from a low of 80,000 in February to a high of 108,800 in August.

Figure 1 Percentage of ED visits that are due to kidney stone disease, by month

Source: Agency for Healthcare Research and Quality, Healthcare Cost and Utilization Project, Nationwide Emergency Department Sample (NEDS), 2009

Figure 1. Percentage of ED visits that are due to kidney stone disease, by mouth. Percentage of all ED visits, January, 1.0%, February, 1.0%, March 1.0%, April 1.0%, May 1.0%, June 1.1%, July, 1.1%, August 1.2%, September 1.0%, October 1.0% November 1.0%, December 1.1%. Source: Agency for Healthcare Research and Quality, Healthcare Cost and Utilization Project, Nationwide Emergency Department Sample (NEDS), 2009.

Both ED visits and hospitalizations for kidney stone disease have increased over the past several years, which is consistent with an increased prevalence of kidney stones^7^ (figure 2); however, the increase in ED visits outpaced the increase in hospitalizations. This may be indicative of a change in practice patterns with stones being treated more frequently in an outpatient rather than inpatient setting.^3^

Figure 2 Rates of ED and hospital visits for kidney stone disease per 100,000 people, over time

Source: Agency for Healthcare Research and Quality, Healthcare Cost and Utilization Project, Nationwide Emergency Department Sample, 2005–2009 and the Nationwide Inpatient Sample, 2000–2009

Figure 2. Rates of ED and hospital visits for kidney stone disease per 100,000 people, over time. Rate of visits per 100,000 people; ; ED; in 2005, 372; in 2006, 403; in 2007, 415; in 2008, 423; in 2009, 441. Rate of visits per 100,000 people; ; Hospital; in 2000, 99; in 2001, 103; in 2002, 108; in 2003, 108; in 2004, 109; in 2005, 111; in 2006, 114; in 2007, 115; in 2008, 123; in 2009, 126. Source: Agency for Healthcare Research and Quality, Healthcare Cost and Utilization Project, Nationwide Emergency Department Sample 2005–2009 and the Nationwide Inpatient Sample, 2000–2009.

## Data Source

The estimates in tables 1–3 and Figure 1 in this Statistical Brief are based upon data from the HCUP 2009 Nationwide Emergency Department Sample (NEDS). The estimates in Table 4 and Figure 2 are based upon data from the HCUP 2005–2009 Nationwide Emergency Department Sample (NEDS) and the 2000–2009 Nationwide Inpatient Sample (NIS). Supplemental source included data on the civilian non-institutionalized population from the U.S. Census Bureau (http://www.census.gov/popest/data/national/asrh/2009/2009-nat-ni.html as accessed on Jan 10, 2012) and information in the methods report entitled “Population Denominator Data for Use with the HCUP Databases (Updated with 2009 Population Data”, HCUP Methods Series Report #2010-02. Online April 12, 2010. US Agency for Healthcare Research and Quality (https://www.hcup-us.ahrq.gov/reports/methods/methods.jsp).

## Definitions

### Procedures, diagnoses, and ICD-9-CM

Multiple surgical procedures can be listed on a record in the SID and SASD. A hierarchical algorithm assigns the most extensive procedure (review order of procedures presented under “Case definition”) to each record by evaluating all procedures listed on the record. Procedures are de-duplicated: if a particular procedure occurs multiple times during the same surgical visit or hospital stay, it is counted only once.

Similarly, multiple diagnoses can be listed on a record in the SID and SASD. A hierarchical algorithm assigns the most serious diagnosis (see order of diagnoses presented under “Case definition” below) to each record by evaluating all diagnoses listed on the record.

The principal diagnosis is that condition established after study to be chiefly responsible for the patient’s admission to the hospital. Secondary diagnoses are concomitant conditions that coexist at the time of admission or that develop during the stay.

ICD-9-CM is the International Classification of Diseases, Ninth Revision, Clinical Modification, which assigns numeric codes to diagnoses and procedures. There are about 14,000 ICD-9-CM diagnosis codes and about 4,000 ICD-9-CM procedure codes.

### Case definition

The ICD-9-CM codes defining kidney stone disease include diagnosis codes in the following range. The anatomical location, as reported in Table 2, is specified in parentheses:

- 592.0: Calculus of kidney (Kidney)
- 592.1: Calculus of ureter (Ureter)
- 592.9: Urinary calculus, unspecified (Urinary calculus, unspecified)
- 594.0: Calculus in divericulum of bladder (Lower urinary tract)
- 594.1: Other calculus in bladder (Lower urinary tract)
- 594.2: Calculus in urethra (Lower urinary tract)
- 594.8: Other lower urinary tract calculus (Lower urinary tract)
- 594.9: Calculus of lower urinary tract, unspecified (Lower urinary tract)
- 274.11: Uric acid nephrolithiasis (Urinary calculus, unspecified)

### Types of hospitals included in HCUP

HCUP is based on data from community hospitals, defined as short-term, non-Federal, general and other hospitals, excluding hospital units of other institutions (e.g., prisons). HCUP data include obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded are long-term care, rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. However, if a patient received long-term care, rehabilitation, or treatment for psychiatric or chemical dependency conditions in a community hospital, the discharge record for that stay will be included in the NIS.

### Unit of analysis

The unit of analysis is the ED visit or hospital discharge (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the ED or hospital multiple times in one year will be counted each time as a separate “visit” or “discharge” from the hospital.

### Location of patients’ residence

Place of residence is based on the urban-rural classification scheme for U.S. counties developed by the National Center for Health Statistics (NCHS):

– Large Central Metropolitan: Central counties of metropolitan areas with 1 million or more residents
– Large Fringe Metropolitan: Fringe counties of counties of metropolitan areas with 1 million or more residents
– Medium Metropolitan: Counties in metropolitan areas of 250,000–999,999 residents
– Small Metropolitan: Counties in metropolitan areas of 50,000–249,999 residents
– Micropolitan: Nonmetropolitan counties, i.e., a nonmetropolitan county with an area of 10,000 or more residents
– Rural: Nonmetropolitan and nonmicropolitan counties.

### Payer

Payer is the expected primary payer for the hospital stay. To make coding uniform across all HCUP data sources, payer combines detailed categories into more general groups:

– Medicare: includes fee-for-service and managed care Medicare patients
– Medicaid: includes fee-for-service and managed care Medicaid patients. Patients covered by the State Children’s Health Insurance Program (SCHIP) may be included here. Because most State data do not identify SCHIP patients specifically, it is not possible to present this information separately.
– Private Insurance: includes Blue Cross, commercial carriers, and private HMOs and PPOs
– Other: includes Worker’s Compensation, TRICARE/CHAMPUS, CHAMPVA, Title V, and other government programs
– Uninsured: includes an insurance status of “self-pay” and “no charge.”

When more than one payer is listed for a hospital discharge, the first-listed payer is used.

### Region

Region is one of the four regions defined by the U.S. Census Bureau:

– Northeast: Maine, New Hampshire, Vermont, Massachusetts, Rhode Island, Connecticut, New York, New Jersey, and Pennsylvania
– Midwest: Ohio, Indiana, Illinois, Michigan, Wisconsin, Minnesota, Iowa, Missouri, North Dakota, South Dakota, Nebraska, and Kansas
– South: Delaware, Maryland, District of Columbia, Virginia, West Virginia, North Carolina, South Carolina, Georgia, Florida, Kentucky, Tennessee, Alabama, Mississippi, Arkansas, Louisiana, Oklahoma, and Texas
– West: Montana, Idaho, Wyoming, Colorado, New Mexico, Arizona, Utah, Nevada, Washington, Oregon, California, Alaska, and Hawaii

### Discharge status

Discharge status indicates the disposition of the patient at discharge from the hospital and includes the following six categories: routine (to home); transfer to another short-term hospital; other transfers (including skilled nursing facility, intermediate care, and another type of facility such as a nursing home); home health care; against medical advice (AMA); or died in the hospital.

## For More Information

For more information about HCUP, visit http://www.hcup-us.ahrq.gov.

For additional HCUP statistics, visit HCUPnet, our interactive query system, at www.hcup.ahrq.gov.

For information on other hospitalizations in the U.S., download HCUP Facts and Figures: Statistics on Hospital-Based Care in the United States in 2009, located at http://www.hcup-us.ahrq.gov/reports.jsp (Accessed July 25, 2012).

For a detailed description of HCUP, more information on the design of the NIS, and methods to calculate estimates, please refer to the following publications:

Introduction to the HCUP Nationwide Inpatient Sample, 2009. Online. May 2011. U.S. Agency for Healthcare Research and Quality. Available at http://hcup-us.ahrq.gov/db/nation/nis/NIS_2009_INTRODUCTION.pdf. (Accessed July 25, 2012).

Introduction to the HCUP Nationwide Emergency Department Sample, 2009. Online. September 2011. U.S. Agency for Healthcare Research and Quality. Available at http://hcup-us.ahrq.gov/db/nation/neds/NEDS2009Introductionv3.pdf. (Accessed July 25, 2012).

Houchens RL, Elixhauser A. Using the HCUP Nationwide Inpatient Sample to Estimate Trends. (Updated for 1988–2004). HCUP Methods Series Report #2006–05. Online. August 18, 2006. U.S. Agency for Healthcare Research and Quality. Available at http://www.hcup-us.ahrq.gov/reports/methods/2006_05_NISTrendsReport_1988-2004.pdf. (Accessed July 25, 2012).

1 Pearle MS, Calhoun EA, Curhan GC. (2005). Urologic diseases in America project: urolithiasis. Journal of Urology.

2 Romero V, Akpinar H, Assimos DG. (2010). Kidney stones: A global picture of prevalence, incidence, and associated risk factors. Reviews in Urology.

3 National Institutes of Health http://www.ncbi.nlm.nih.gov/pubmedhealth/PMH0001493/ as accessed on January 12, 2012.

4 Graham A, Luber S, Wolfson AB. (2011). Urolithiasis in the emergency department. Emergency Medicine Clinic of North America.

5 Seitz C, Liatsikos E, Porpiglia F, Tiselius HG, Zwergel U. (2009). Medical therapy to facilitate the passage of stones: what is the evidence?. European Urology.

6 Singh A, Alter H, Littlepage A. (2007). A systematic review of medical therapy to facilitate passage of ureteral calculi. Annals of Emergency Medicine.

7 Scales CD, Smith AC, Hanley JM, Saigal CS. (2012). Prevalence of kidney stones in America. European Urology.