# Statistical Brief #137 Obesity-Related Hospitalizations, 2004 versus 2009

## Introduction

Obesity is a significant public health problem, with more than one-third of adults in the United States being classified as obese (Body Mass Index [BMI] of 30 or greater)^1^ and another one-third classified as overweight (BMI of 25–29.9).^2^ Although the prevalence of obesity doubled for adults between 1980 and 2008,^3^ recent evidence suggests that the rate of increase has been slowing.^4^ From 2007–2008 to 2009–2010 there was no change in the prevalence of obesity in the United States. The prevalence of obesity in women has not changed significantly from 1999–2000 (33.4 percent) to 2009–2010 (35.8 percent), but the prevalence in men increased from 1999–2000 (27.5 percent) to 2009–2010 (35.5 percent).^4^ Men and women now have nearly identical rates of obesity.

Obesity is expensive, with medical care costs related to obesity estimated at nearly $150 billion in 2008. Obese individuals have annual medical care costs that are almost $1,500 higher than costs for those with normal weight.^3^ In addition, obesity is associated with an increased risk of serious medical conditions such as heart disease, type 2 diabetes, cancer, and stroke.^3^

This Statistical Brief presents data from the Healthcare Cost and Utilization Project (HCUP) on obesity-related hospitalizations in 2009, updating previously published information from 2004.^5^ Characteristics of patients, usage and costs of hospital stays, associated diagnoses, and procedures performed are examined for patients admitted primarily for obesity and for those with a secondary diagnosis—or comorbidity—of obesity. All differences between estimates noted in the text are statistically significant at the .001 level.

## Findings

Highlights

■ In 2009, there were 2.8 million hospital stays in which obesity was a principal or secondary diagnosis, accounting for more than 9 percent of hospital stays. This represents an increase from about 3 percent of hospital stays in 1996 and 6 percent of stays in 2004.
■ The vast majority of obesity-related hospitalizations in 2009 involved obesity as a secondary diagnosis (95 percent).
■ Hospital stays with obesity as a principal diagnosis remained relatively stable at about 0.4 percent of stays between 2004 and 2009. The rate of hospitalization in 2009 was highest among females and patients ages 18–44 and 45–64.
■ Hospital stays with obesity as a secondary diagnosis increased from 5.3 percent of stays in 2004 to 8.9 percent of stays in 2009. The rate of hospitalization in 2009 increased with age and was highest among females and patients in the Midwest.
■ For hospital stays with obesity as a principal diagnosis, the most common procedure performed in 2009 was bariatric surgery (89.3 percent of stays), virtually unchanged from 2004.
■ For hospital stays with obesity as a secondary diagnosis, the most common principal diagnosis in 2009 was osteoarthritis, accounting for 5.6 percent of stays. This represents an increase from 4.4 percent of stays in 2004.

### Overall trends in hospital stays related to obesity

In 2009, there were approximately 2.8 million hospital stays for which obesity was either a principal or secondary diagnosis (excluding infants and maternal stays). The share of obesity-related hospitalizations increased from 3 percent of all stays in 1996 (data not shown) to more than 9 percent of all stays in 2009. As shown in figure 1, the vast majority of obesity-related hospitalizations involved obesity as a secondary diagnosis, increasing from 766,600 stays in 1996 to 2,716,200 stays in 2009 (a 3.5-fold increase). Hospitalizations with obesity as a principal diagnosis were much less common but also increased from 10,100 stays in 1996 to 132,900 stays in 2009 (a 13-fold increase). These increases are considerably higher than the increase in prevalence of obesity in the United States (48 percent increase from 1994 to 2008).^6^

Figure 1 Hospital stays with obesity as a principal or secondary diagnosis, 1996–2009

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 1996–2009

Figure 1. Hospital stays with obesity as a principal or secondary diagnosis, 1996–2009. Trend line chart; discharges with obesity as a principal diagnosis, trended upward slightly from 1996 through 2009, leveling out in 2008 and 2009 at just more than 100,000 discharges. Discharges with obesity as a secondary diagnosis trended upward at a much faster rate, beginning in 1996 at about 750,000 and continuing upward at 2,750,000 in 2009. Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 1996–2009

### Differences in hospital stays related to obesity

Table 1 compares hospital stays with a principal diagnosis of obesity to stays with obesity as a secondary diagnosis and stays with no mention of obesity, excluding infant and maternal stays.

Table 1 Hospital stays^1^ related to obesity compared to stays with no mention of obesity, 2004 versus 2009

| Obesity appears on the discharge record | | | | No mention of obesity
| As a principal diagnosis | | As a secondary diagnosis | | No mention of obesity
| 2004 | 2009 | 2004 | 2009 | 2004 | 2009
Number of discharges (stays) | 126,200 | 132,900 | 1,567,200 | 2,716,200 | 27,756,400 | 27,632,300
Percentage of all stays | 0.4% | 0.4% | 5.3% | 8.9% | 94.2% | 90.7%
Rate per 10,000 population^2^ | 4.3 | 4.3 | 53.5 | 88.5 | 947.2 | 900.1
Age distribution^2^ (rate per 10,000 population)^3^
18–44 | 6.2 | 5.6 | 33.0 | 48.4 | 470.9 | 428.4
45–64 | 7.7 | 7.8 | 102.7 | 157.6 | 1,100.1 | 1,046.4
65 and older | 0.4 | 1.9 | 123.0 | 223.9 | 3,477.8 | 3,196.9
Sex^2^ (rate per 10,000 population)
Female | 6.9 | 6.6 | 66.9 | 107.0 | 990.4 | 926.6
Male | 1.5 | 2.0 | 39.5 | 69.4 | 895.1 | 867.3
U.S. region^2^ (rate per 10,000 population)
Northeast | 5.8 | 4.8 | 45.3 | 74.1 | 1,056.1 | 1,055.9
Midwest | 4.1 | 5.6 | 60.6 | 106.7 | 1,009.0 | 949.9
South | 4.0 | 3.7 | 59.2 | 95.7 | 1,014.2 | 920.4
West | 3.9 | 3.8 | 44.1 | 71.0 | 692.4 | 701.0
Patient’s residence^4^ (rate per 10,000 population)
Urban areas | 4.3 | 4.1 | 51.5 | 83.7 | 904.1 | 842.4
Rural areas | 4.5 | 4.4 | 63.3 | 103.6 | 1,162.0 | 1,054.0
Community-level income (median household income for patient’s ZIP Code)^4^ (rate per 10,000 population)
Lowest quartile | 3.6 | 3.6 | 62.7 | 106.0 | 1,077.7 | 1,008.5
Other | 4.4 | 4.4 | 48.7 | 79.7 | 873.8 | 826.4
Mean length of stay, days | 3.1 | 2.2 | 4.9 | 5.2 | 5.1 | 5.0
Aggregate costs (billions)^5^ | $1.7 | $1.6 | $15.6 | $31.8 | $283.0 | $294.9
Percentage of total aggregate costs | 0.6% | 0.5% | 5.2% | 9.7% | 94.2% | 89.8%
Mean cost per stay, dollars^5^ | $13,200 | $12,400 | $10,000 | $11,700 | $10,200 | $10,700

1 Infant and maternal stays were excluded from counts of discharges (stays).

2 Population denominator data for the overall rate and rates for patient age, sex, and U.S. region were based on U.S. Census Bureau, Population Division, Annual Estimates of the Resident Population for the United States.

3 Ages 0–17 are not reported here. For complete information on this age group, see Wier LM, Encinosa W. Obesity in Children: Hospitalizations from 2000 to 2009. HCUP Statistical Brief #138. July 2012. Agency for Healthcare Research and Quality, Rockville, MD. Available at http://www.hcup-us.ahrq.gov/reports/statbriefs/sb138.pdf.

4 Population denominator data for rates for patient’s residence and community-level income were based on Claritas Population Estimates.

5 Aggregate costs and mean cost per stay in 2004 are inflation-adjusted to 2009 dollars.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2004, 2009

In 2009, there were 132,900 hospital stays (0.4 percent of all stays) with obesity as a principal diagnosis. Nearly all of these stays (99.6 percent) had a diagnosis of morbid obesity, which is defined as at least twice a person’s ideal weight, 100 pounds overweight, or a body mass index that is greater than 39. The number of stays with a principal diagnosis of obesity remained relatively stable between 2004 and 2009.

There were 2.7 million hospital stays with obesity as a secondary diagnosis in 2009. Just over one-third of these stays (38.9 percent) had a diagnosis of morbid obesity. The number of hospital stays with obesity as a secondary diagnosis increased from 1.6 million (5.3 percent of all stays) in 2004 to 2.7 million (8.9 percent of all stays) in 2009.

In 2009, there were 4.3 hospital stays with obesity as a principal diagnosis per 10,000 population, with no change from 2004. Patients ages 18–44 and 45–64 had higher rates of hospitalization with obesity as a principal diagnosis (5.6 and 7.8 stays, respectively) compared to adults age 65 and older (1.9 stays). Females had a higher rate of hospitalization with obesity as a principal diagnosis (6.6 stays per 10,000) than did males (2.0 stays). There was no difference in the rate of hospitalization principally for obesity by region, urban/rural residence, or community-level income.

In 2009, there were 88.5 stays per 10,000 population with obesity as a secondary diagnosis. This represents a 65 percent increase from 53.5 stays per 10,000 in 2004. The rate of hospitalization with obesity as a secondary diagnosis increased with the patient’s age. Females had a 54 percent higher rate of hospitalization with obesity as a secondary diagnosis (107.0 stays per 10,000) than did males (69.4 stays). The rate of hospitalization for stays with no mention of obesity was not significantly different for males and females.

The rate of hospitalization with obesity as a secondary diagnosis in 2009 was higher in the Midwest (106.7 stays per 10,000) than in the Northeast and West (74.1 and 71.0 stays, respectively). The rate for the South (95.7 stays) was not significantly different from the other regions. The rate of hospitalization with obesity as a secondary diagnosis also was higher among stays in communities from the lowest income quartile (106.0 stays) versus higher income communities (79.7 stays)—a 33 percent difference. There was no difference in the rate of hospitalization with obesity as a secondary diagnosis by patient’s residence (rural versus urban).

The length of stay for hospitalizations with obesity as a principal diagnosis decreased from 3.1 days in 2004 to 2.2 days in 2009. The length of stay for hospitalizations with obesity as a secondary diagnosis increased from 4.9 days in 2004 to 5.2 days in 2009. There was no change in the length of stay for hospitalizations with no mention of obesity (5.1 days in 2004 versus 5.0 days in 2009).

In 2009, hospital stays with obesity as a principal diagnosis accounted for $1.6 billion, essentially unchanged from 2004, and the mean cost per stay was $12,400. Hospital stays with obesity as a secondary diagnosis cost $31.8 billion in 2009, double the amount in 2004, and the mean cost per stay was $11,700, up from $10,000 in 2004. Compared with hospitalizations with no mention of obesity, the mean cost per stay for hospitalizations with obesity as a secondary diagnosis was 9 percent higher in 2009. Overall, hospital stays with any mention of obesity accounted for $33.4 billion (10.2 percent) of aggregate hospital costs in 2009.

### Procedures related to obesity

Table 2 lists the five most common procedures performed in 2009 during hospital stays for which obesity was the principal diagnosis. Approximately 89.3 percent of stays in 2009 involved bariatric surgery, virtually unchanged from 2004. Other common procedures performed in 2009 were upper gastrointestinal endoscopy and biopsy (14.4 percent) and diaphragmatic hernia repair (12.0 percent), which increased from 1.5 percent of procedures performed in 2004.

Table 2 Most common all-listed procedures for patients with obesity as a principal diagnosis, 2004 versus 2009

Rank | | All-listed procedure | 2004 | | 2009
2004 | 2009 | All-listed procedure | Number of stays | Percentage | Number of stays | Percentage
1 | 1 | Bariatric surgery | 114,100 | 90.3 | 118,700 | 89.3
4 | 2 | Upper gastrointestinal endoscopy; biopsy | 13,100 | 10.4 | 19,200 | 14.4
16 | 3 | Diaphragmatic hernia repair | 1,900 | 1.5 | 15,900 | 12.0
11 | 4 | Gastrectomy; partial and total | 3,400 | 2.7 | 13,900 | 10.5
6 | 5 | Excision; lysis peritoneal adhesions | 10,200 | 8.1 | 13,700 | 10.3

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2004, 2009

### Conditions related to obesity

Table 3 lists the 10 most common principal diagnoses in 2009 for hospital stays where obesity was a secondary diagnosis (i.e., a coexisting condition). The most common principal diagnosis was osteoarthritis, which accounted for 5.6 percent of the hospital stays with obesity as a secondary diagnosis in 2009. Osteoarthritis was twice as common as a principal diagnosis among stays with obesity as a secondary diagnosis compared to stays with no mention of obesity (data not shown).

Table 3 Principal diagnosis for hospital stays with a secondary diagnosis of obesity, 2004 versus 2009

Rank | | Principal diagnosis | Percentage of stays with this principal diagnosis among stays with obesity as a secondary diagnosis
2004 | 2009 | Principal diagnosis | 2004 | 2009 | Percentage change
4 | 1 | Osteoarthritis | 4.4 | 5.6 | 27%
3 | 2 | Congestive heart failure; nonhypertensive | 5.6 | 4.7 | −15%
1 | 3 | Coronary atherosclerosis and other heart disease | 6.8 | 4.3 | −37%
2 | 4 | Nonspecific chest pain | 5.8 | 3.7 | −36%
5 | 5 | Skin and subcutaneous tissue infections | 3.6 | 3.7 | 3%
10 | 6 | Cardiac dysrhythmias | 2.5 | 3.1 | 20%
8 | 7 | Pneumonia (except that caused by tuberculosis or sexually transmitted disease) | 2.9 | 3.1 | 6%
14 | 8 | Chronic obstructive pulmonary disease and bronchiectasis | 2.2 | 3.0 | 34%
6 | 9 | Mood disorders | 3.2 | 2.7 | −14%
7 | 10 | Acute myocardial infarction | 3.1 | 2.7 | −13%

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2004, 2009

The most common principal diagnoses for stays with obesity as a secondary diagnosis were the same in 2004 as in 2009, with the exception of chronic obstructive pulmonary disease and bronchiectasis, which was not in the top 10 in 2004. There was also a change in 2009 in the rank order of the principal diagnoses. For example, osteoarthritis was the fourth most common principal diagnosis in 2004; it increased 27 percent to become the most common diagnosis in 2009. In 2004, coronary atherosclerosis was the most common principal diagnosis, accounting for 6.8 percent of all stays; it decreased 37 percent to become the third most common diagnosis in 2009.

## Data Source

The estimates in this Statistical Brief are based upon data from the HCUP Nationwide Inpatient Sample (NIS) for 2004 and 2009. Historical data were drawn from the 1996–2009 NIS. Supplemental sources included data on regional population estimates from “Table 1: Annual Estimates of the Resident Population for the United States, Regions, States, and Puerto Rico: April 1, 2000 to July 1, 2009 (NST-EST2009-01),” Population Division, U.S. Census Bureau, Release date: December 2009 (http://www.census.gov/popest/data/historical/2000s/vintage_2009/index.html).

Many hypothesis tests were conducted for this Statistical Brief. Thus, to decrease the number of false-positive results, we reduced the significance level to .001 for individual tests.

## Definitions

### Diagnoses, procedures, ICD-9-CM, and Clinical Classifications Software (CCS)

The principal diagnosis is that condition established after study to be chiefly responsible for the patient’s admission to the hospital. All-listed procedures include all procedures performed during the hospital stay whether for definitive treatment or for diagnostic or exploratory purposes.

ICD-9-CM is the International Classification of Diseases, Ninth Revision, Clinical Modification, which assigns numeric codes to diagnoses and procedures. There are about 14,000 ICD-9-CM diagnosis codes and about 4,000 ICD-9-CM procedure codes.

CCS categorizes ICD-9-CM diagnoses and procedures into a manageable number of clinically meaningful categories.^7^ This “clinical grouper” makes it easier to quickly understand patterns of diagnoses and procedures.

In “Table 2. Most common all-listed procedures for patients with obesity as a principal diagnosis, 2004 versus 2009,” two “Other” CCS categories were top-ranked in 2009: CCS 94 (Other OR upper GI therapeutic procedures) and CCS 86 (Other hernia repair procedures). Upon examination of the constituent ICD-9-CM codes for these two CCS categories, two types of procedures were identified as the predominant procedures for patients with obesity as a principal diagnosis: bariatric surgery (within CCS 94) and diaphragmatic hernia repair (within CCS 86). These procedure types were removed from these two CCS categories and analyzed separately. The associated ICD-9-CM codes are as follows:

- Bariatric surgery (procedure codes within CCS 94): 44.31, 44.38, 44.39, 44.68, 44.95, 44.96, 44.97, 44.98
- Diaphragmatic hernia repair (procedure codes within CCS 86): 53.7, 53.71, 53.72, 53.75, 53.80, 53.81, 53.83, 53.84

### Case definition

The ICD-9-CM diagnosis codes defining obesity are 278.00 (obesity, unspecified) and 278.01 (morbid obesity). These codes were introduced in 1995. In 2005, diagnosis code 278.02 (overweight) was introduced. This new code is not included in the analyses, and there is no evidence that “overweight” cases were miscoded as “obesity” cases in prior years. Code 278.02 includes relatively few cases (less than 100,000 each year) and the trend in number of discharges for obesity (278.00 and 278.01) appears to be unaffected by the introduction of code 278.02 (smooth, increasing trend line for discharges with “overweight” as an included diagnosis code).

### Types of hospitals included in HCUP

HCUP is based on data from community hospitals, defined as short-term, non-Federal, general, and other hospitals, excluding hospital units of other institutions (e.g., prisons). HCUP data include obstetrics and gynecology, otolaryngology, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded are long-term care, rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. However, if a patient received long-term care, rehabilitation, or treatment for psychiatric or chemical dependency conditions in a community hospital, the discharge record for that stay will be included in the NIS.

### Unit of analysis

The unit of analysis is the hospital discharge (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the hospital multiple times in one year will be counted each time as a separate “discharge” from the hospital.

### Costs and charges

Total hospital charges were converted to costs using HCUP Cost-to-Charge Ratios based on hospital accounting reports from the Centers for Medicare & Medicaid Services (CMS).^8^ Costs will reflect the actual expenses incurred in the production of hospital services, such as wages, supplies, and utility costs; charges represent the amount a hospital billed for the case. For each hospital, a hospital-wide cost-to-charge ratio is used. Hospital charges reflect the amount the hospital billed for the entire hospital stay and do not include professional (physician) fees. For the purposes of this Statistical Brief, costs are reported to the nearest hundred.

### Location of patients’ residence

Place of residence is based on the urban-rural classification scheme for U.S. counties developed by the National Center for Health Statistics (NCHS). For this Statistical Brief, we collapsed the NCHS categories into either urban or rural according to the following:

Urban:

- Large Central Metropolitan: includes metropolitan areas with 1 million or more residents
- Large Fringe Metropolitan: includes counties of metropolitan areas with 1 million or more residents
- Medium and Small Metropolitan: includes areas with 50,000 to 999,999 residents.

Rural:

- Micropolitan and Noncore: includes nonmetropolitan counties (i.e., counties with no town greater than 50,000 residents).

### Median community-level income

Median community-level income is the median household income of the patient’s ZIP Code of residence. The cut-offs for the quartile designation are determined using ZIP Code demographic data obtained from Claritas. The income quartile is missing for homeless and foreign patients.

### Region

Region is one of the four regions defined by the U.S. Census Bureau:

– Northeast: Maine, New Hampshire, Vermont, Massachusetts, Rhode Island, Connecticut, New York, New Jersey, and Pennsylvania
– Midwest: Ohio, Indiana, Illinois, Michigan, Wisconsin, Minnesota, Iowa, Missouri, North Dakota, South Dakota, Nebraska, and Kansas
– South: Delaware, Maryland, District of Columbia, Virginia, West Virginia, North Carolina, South Carolina, Georgia, Florida, Kentucky, Tennessee, Alabama, Mississippi, Arkansas, Louisiana, Oklahoma, and Texas
– West: Montana, Idaho, Wyoming, Colorado, New Mexico, Arizona, Utah, Nevada, Washington, Oregon, California, Alaska, and Hawaii

## For More Information

For more information about HCUP, visit http://www.hcup-us.ahrq.gov/.

For additional HCUP statistics, visit HCUPnet, our interactive query system, at http://hcupnet.ahrq.gov/.

For information on other hospitalizations in the United States, download HCUP Facts and Figures: Statistics on Hospital-Based Care in the United States in 2009, located at http://www.hcup-us.ahrq.gov/reports.jsp.

For a detailed description of HCUP, more information on the design of the NIS, and methods to calculate estimates, please refer to the following publications:

Introduction to the HCUP Nationwide Inpatient Sample, 2009. Online. May 2011. U.S. Agency for Healthcare Research and Quality. Available at http://hcup-us.ahrq.gov/db/nation/nis/NIS_2009_INTRODUCTION.pdf. (Accessed June 15, 2012).

Houchens R, Elixhauser A. Final Report on Calculating Nationwide Inpatient Sample (NIS) Variances, 2001. HCUP Methods Series Report #2003-2. Online. June 2005 (revised June 6, 2005). U.S. Agency for Healthcare Research and Quality. Available at http://www.hcup-us.ahrq.gov/reports/methods/CalculatingNISVariances200106092005.pdf. (Accessed June 15, 2012).

Houchens RL, Elixhauser A. Using the HCUP Nationwide Inpatient Sample to Estimate Trends. (Updated for 1988–2004). HCUP Methods Series Report #2006-05. Online. August 18, 2006. U.S. Agency for Healthcare Research and Quality. Available at http://www.hcup-us.ahrq.gov/reports/methods/2006_05_NISTrendsReport_1988-2004.pdf. (Accessed June 15, 2012).

1 http://www.cdc.gov/obesity/data/adult.html. (Accessed June 15, 2012).

2 http://www.cdc.gov/nchs/data/hestat/overweight/overweight_adult_03.htm. (Accessed June 15, 2012).

3 http://www.cdc.gov/chronicdisease/resources/publications/aag/obesity.htm. (Accessed June 15, 2012).

4 Ogden CL, Carroll MD, Kit BK, Flegal KM. Prevalence of obesity in the United States, 2009–2010. NCHS data brief, no 82. Hyattsville, MD: National Center for Health Statistics. 2012.

5 Elixhauser A, Steiner C. Obese Patients in U.S. Hospitals, 2004. HCUP Statistical Brief #20. December 2006. Agency for Healthcare Research and Quality, Rockville, MD. http://www.hcup-us.ahrq.gov/reports/statbriefs/sb20.pdf. (Accessed June 15, 2012).

6 http://www.cdc.gov/nchs/data/hestat/obesity_adult_07_08/obesity_adult_07_08.htm. (Accessed June 15, 2012).

7 HCUP CCS. Healthcare Cost and Utilization Project (HCUP). U.S. Agency for Healthcare Research and Quality, Rockville, MD. Available at http://www.hcup-us.ahrq.gov/toolssoftware/ccs/ccs.jsp. Updated March 2012. (Accessed June 15, 2012).

8 HCUP Cost-to-Charge Ratio Files (CCR). Healthcare Cost and Utilization Project (HCUP). 2001–2008. U.S. Agency for Healthcare Research and Quality, Rockville, MD. Available at http://www.hcup-us.ahrq.gov/db/state/costtocharge.jsp. Updated August 2011. (Accessed June 15, 2012).