# Statistical Brief #114 Sports Related Concussions, 2008

## Introduction

Sports related concussions have attracted increasing public attention in recent years. In January 2011, Congress reintroduced legislation to set minimum safety standards for concussion management in public schools.^1^ As of March 2011, a dozen states^2^ have laws in place that promote the use of established protocols that guide the management of student athletes who suffer concussions. More states^3^ are following suit with similar legislation pending. Without appropriate management, sports related concussions can have adverse effects on a student’s school performance and social functioning, and can cause long-term symptoms and complications.

This Statistical Brief presents data from the Healthcare Cost and Utilization Project (HCUP) on emergency department (ED) visits and inpatient admissions for sports related concussions in 2008. Patient demographic characteristics (age, gender, and region), hospital characteristics (teaching and trauma center status), and clinical characteristics (loss of consciousness) are compared between sports related and non-sports related concussions. Top concurrent conditions are also compared between these two types of concussions. All differences between estimates noted in the text are statistically significant at the 0.05 level or better.

## Findings

Highlights

- In 2008, about 44,000 ED visits were related to concussions that occurred during sports activities.
- Fifty-eight percent of sports related concussion ED visits was for youth 14 to 18 years of age, 17 percent for 11- to 13-year olds, and another 8 percent by 19- to 23-year olds.
- Overall, half of sports related concussions were associated with no loss of consciousness, one-fifth of cases had brief loss of consciousness, 12 percent had moderate or prolonged loss of consciousness, and the remainder was unspecified.
- The vast majority (95 percent) of sports related concussion ED cases were discharged home compared to 80 percent of non-sports related concussions.
- Twenty-five percent of hospitalized patients had suffered moderate or prolonged loss of consciousness, compared to 11 percent of patients who were treated and released from the ED.
- Concurrent conditions tended to be more serious when concussion was listed as a secondary condition, and included open wounds of the head, neck and trunk, and skull and face fractures.

In 2008, there were approximately 44,000 ED visits for sports related concussions; of all ED visits for concussion, 7.4 percent were related to sports. Table 1 compares the distribution of ED visits for sports related concussions to non-sports related concussions by patient demographic and clinical characteristics, and hospital characteristics.

Table 1 Characteristics of emergency department (ED) visits related to concussion, 2008

| ED visits for concussion^*^
| Sports related | Non-sports related
Total number of visits | 43,802 | 549,012
Percentage of all ED visits | 0.04 | 0.44
Patient characteristics
Gender (percentage)
Male | 77.8 | 58.3
Female | 22.2 | 41.7
Region, rate per 10,000 population
Northeast | 2.1 | 16.8
Midwest | 1.7 | 21.4
South | 1.0 | 17.4
West | 1.2 | 15.8
Clinical characteristics
Loss of consciousness (percentage)
No loss | 51.6 | 39.9
Brief loss | 21.1 | 19.2
Moderate or prolonged loss | 11.6 | 25.0
Unspecified | 15.6 | 15.9
Hospital characteristics
Teaching status (percentage)
Yes | 38.8 | 39.9
No | 61.2 | 60.1
Trauma center status (percentage)
Yes | 39.2 | 44.1
No | 60.8 | 55.9

* Based on all-listed diagnoses.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Emergency Department Sample, 2008

In 2008, males accounted for more than three-quarters of ED visits for concussion related to sports. This compares to 58.3 percent of males with non-sports related concussions.

The rate of ED visits for sports related concussions was higher in the Northeast and Midwest regions at 2.1 and 1.7 per 10,000 population, compared to the South and West (1.0 and 1.2 per 10,000). The rate of ED visits for non-sports related concussions was between 7 and 16 times higher than sports related concussions and was the highest in the Midwest region of the U.S.

More than half of ED patients diagnosed with a sports related concussion experienced no loss of consciousness (51.6 percent) and another one-fifth experienced a brief loss of consciousness (21.1 percent). In comparison, ED patients with a non-sports related concussion were more likely to report loss of consciousness—one-quarter of them experienced moderate or prolonged loss of consciousness, more than twice the proportion of ED patients diagnosed with a sports related concussion (11.6 percent).

Emergency departments of teaching hospitals treated a little more than one-third of visits for concussion, regardless of whether the concussion was sports related or not. Thirty-nine percent of ED visits for sports related concussions occurred in an ED with a designated trauma center, compared to 44.1 percent of ED visits for non-sports related concussions.

### Sports related concussions by patient age

The ED visits for sports related concussion are highly concentrated in school age children. Figure 1 shows the age distribution of sports related and non-sports related concussions in 2008. Of all ED visits for sports related concussion, more than half (57.9 percent) were for high school age children (14–18 years of age). Another 16.8 percent were for middle school age children (11–13 years of age). Less than one-tenth of ED patients diagnosed with sports related concussion were 24 and older. In contrast, the majority of non-sports related concussion ED visits (58.4 percent) occurred in patients 24 and older.

Figure 1 Age distribution for sports related compared to non-sports related concussions, 2008

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Emergency Department Sample, 2008

Stacked bar chart; percentage; Sports related, ages 1 through 5, 0.9; 6 through 10, 6.5; 11 through 13, 16.8; 14 through 18, 57.9; 19 through 23, 8.3; 24 through 30, 4.0; 31 and over, 5.6; Non-sports related, ages 1 through 5, 5.9; 6 through 10, 5.0; 11 through 13, 4.3; 14 through 18, 13.7; 19 through 23, 12.7; 24 through 30, 12.1; 31 and over, 46.3

### Patient discharge status for sports related concussions

Figure 2 shows that the vast majority (95.4 percent) of ED visits in patients with a sports related concussion were discharged home. Only 3.7 percent of patients were admitted to the same hospital or transferred to another hospital for further treatment. For ED visits following non-sports related concussions, 17.3 percent were admitted or transferred to another hospital.

Figure 2 Discharge status of ED visits for sports related compared to non-sports related concussions, 2008

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Emergency Department Sample, 2008

Stacked bar chart; percentage; Sports related; routine discharge, 95.4; transferred or admitted to hospital, 3.7; other, 0.9; Non-sports related; routine discharge, 80.4; transferred or admitted to hospital, 17.3; other, 2.3

### Level of consciousness by patient discharge status for sports related concussion

A higher proportion of patients who were hospitalized after an ED visit for sports related concussion experienced loss of consciousness than those who were discharged home (figure 3). Thirty-six percent of hospitalized patients experienced brief loss of consciousness, compared to 20.7 percent of those sent home. The proportion of hospitalized patients who had suffered moderate or prolonged loss of consciousness (25.2 percent) was more than double that of patients routinely discharged (11.1 percent).

Figure 3 Level of loss of consciousness by patient discharge status for sports related concussions, 2008

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Emergency Department Sample, 2008

Stacked bar chart; percentage;Routine discharge; no loss, 52.5; brief loss, 20.7; moderate or prolonged loss, 11.1; unspecified, 15.8. Transferred or admitted to hospital; no loss, 29.1; brief loss, 36.2; moderate or prolonged loss, 25.2; unspecified, 9.4.

### Top conditions associated with sports related concussion

Table 2 provides the top 10 conditions associated with concussion. For ED visits with concussion listed as the principal diagnosis, the associated conditions were less serious than when concussion was listed as a secondary diagnosis. For sports related concussion cases, open wounds of head, neck and trunk, skull and face fractures, and fracture of upper limb were all more frequent when concussion was listed as a secondary condition. Less serious conditions such as a superficial injury or contusion, sprains and strains, and headache were associated with sport related concussion listed as a principal diagnosis.

Table 2 Conditions associated with sports related concussions, 2008

Concussion listed as the principal diagnosis | | | Concussion listed as a secondary diagnosis
| Associated secondary conditions | | Associated principal conditions
Rank | CCS condition | Percentage of all associated conditions | CCS condition | Percentage of all associated conditions
1 | Superficial injury; contusion | 18.9 | Superficial injury; contusion | 25.7
2 | Sprains and strains | 13.1 | Open wounds of head; neck; and trunk | 19.5
3 | Headache; including migraine | 9.4 | Other injuries and conditions due to external causes | 18.9
4 | Open wounds of head; neck; and trunk | 5.6 | Sprains and strains | 11.5
5 | Nausea and vomiting | 4.5 | Skull and face fractures | 7.5
6 | Other injuries and conditions due to external causes | 4.5 | Headache; including migraine | 3.9
7 | Asthma | 4.5 | Fracture of upper limb | 1.4
8 | Spondylosis; intervertebral disc disorders; other back problems | 4.4 | Spondylosis; intervertebral disc disorders; other back problems | 1.4
9 | Conditions associated with dizziness or vertigo | 2.4 | Syncope | 1.2
10 | Skull and face fractures | 1.8 | Delirium, dementia, and amnestic and other cognitive disorders | 1.1

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Emergency Department Sample, 2008

## Data Source

The estimates in this Statistical Brief are based upon data from the HCUP 2008 Nationwide Emergency Department Sample (NEDS). Supplemental sources included data from the U.S. Census Bureau, Population Division, Annual Estimates of the Population for the United States, Regions, and Divisions.

## Definitions

### Diagnoses, ICD-9-CM, and Clinical Classifications Software (CCS)

The principal diagnosis is that condition established after study to be chiefly responsible for the patient’s admission to the hospital. Secondary diagnoses are concomitant conditions that coexist at the time of admission or that develop during the stay. All-listed diagnoses include the principal diagnosis plus these additional secondary conditions.

ICD-9-CM is the International Classification of Diseases, Ninth Revision, Clinical Modification, which assigns numeric codes to diagnoses. There are about 13,600 ICD-9-CM diagnosis codes.

CCS categorizes ICD-9-CM diagnoses into a manageable number of clinically meaningful categories.^4^ This “clinical grouper” makes it easier to quickly understand patterns of diagnoses and procedures.

### Case definition

The ICD-9-CM codes defining concussion include diagnosis codes with ‘850’ in the first three digits. Sports related concussion is defined as concussion that has E code ‘E9170’ or ‘E9175’, or ‘E886’.

### Types of hospitals included in HCUP

HCUP is based on data from community hospitals, defined as short-term, non-Federal, general and other hospitals, excluding hospital units of other institutions (e.g., prisons). HCUP data include OB-GYN, ENT, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded are long-term care, rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. Please note, a discharge of this nature will be included in the NIS if it occurred in a community hospital.

### Unit of analysis

The unit of analysis is the ED visit or hospital discharge (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the ED or hospital multiple times in one year will be counted each time as a separate “visit” or “discharge” from the hospital.

### Region

Region is one of the four regions defined by the U.S. Census Bureau:

– Northeast: Maine, New Hampshire, Vermont, Massachusetts, Rhode Island, Connecticut, New York, New Jersey, and Pennsylvania
– Midwest: Ohio, Indiana, Illinois, Michigan, Wisconsin, Minnesota, Iowa, Missouri, North Dakota, South Dakota, Nebraska, and Kansas
– South: Delaware, Maryland, District of Columbia, Virginia, West Virginia, North Carolina, South Carolina, Georgia, Florida, Kentucky, Tennessee, Alabama, Mississippi, Arkansas, Louisiana, Oklahoma, and Texas
– West: Montana, Idaho, Wyoming, Colorado, New Mexico, Arizona, Utah, Nevada, Washington, Oregon, California, Alaska, and Hawaii

### Discharge status

Discharge status indicates the disposition of the patient at discharge from the hospital, and includes the following six categories: routine (to home), transfer to another short-term hospital, other transfers (including skilled nursing facility, intermediate care, and another type of facility such as a nursing home), home health care, against medical advice (AMA), or died in the hospital.

## For More Information

For more information about HCUP, visit www.hcup-us.ahrq.gov.

For additional HCUP statistics, visit HCUPnet, our interactive query system, at www.hcup.ahrq.gov.

For information on other hospitalizations in the U.S., download HCUP Facts and Figures: Statistics on Hospital-Based Care in the United States in 2008, located at http://www.hcup-us.ahrq.gov/reports.jsp.

For a detailed description of HCUP, more information on the design of the NEDS, and methods to calculate estimates, please refer to the following publications:

Introduction to the HCUP Nationwide Emergency Department Sample, 2008. Online. October 2010. U.S. Agency for Healthcare Research and Quality. http://hcup-us.ahrq.gov/db/nation/neds/NEDS2008Introductionv3.pdf

1 H.R.469—The Protecting Student Athletes from Concussions Act of 2011.

2 States with current legislation include Connecticut, Idaho, Massachusetts, New Jersey, New Mexico, Oklahoma, Oregon, Rhode Island, South Dakota, Texas, Virginia, and Washington.

3 States with pending legislation include Alaska, Arizona, California, Colorado, District of Columbia, Florida, Hawaii, Illinois, Indiana, Iowa, Kansas, Maine, Maryland, Missouri, Nebraska, New York, North Dakota, Ohio, Pennsylvania, Tennessee, Utah, Vermont, and Wyoming.

4 HCUP CCS. Healthcare Cost and Utilization Project (HCUP). December 2009. U.S. Agency for Healthcare Research and Quality, Rockville, MD. www.hcup-us.ahrq.gov/toolssoftware/ccs/ccs.jsp