# Statistical Brief #110 Hospitalizations Related to Childbirth, 2008

## Introduction

In 2008, childbirth continued to be the most common reason for hospitalization in U.S. hospitals^1^—despite declining to 4.2 million total stays from a high of 4.5 million in 2007. Most of these (67 percent) were delivered vaginally, and the majority of vaginal deliveries (57 percent) occurred without complications or serious procedures.

Over the last several years, there has been a dramatic shift in the utilization of certain obstetric procedures. These changes in the use of certain childbirth-related procedures have garnered media attention and stimulated interest in research on the safety, clinical outcomes, and economic implications of shifts in mode of delivery and utilization of obstetric procedures. Cesarean sections (C-sections) have grown from 21 percent of childbirths in 1997 to 33 percent in 2008.^2^ While some studies have highlighted the maternal benefits of elective C-sections,^3^ other research indicates that C-sections generally tend to be more costly than vaginal deliveries,^4^ are associated with higher rates of maternal rehospitalization and postpartum medical care utilization.^5,6^ Some research indicates potentially worse neonatal outcomes for C-section deliveries, including elevated risk of mortality.^7^ During this time, vaginal births after C-section (VBAC), which are associated with rare but serious complications including uterine scar rupture,^8^ have declined and further contributed to the growing number of repeat C-sections performed. More recent reviews contend that VBAC is a reasonable and safe choice for the majority of women with a prior C-section.^9^ Additionally, national clinical groups, such as the American College of Obstetrics and Gynecology (ACOG),^10^ have recommended against the routine use of episiotomies to assist vaginal births.

In light of the importance of childbirth-related hospitalizations in the health care system, it is important to quantify and understand changing trends in hospital procedures for childbirth. This Statistical Brief presents data from the Healthcare Cost and Utilization Project (HCUP) on childbirths occurring in U.S. community hospitals in 2008. All data are reported from the maternal perspective (i.e., reflecting the experience of the mother, not the newborn). Variations in the utilization and costs associated with childbirth-related hospitalizations are illustrated with a focused look at differences across mode of delivery and payer type. All differences between estimates noted in the text are statistically significant at the 0.05 level or better.

## Findings

Highlights

- In 2008, there were 4.2 million maternal childbirth-related hospitalizations (down from 4.5 million in 2007) totaling $18.9 billion in hospital costs.
- More than half of all maternal childbirth-related hospital stays were billed to private insurance (2.2 million), while 40 percent were billed to Medicaid (1.7 million).
- In 2008, 33 percent of childbirths were by C-section, up from 21 percent in 1997. In fact, C-sections were, overall, the most commonly performed operating room procedures in U.S. hospitals.
- The increase in repeat C-section delivery was coupled with a decrease in the rate of VBACs, which fell to 1 percent of all deliveries in 2008.
- C-sections accounted for 34 percent of all privately insured births, but only 28 percent of uninsured births.
- Reflecting changing practice patterns, there was also a 32 percent decrease in the use of forceps and a 60 percent decrease in episiotomies.

In 2008, women experienced 4.2 million childbirths in U.S. community hospitals, a decrease from the 4.5 million childbirths in 2007. Still, childbirth remained the most common reason for hospitalization; these stays accounted for 11 percent of all hospital stays. Childbirth-related hospitalizations totaled $18.9 billion in hospital costs, 5 percent of all inpatient hospital costs.

### Characteristics of childbirth-related hospitalizations by mode of delivery

Table 1 presents utilization, length of stay (LOS), and cost information for maternal hospitalizations associated with the delivery of infants in U.S. community hospitals by type of delivery. Across all types of delivery, the mean LOS was 2.6 days—it ranged considerably from 2.1 days for vaginal deliveries without complications to 4.5 days for C-sections with complications.

Table 1 Utilization, length of stay, and cost information for childbirth in U.S. community hospitals, by mode of delivery, 2008^*^

Type of delivery | Number of hospital stays | Mean length of stay (days) | Mean cost per stay | Total cost (in billions)
All types of delivery | 4,209,800 | 2.6 | $4,500 | $18.9
Vaginal delivery without complication | 2,387,800 | 2.1 | $3,400 | $8.1
Vaginal delivery with complication | 342,300 | 2.7^†^ | $4,400^†^ | $1.5
Vaginal delivery with sterilization &/or dilation and curettage (D&C) | 101,100 | 2.4 | $5,600 | $0.6
Vaginal delivery with operating room procedure except sterilization and/or D&C | 2,000 | 3.7 | $9,400 | $0.0
C-section without complication | 904,300 | 3.1 | $5,700 | $5.1
C-section with complication | 472,300 | 4.5 | $7,600 | $3.6

* Hospitalization for childbirth and delivery type identified by DRGs 765–768 and 774–775.

† Differences from vaginal delivery without complication not statistically significant at p < 0.05.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2008

On average, hospital deliveries cost $4,500 per stay, but the mean cost per stay varied depending on the mode of delivery. C-sections tended to be more costly than vaginal deliveries ($5,700 versus $3,400 without complications, and $7,600 versus $4,400 with complications, respectively). While uncommon, vaginal delivery with an operating room procedure (such as operative forceps or vacuum delivery) had the highest average cost ($9,400)—more than double the cost per stay for all types of delivery ($4,500). In total, vaginal deliveries accounted for 54 percent of annual hospital delivery costs ($10.2 billion), and C-sections accounted for the remaining 46 percent ($8.7 billion).

### Characteristics of childbirth-related hospitalizations by patient characteristics

Table 2 displays the number of hospital stays, average LOS, and cost information for maternal hospitalizations associated with childbirth by expected primary payer, geographic region, and age. More than half of all maternal childbirth-related hospital stays were billed to private insurance (2.2 million stays), while 40 percent were billed to Medicaid (1.7 million stays). The remaining 8 percent was billed to uninsured individuals, “other” insurance plans, or Medicare.^11^

Table 2 Utilization, length of stay, and cost information for the delivery of infants in U.S. community hospitals, by patient characteristics, 2008^*^

| Number of hospital stays for childbirth | Share of stays | Stays per 100 women of childbearing age^†^ | Mean length of stay (days) | Mean cost per stay | Total cost (in billions)
Payer
Medicare^‡^ | 30,100 | 1% | NA^§^ | 3.1 | $5,000^¶^ | $0.2
Medicaid | 1,698,900 | 40% | NA^§^ | 2.6 | $4,400^¶^ | $7.4
Private insurance | 2,213,400 | 53% | NA^§^ | 2.7 | $4,600 | $10.2
Uninsured | 150,500 | 4% | NA^§^ | 2.4 | $3,900 | $0.6
Other insurance | 112,900 | 3% | NA^§^ | 2.6^¶^ | $4,200 | $0.5
Region
Northeast | 684,200 | 16% | 6.2 | 2.9 | $5,300 | $3.6
Midwest | 951,800 | 23% | 7.1 | 2.6 | $4,400 | $4.2
South | 1,499,500 | 36% | 6.5 | 2.6 | $3,800 | $5.6
West | 1,074,200 | 26% | 7.4 | 2.5 | $5,100^¶^ | $5.4
Age
15–17\|\| | 131,500 | 3% | 2.1 | 2.6^¶^ | $4,200^¶^ | $0.6
18–44^**^ | 4,060,000 | 96% | 7.3 | 2.6 | $4,500 | $18.2

* Hospitalization for childbirth determined by DRGs 765–768 and 774–775. A small number of hospitalizations are missing corresponding payer data.

† Includes women age 15–44 years old.

‡ Medicare provides health insurance for a limited number of individuals with disabilities or with end-stage renal disease under the age of 65.

§ Not applicable: due to differences in the way that HCUP and the Census Current Population Survey determine insurer, we cannot accurately determine stays per female population of childbearing age.

¶ Differences from private insurance, Northeast, and age group 18–44, respectively, not statistically significant at p < 0.05.

|| Less than 1 percent of hospitalizations for childbirth were for girls 14 or younger.

** Less than 1 percent of hospitalizations for childbirth were for women 45 or older.

Sources: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2008

U.S. Census Bureau, Population Division, Annual Estimates of the Resident Population by Single-Year of Age and Sex for the United States and States: April 1, 2000 to July 1, 2009, last accessed February 17, 2011.

The rate of maternal childbirth-related hospital stays per women of childbearing age (15–44 years old) was similar across regions, ranging from 6.2 per 100 women to 7.4 per 100 women. Maternal childbirth-related hospital stays were highly concentrated among women age 18–44 (96 percent) with just 3 percent of stays for women 17 or younger and less than 1 percent of stays for women 45 older.

### Utilization of specific obstetrical procedures: C-sections, vaginal birth after C-section (VBAC), episiotomies, and use of forceps

Of the 4.2 million childbirths that occurred in U.S. hospitals in 2008, a third of cases (32.6 percent) were delivered via C-section—a 72 percent increase from 1997, when about a fifth of deliveries were performed via C-section (figure 1). In addition, the rate of repeat C-sections nearly doubled, from 8 percent in 1997 to 14 percent in 2008. During this time, the rate of VBACs dropped from 4 percent to 1 percent. As a result in 2008, nearly all childbirths after a previous C-section (91 percent) were repeat C-sections. In 1997, 65 percent of childbirths after previous C-sections were repeat C-sections and 35 percent were VBAC.

Figure 1 From 1997 to 2008, the rate of C-sections and repeat C-sections grew while the rate of vaginal births and VBACs decreased*

*Hospitalization for childbirth and delivery type identified by DRGs 370–375 for 1997–2007 and 765–768 and 774–775 for 2008. Previous C-section identified by ICD-9-CM all-listed diagnosis code of 654.20, 654.21, or 654.23.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 1997–2008

Stacked column bar chart in percentages; 1997, 75% non-VBAC vaginal birth; 4 percent, vaginal birth after C-section ( v b a c); 13 percent, first-time C-section; 8 percent, repeat C-section. 1998, 75% non-VBAC vaginal birth; 4 percent, vaginal birth after C-section ( v b a c); 13 percent, first-time C-section; 8 percent, repeat C-section. 1999, 74% non-VBAC vaginal birth; 4 percent, vaginal birth after C-section ( v b a c); 14 percent, first-time C-section; 8 percent, repeat C-section. 2000, 74% non-VBAC vaginal birth; 3 percent, vaginal birth after C-section ( v b a c); 14 percent, first-time C-section; 9 percent, repeat C-section. 2001, 72% non-VBAC vaginal birth; 3 percent, vaginal birth after C-section ( v b a c); 15 percent, first-time C-section; 10 percent, repeat C-section. 2002, 71% non-VBAC vaginal birth; 2 percent, vaginal birth after C-section ( v b a c); 16 percent, first-time C-section; 11 percent, repeat C-section. 2003, 69% non-VBAC vaginal birth; 2 percent, vaginal birth after C-section ( v b a c); 17 percent, first-time C-section; 12 percent, repeat C-section. 2004, 68% non-VBAC vaginal birth; 2 percent, vaginal birth after C-section ( v b a c); 18 percent, first-time C-section; 12 percent, repeat C-section. 2005, 67% non-VBAC vaginal birth; 1 percent, vaginal birth after C-section ( v b a c); 18 percent, first-time C-section; 13 percent, repeat C-section. 2006, 67% non-VBAC vaginal birth; 1 percent, vaginal birth after C-section ( v b a c); 18 percent, first-time C-section; 13 percent, repeat C-section. 2007, 66% non-VBAC vaginal birth; 1 percent, vaginal birth after C-section ( v b a c); 19 percent, first-time C-section; 14 percent, repeat C-section. 2008, 66% non-VBAC vaginal birth; 1 percent, vaginal birth after C-section ( v b a c); 18 percent, first-time C-section; 14 percent, repeat C-section.

As shown in figure 2, the share of childbirths delivered by C-section varied by payer and by geographic region. Private insurance had the highest share of C-sections (34 percent) versus vaginal deliveries while uninsured individuals had the lowest share (28 percent). C-sections accounted for 31 percent of childbirth-related hospitalizations billed to Medicaid. The South had the greatest share of C-sections (35 percent), while the Midwest had the lowest share (30 percent).

Figure 2 Share of childbirths delivered vaginally versus by C-section varied by payer and geographic region, 2008*

*Hospitalization for childbirth and delivery type identified by DRGs 765–768 and 774–775.

†Differences from Northeast rates not statistically significant at the 0.05 level.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2008

Stacked column bar chart in percentages; categorized by payer and then region; for all payers, vaginal birth, 67%, C-Section, 33%; private insurance, vaginal birth, 66%, C-section, 34%; Medicaid, vaginal birth, 69%, C-section, 31%; Uninsured, vaginal birth, 72%, C-section, 28%. Per region; Northeast, vaginal birth, 66%, C-Section, 34%; Midwest, vaginal birth, 70%, C-section, 30%; South, vaginal birth, 65%†, C-section, 35%†; West, vaginal birth, 69%, C-section, 31%.

The use of two obstetrical procedures associated with vaginal births has significantly declined (figure 3). Episiotomy is a surgical incision made into the perineum—the region between the vagina and the anus—to widen the vaginal opening for delivery. Forceps are used to aid in the delivery of the fetus by applying traction to the fetal head. From 1997 to 2008, the use of forceps decreased by 32 percent, and there were 60 percent fewer episiotomies.

Figure 3 The share of vaginal births with episiotomies and use of forceps decreased, reflecting changing practice patterns, 1997–2008*

*Hospitalization for childbirth and delivery type identified by DRGs 370–375 for 1997–2007 and 765–768 and 774–775 for 2008. Episiotomy identified by CCS all-listed procedure code of 133. Forceps identified by CCS all-listed procedure code of 135.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, HCUPnet, Nationwide Inpatient Sample, 1997–2008

Bar chart in percentages; 1997, 29% episiotomy; 14 percent, forceps. 1998, 26% episiotomy; 14 percent, forceps. 1999, 26% episiotomy; 12 percent, forceps. 2000, 24% episiotomy; 12 percent, forceps. 2001, 23% episiotomy; 12 percent, forceps, 2002, 20% episiotomy; 11 percent, forceps. 2003, 20% episiotomy; 11 percent, forceps. 2004, 18% episiotomy; 10 percent, forceps. 2005, 15% episiotomy; 10 percent, forceps. 2006, 13% episiotomy; 10 percent, forceps. 2007, 13% episiotomy; 10 percent, forceps. 2008, 12% episiotomy (episiotomies have decreased 60% since 1997.); 10 percent, forceps (The use of forceps has decreased 32% since 1997.).

## Data Source

The estimates in this Statistical Brief are based upon data from the HCUP 2008 Nationwide Inpatient Sample (NIS). Historical data were drawn from the 1997–2007 NIS. Some statistics were generated from HCUPnet, a free, online query system that provides users with immediate access to largest set of publicly available, all-payer national, regional, and State-level hospital care databases from HCUP.

## Definitions

### Procedures, Diagnoses, ICD-9-CM, Clinical Classifications Software (CCS), and Diagnosis-Related Groups (DRGs)

The principal procedure is the procedure that was performed for definitive treatment rather than performed for diagnostic or exploratory purposes (i.e., the procedure that was necessary to take care of a complication). If two procedures appear to meet this definition, the procedure most related to the principal diagnosis was selected as the principal procedure. All-listed procedures include all procedures performed during the hospital stay.

The principal diagnosis is that condition established after study to be chiefly responsible for the patient’s admission to the hospital. Secondary diagnoses are concomitant conditions that coexist at the time of admission or that develop during the stay. All-listed diagnoses include the principal diagnosis plus these additional secondary conditions.

ICD-9-CM is the International Classification of Diseases, Ninth Revision, Clinical Modification, which assigns numeric codes to diagnoses. There are about 13,600 ICD-9-CM diagnosis codes.

CCS categorizes ICD-9-CM diagnoses into a manageable number of clinically meaningful categories.^12^ This “clinical grouper” makes it easier to quickly understand patterns of diagnoses and procedures. DRGs comprise a patient classification system that categorizes patients into groups that are clinically coherent and homogeneous with respect to resource use. DRGs group patients according to diagnosis, type of treatment (procedures), age, and other relevant criteria. Each hospital stay has one DRG assigned to it.

### Case definition

For this report, the following codes were used to identify childbirth-related diagnoses and procedures:

– Childbirth-related hospitalization: DRGs 370–375 (1997–2007) and 765–768 and 774–775 (2008) (DRG numbering system changed in 2008)
– Vaginal birth: DRG codes 372–375 (1997–2007) and 767–768 and 774–775 (2008)
– C-section: DRG codes 370–375 (1997–2007) and 765–766 (2008) or CCS all-listed procedure code of 134
– Previous C-section: ICD-9-CM all-listed diagnosis code of 654.20, 654.21, or 654.23
– Episiotomy: CCS all-listed procedure code of 133
– Use of forceps: CCS all-listed procedure code of 135

### Types of hospitals included in HCUP

HCUP is based on data from community hospitals, defined as short-term, non-Federal, general and other hospitals, excluding hospital units of other institutions (e.g., prisons). HCUP data include OB-GYN, ENT, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded are long-term care, rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. Please note, a discharge of this nature will be included in the NIS if it occurred in a community hospital.

### Unit of analysis

The unit of analysis is the hospital discharge (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the hospital multiple times in one year will be counted each time as a separate “discharge” from the hospital.

### Costs and charges

Total hospital charges were converted to costs using HCUP Cost-to-Charge Ratios based on hospital accounting reports from the Centers for Medicare and Medicaid Services (CMS).^13^ Costs will tend to reflect the actual costs of production, while charges represent what the hospital billed for the case. For each hospital, a hospital-wide cost-to-charge ratio is used because detailed charges are not available across all HCUP States. Hospital charges reflect the amount the hospital charged for the entire hospital stay and does not include professional (physician) fees. For the purposes of this Statistical Brief, costs are reported to the nearest hundred.

### Payer

Payer is the expected primary payer for the hospital stay. To make coding uniform across all HCUP data sources, payer combines detailed categories into more general groups:

– Medicare includes fee-for-service and managed care Medicare patients.
– Medicaid includes fee-for-service and managed care Medicaid patients. Patients covered by the State Children’s Health Insurance Program (SCHIP) may be included here. Because most state data do not identify SCHIP patients specifically, it is not possible to present this information separately.
– Private insurance includes Blue Cross, commercial carriers, and private HMOs and PPOs.
– Other includes Worker’s Compensation, TRICARE/CHAMPUS, CHAMPVA, Title V, and other government programs.
– Uninsured includes an insurance status of “self-pay” and “no charge.

When more than one payer is listed for a hospital discharge, the first-listed payer is used.

### Region

Region is one of the four regions defined by the U.S. Census Bureau:

– Northeast: Maine, New Hampshire, Vermont, Massachusetts, Rhode Island, Connecticut, New York, New Jersey, and Pennsylvania
– Midwest: Ohio, Indiana, Illinois, Michigan, Wisconsin, Minnesota, Iowa, Missouri, North Dakota, South Dakota, Nebraska, and Kansas
– South: Delaware, Maryland, District of Columbia, Virginia, West Virginia, North Carolina, South Carolina, Georgia, Florida, Kentucky, Tennessee, Alabama, Mississippi, Arkansas, Louisiana, Oklahoma, and Texas
– West: Montana, Idaho, Wyoming, Colorado, New Mexico, Arizona, Utah, Nevada, Washington, Oregon, California, Alaska, and Hawaii

## For More Information

For more information about HCUP, visit www.hcup-us.ahrq.gov.

For additional HCUP statistics, visit HCUPnet, our interactive query system, at www.hcup.ahrq.gov.

For information on other hospitalizations in the U.S., download HCUP Facts and Figures: Statistics on Hospital-Based Care in the United States in 2008, located at http://www.hcup-us.ahrq.gov/reports.jsp.

For a detailed description of HCUP, more information on the design of the NIS, and methods to calculate estimates, please refer to the following publications:

Barrett M., Hunter K., Coffey R., Levit K. Population Denominator Data for Use with the HCUP Databases (Updated with 2009 Population Data). HCUP Methods Series Report # 2010-02. Online April 12, 2010. U.S. Agency for Healthcare Research and Quality. http://www.hcup-us.ahrq.gov/reports/methods/methods.jsp.

Introduction to the HCUP Nationwide Inpatient Sample, 2008. Online. May 2010. U.S. Agency for Healthcare Research and Quality. http://hcup-us.ahrq.gov/db/nation/nis/NIS_2008_INTRODUCTION.pdf.

Houchens, R., Elixhauser, A. Final Report on Calculating Nationwide Inpatient Sample (NIS) Variances, 2001. HCUP Methods Series Report #2003-2. Online. June 2005 (revised June 6, 2005). U.S. Agency for Healthcare Research and Quality. http://www.hcup-us.ahrq.gov/reports/methods/CalculatingNISVariances200106092005.pdf.

Houchens R.L., Elixhauser A. Using the HCUP Nationwide Inpatient Sample to Estimate Trends. (Updated for 1988Updated for 2004). HCUP Methods Series Report #2006-05 Online. August 18, 2006. U.S. Agency for Healthcare Research and Quality. http://www.hcup-us.ahrq.gov/reports/methods/2006_05_NISTrendsReport_1988-2004.pdf.

1 HCUP is based on data from community hospitals, defined as short-term, non-Federal, general and other hospitals, excluding hospital units of other institutions (e.g., prisons). HCUP data include OB-GYN, ENT, orthopedic, cancer, pediatric, public, and academic medical hospitals.

2 Macdorman M.F., Menacker F., Declercq E. Cesarean birth in the United States: epidemiology, trends, and outcomes. Clinical Perinatology, 2008; 35:293307.

3 National Institutes of Health. State of the Science Conference Statement. Cesarean delivery on maternal request. Obstetrics and Gynecology, 2006; 107: 1386–97.

4 Zupancic JAF. The economics of elective Cesarean section. Clinical Perinatology, 2008; 35:59199.

5 Lui T., Chen C., Lin H. Does elective Cesarean section increase utilization of postpartum maternal medical care? Medical Care, 2008; 46(4):44043.

6 Declercq E., Barger M., Cabral H.J., Evans S.R., Kotelchuck M., Simon C., Weiss J., Heffner L.J. Maternal outcomes associated with planned primary Cesarean section births compared with planned vaginal births. Obstetrics and Gynecology, 2007; 109(3):66977.

7 MacDorman M.F., Declercq E., Menacker F., Malloy M.H. Neonatal mortality for primary cesarean and vaginal births to low-risk women: application of an “intention to treat” model. Birth, 2008; 35(1):38.

8 Guise J., Berlin M., McDonagh M., Osterweil P., Chan B., Helfand M. Safety of vaginal birth after Cesarean: A systematic review. American College of Obstetricians and Gynecologists, 2004; 103(3):42029.

9 Agency for Healthcare Research and Quality. Vaginal Birth After Cesarean: New Insights, Structured Abstract. March 2010. Rockville, MD. http://www.ahrq.gov/clinic/tp/vbacuptp.htm.

10 Clinical practice guidelines from the American College of Obstetrics and Gynecology (ACOG) suggest that the best available data do not support the liberal or routine use of episiotomy (ACOG Practice Bulletin; #115, August 2010).

11 Medicare provides health insurance for a limited number of individuals with disabilities or end-stage renal disease under the age of 65.

12 HCUP CCS. Healthcare Cost and Utilization Project (HCUP). December 2009. U.S. Agency for Healthcare Research and Quality, Rockville, MD. www.hcup-us.ahrq.gov/toolssoftware/ccs/ccs.jsp.

13 HCUP Cost-to-Charge Ratio Files (CCR). Healthcare Cost and Utilization Project (HCUP). 2001–2008. U.S. Agency for Healthcare Research and Quality, Rockville, MD. www.hcup-us.ahrq.gov/db/state/costtocharge.jsp.