# Statistical Brief #108 Uninsured Hospitalizations, 2008

## Introduction

In 2008, an estimated 15.4 percent of the U.S. population was uninsured.^1^ By 2009, the uninsured share of the population grew to 16.7 percent.^2^ Trends in health insurance coverage are driven by several factors including changes in employer-sponsored health benefits, rates of unemployment, incomes of working families, costs of health insurance premiums, and the accessibility of public insurance programs.^3^

When there is no insurance coverage, hospitals bill patients directly. The resulting burden of payment for uninsured individuals and their families can be substantial, particularly during an economic downturn. Likewise, when these bills remain unpaid, the cost of uncompensated care represents a financial burden to hospitals and, ultimately, contributes to increases in health care costs to society overall.

This Statistical Brief presents data from the Healthcare Cost and Utilization Project (HCUP) Nationwide Inpatient Sample (NIS) on uninsured hospital stays in 2008. In the NIS, uninsured hospitalizations include those for which the patient was billed directly as well as those for which the hospital did not charge the patient or insurer (referred to as “no charge”). Note that although all such stays are uninsured, not all of them are uncompensated, as patients charged directly by the hospital may pay the bill in part or total.

In this Statistical Brief, characteristics of uninsured hospitalizations, such as utilization, cost, patient populations, and geographic locations are compared with the characteristics of insured hospital stays, that is, stays covered by Medicare, Medicaid, private health insurance and government programs such as Workers’ Compensation, TRICARE/CHAMPUS, CHAMPVA, and Title V. Changes in utilization by diagnosis and by procedure are compared in five year increments from 1998. All differences between estimates noted in the text are statistically significant at the 0.05 level or better.

## Findings

Highlights

- In 2008, the uninsured accounted for 2.1 million inpatient hospitalizations, or 5.3 percent of all U.S. community hospital stays.
- The number of uninsured hospital stays held fairly steady (−0.2 percent growth) between 1998 and 2003, but grew by 21.0 percent between 2003 and 2008.
- Compared to insured stays, uninsured hospitalizations were typically shorter (3.8 days versus 4.7 days) and cost less (average cost per stay of ($7,300 versus $9,200). Even when the elderly were excluded, uninsured stays remained shorter and less expensive than insured stays.
- A larger share of hospital stays in the South were uninsured (7.6 percent) compared to 4.9 percent in the Midwest, 3.6 percent in the West, and 3.2 percent in the Northeast.
- Uninsured hospitalizations accounted for 8.3 percent of stays in public hospitals. In private, for-profit hospitals, 5.5 percent of all stays were uninsured, and in private, not-for-profit hospitals, 4.7 percent of all stays were uninsured.
- Childbirth was the most common reason for an uninsured stay.
- The largest growth in uninsured stays was for skin infections, gallbladder disease, and diabetes complications.

In 2008, the uninsured accounted for 2.1 million inpatient hospitalizations, or 5.3 percent of all U.S. community hospital stays (table 1). Altogether, uninsured hospitalizations accounted for 4.3 percent of the aggregate costs of inpatient hospital care. Between 1998 and 2008, growth in the number of uninsured hospitalizations (20.8 percent) outpaced growth in insured hospitalizations (14.0 percent).

Table 1 Characteristics of uninsured and insured hospital stays, 2008

| Uninsured stays | Insured stays
Stays for all patients
Number of hospital stays (percentage of all stays) | 2,126,300 5.3% | 37,758,800 94.7%
Growth in number of stays, 1998–2008 (percentage growth) | 20.8% | 14.0%
Mean length of stay, days^‡^ | 3.8 | 4.7
Hospital costs
Mean cost per stay, dollars^‡^ | $ 7,300 | $ 9,200
Aggregate costs, billion dollars (percentage of all costs) | $ 15.5 4.3% | $ 348.6 95.7%
Discharge status ‡
Released to another institution or short term hospital | 5.3% | 15.3%
Left against medical advice | 3.4% | 0.8%
Discharged to home health care | 2.7% | 10.3%
Died in the hospital | 1.4% | 2.1%
Routine | 87.2% | 71.5%
Severity of illness measures
Patients with at least one therapeutic procedure | 19.4% | 22.0%
Patients on mechanical ventilation^‡^ | 0.1% | 0.2%
Number of chronic conditions (mean)^‡^ | 2.5 | 3.5
Cases with highest severity of illness^‡^ | 17.6% | 26.8%
Stays for non-elderly patients *
Number of hospital stays | 2,040,400 | 23,838,700
Mean length of stay, days, for non-elderly patients^‡^ | 3.7 | 4.1
Hospital costs for non-elderly patients
Mean cost per stay, dollars^‡^ | $ 7,100 | $ 8,100
Severity of illness measures for non-elderly patients
Patients with at least one therapeutic procedure | 19.1% | 20.8%
Patients on mechanical ventilation^‡^ | 0.1% | 0.3%
Number of chronic conditions (mean) | 2.4 | 2.4
Cases with highest severity of illness | 16.8% | 17.6%

‡ Differences between uninsured stays and insured stays were statistically significant at p<0.05.

* Statistics are presented for the non-elderly population because the majority of elderly patients (age 65+) qualify for Medicare coverage.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2008

As shown in table 1, uninsured hospitalizations were typically shorter in length and cost less than insured stays (3.8 days versus 4.7 days; average cost per stay of $7,300 versus $9,200). However, when patients age 65 or older were excluded from both groups, characteristics of uninsured and insured stays became less divergent. Because most patients age 65 and older are covered by Medicare, uninsured stays are predominantly for patients younger than 65. Even with the exclusion of older patients, uninsured stays remained shorter (3.7 days versus 4.1 days) and cost less (average cost per stay of $7,100 versus $8,100) than insured stays.

Uninsured hospitalizations more frequently resulted in discharge against medical advice than did insured stays (3.4 percent versus 0.8 percent), and less frequently resulted in release to another institution or short term hospital (5.3 percent versus 15.3 percent) or a discharge to home health care (2.7 percent versus 10.3 percent).

Overall, hospitalized uninsured patients had fewer recorded chronic conditions than insured hospital patients (2.5 versus 3.5 chronic conditions per patient), a smaller portion were on mechanical ventilation (0.1 percent of uninsured, 0.2 percent of insured), and cases were not as severely ill (17.6 percent of uninsured cases had highest severity of illness, 26.8 percent of insured cases had highest severity of illness).

When patients age 65 or older were excluded from each group, the percent of patients on mechanical ventilation (0.1 percent of uninsured, 0.3 percent of insured) was the only severity of illness measure for which there was a difference between the uninsured and insured patients.

Table 2 shows that uninsured hospital patients were more likely to be male, more likely to be younger, and more likely to reside in poorer communities than were insured patients. More than half of uninsured hospitalizations were for men (51.9 percent); in contrast, men accounted for just 40.9 percent of insured hospitalizations. The mean age of uninsured hospital patients was 36.2 years, 13 years younger than the mean age of insured hospital patients (49.2 years). Focusing just on the non-elderly hospitalized population, nearly half of all uninsured patients (49.0 percent) were ages 18–44. More than one-third (36.2%) of uninsured stays were for patients residing in the poorest communities (lowest median income ZIP Codes), compared to 27.7% of insured stays.

Table 2 Characteristics of patients with uninsured hospital stays and with insured hospital stays, 2008

| Uninsured stays | Insured stays
Number of hospital stays | 2,126,300 | 37,758,800
Gender ‡
Male | 51.9% | 40.9%
Female | 48.1% | 59.1%
Age characteristics
Mean patient age^‡^ | 36.2 | 49.2
Age distribution^‡^
<1 years | 12.4% | 12.4%
1–17 years | 2.5% | 3.6%
18–44 years | 47.1% | 23.9%
45–64 years | 34.1% | 23.3%
65+ years | 3.9% | 36.8%
Age distribution for non-elderly patients^‡,*^
<1 years | 12.9% | 19.7%
1–17 years | 2.6% | 5.6%
18–44 years | 49.0% | 37.9%
45–64 years | 35.5% | 36.8%
Median community-level income ‡
First quartile (poorest communities) | 36.2% | 27.7%
Second quartile | 28.9% | 27.4%
Third quartile | 21.0% | 23.0%
Fourth quartile (wealthiest communities) | 13.9% | 21.9%

‡ Differences between uninsured stays and insured stays were statistically significant at p<0.05.

* Age distribution is presented for the non-elderly population because the majority of elderly patients (age 65+) qualify for Medicare coverage

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2008

### Uninsured hospitalizations and costs by hospital type, 2008

As shown in figure 1, the South had the largest percent of uninsured hospitalizations (7.6 percent), followed by the Midwest, where 4.9 percent of stays were uninsured. The uninsured made up smaller portions of all hospital stays in the West (3.6 percent) and the Northeast (3.2 percent). The share of costs attributable to uninsured stays followed similar regional patterns, with uninsured stays responsible for 6.2 percent of inpatient hospital costs in the South, 4.1 percent in the Midwest, 3.0 percent in the West, and 2.4 percent in the Northeast.

Figure 1 Uninsured share of all discharges and of aggregate costs by hospital type, 2008

* Differences between uninsured stays and insured stays were statistically significant at p<0.05.

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 2008

Bar chart, in percentages, by region, owner, bed size, location, and teaching status; Text following the asterisk reads as follows: “Differences between uninsured stays and insured stays were statistically significant at p<0.05.” Region*; uninsured share of discharges; Northeast, 3.2%; Midwest, 4.9%; South, 7.6%; West, 3.6%. Region*; uninsured share of aggregate costs; Northeast, 2.4%; Midwest, 4.1%; South, 6.2%; West, 3.0%. Owner*; uninsured share of discharges; Private, for profit; 5.5%; Private, not-for-profit; 4.7%; Public; 8.3%. Owner *; uninsured share of aggregate costs; Private, for profit; 4.3%; Private, not-for-profit; 3.7%; Public; 6.5%. Bed size; uninsured share of discharges; large; 5.5%; medium; 5.3%; small; 4.3%. Bed size; uninsured share of aggregate costs; large; 4.4%; medium; 4.3%; small; 3.2%. Location; uninsured share of discharges; urban; 5.4%; rural; 5.2%. Location; uninsured share of aggregate costs; large; 5.2%; medium; 4.2%. Teaching status; uninsured share of discharges; teaching; 5.6%; nonteaching; 5.1%. Teaching status; uninsured share of aggregate costs; teaching; 4.4%; nonteaching; 4.1%.

Across all publicly owned hospitals, uninsured hospital stays accounted for 8.3 percent of total stays—the largest share of uninsured hospitalizations for any ownership type. In private, for-profit hospitals, 5.5 percent of all stays were uninsured, and in private, not-for-profit hospitals, 4.7 percent of all stays were uninsured. Aggregate costs followed a similar pattern: uninsured stays accounted for 6.5 percent of public hospital costs, 4.3 percent of private, for-profit hospital costs, and 3.7 percent of private, not-for-profit hospital costs.

The share of uninsured discharges and the share of costs did not vary much among hospitals of different bed sizes, different locations (urban/rural) or different teaching statuses.

### Most common principal diagnoses associated with uninsured hospitalizations, 1998–2008

Table 3 shows the top reasons for uninsured hospital stays in 1998, 2003 and 2008, and growth in uninsured stays for these conditions. The number of uninsured hospital stays held steady during the first six-year period (−0.2 percent growth between 1998 and 2003), but grew appreciably during the latter year period (21.0 percent growth between 2003 and 2008).

Table 3 Top 10 reasons for hospital stays among the uninsured, 1998, 2003, and 2008

Principal diagnosis | 1998 | 2003 | 2008 | Growth 1998–2003 | Growth 2003–2008
All hospital stays | 34,874,000 | 38,220,700 | 39,885,100 | 9.6% | 4.4%
All uninsured hospital stays (percentage of stays) | 1,759,800 5.0% | 1,757,100 4.6% | 2,126,300 5.3% | −0.2% | 21.0%
Liveborn | 201,900 11.5% | 191,900 10.9% | 240,400 11.3% | −5.0% | 25.3%
Mood disorders | 64,600 3.7% | 69,110 3.9% | 79,300 3.7% | 7.0% | 14.7%
Nonspecific chest pain | 45,200 2.6% | 62,600 3.6% | 68,100 3.2% | 38.5% | 8.8%
Skin infections | 31,000 1.8% | 43,000 2.4% | 66,600 3.1% | 38.7% | 54.9%
Alcohol-related disorders | 55,100 3.1% | 45,000 2.6% | 60,700 2.9% | −18.3% | 34.9%
Diabetes mellitus with complications | 33,400 1.9% | 37,100 2.1% | 51,900 2.4% | 11.1% | 39.9%
Pneumonia | 53,400 3.0% | 44,100 2.5% | 47,200 2.2% | −17.4% | 7.0%
Substance-related disorders | 45,200 2.6% | 43,800 2.5% | 42,500 2.0% | −3.1% | −3.0%
Biliary tract disease | 25,500 1.4% | 29,400 1.7% | 42,000 2.0% | 15.3% | 42.9%
Acute myocardial infarction | 29,800 1.7% | 33,800 1.9% | 40,400 1.9% | 13.4% | 19.5%

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 1999 and 2008

In 2008, newborns accounted for 11 percent of uninsured hospital stays. Three of the top ten reasons for uninsured stays were related to mental illness or substance use (mood disorders, alcohol-related disorders, and substance use disorders); and two of the top ten reasons were related to the cardiovascular system (nonspecific chest pain and acute myocardial infarction).

Despite no change in the overall number of uninsured stays from 1998 to 2003, stays for nonspecific chest pain and skin infections grew by 38.5 percent and 38.7 percent respectively. From 2003 to 2008, stays for skin infections grew by 54.9 percent, stays for biliary tract disease grew by 42.9 percent, and stays for diabetes mellitus with complications grew by 39.9 percent, outpacing overall increases in uninsured stays.

### Most common principal procedures associated with uninsured hospitalizations, 1998–2008

Table 4 shows the top ten procedures for uninsured hospital stays in 1998, 2003, and 2008. Alcohol and drug rehabilitation/detoxification was the most frequent principal procedure among uninsured stays. Other common principal procedures performed during uninsured hospital stays included respiratory intubation and mechanical ventilation, childbirth-related procedures (cesarean section, circumcision, and repair of current obstretric laceration), and heart procedures (diagnostic cardiac catheterization and percutaneous coronary angioplasty (PTCA)).

Table 4 Top 10 principal procedures for hospital stays among the uninsured, 1998, 2003, and 2008

Principal procedure | 1998 | 2003 | 2008 | Growth 1998–2003 | Growth 2003–2008
All hospital stays | 34,874,000 | 38,220,700 | 39,885,100 | 9.6% | 4.4%
All uninsured stays (percentage of stays) | 1,759,800 5.0% | 1,757,100 4.6% | 2,126,300 5.3% | −0.2% | 21.0%
Alcohol and drug rehabilitation/detoxification | 73,900 4.2% | 62,200 3.5% | 69,000 3.2% | −15.8% | 10.9%
Respiratory intubation and mechanical ventilation | 28,500 1.6% | 31,300 1.8% | 45,800 2.2% | 9.8% | 46.3%
Upper gastrointestinal endoscopy, biopsy | 29,400 1.7% | 32,900 1.9% | 43,400 2.0% | 11.9% | 31.9%
Cesarean section | 23,300 1.3% | 31,200 1.8% | 42,100 2.0% | 33.9% | 34.9%
Circumcision | 41,400 2.4% | 37,600 2.1% | 41,800 2.0% | −9.2% | 11.2%
Cholecystectomy and common duct exploration | 21,700 1.2% | 25,500 1.5% | 37,200 1.7% | 17.5% | 45.9%
Diagnostic cardiac catheterization, coronary arteriography | 26,000 1.5% | 32,500 1.8% | 36,600 1.7% | 25.0% | 12.6%
Percutaneous coronary angioplasty (PTCA) | 15,200 0.9% | 23,000 1.3% | 36,200 1.7% | 51.3% | 57.4%
Appendectomy | 28,600 1.6% | 32,100 1.8% | 35,100 1.7% | 12.2% | 9.3%
Repair of current obstetric laceration | 25,000 1.4% | 19,900 1.1% | 27,700 1.3% | −20.4% | 39.2%

Source: AHRQ, Center for Delivery, Organization, and Markets, Healthcare Cost and Utilization Project, Nationwide Inpatient Sample, 1999 and 2008

Between both 1998 and 2003, and 2003 and 2008, growth in the number of uninsured stays with a percutaneous coronary angioplasty (PTCA) procedure grew rapidly (51.3 percent and 57.4 percent growth in each period respectively). Cesarean section was the next procedure for which there was rapid growth during both periods (33.9 percent and 34.9 percent growth in each period respectively). A few procedures grew more rapidly during the latter period (2003–2008) than the earlier period: respiratory intubation and mechanical ventilation (46.3 percent growth between 2003 and 2008), cholecystectomy and common duct exploration (45.9 percent growth between 2003 and 2008), and repair of current obstetric laceration (39.2 percent growth between 2003 and 2008).

While alcohol and drug rehabilitation/detoxification remained the top procedure for uninsured hospital stays in the time-period spanning 1998 to 2008, use of this procedure grew at a slower rate than most other frequent procedures.

## Data Source

The estimates in this Statistical Brief are based upon data from the 2008 HCUP Nationwide Inpatient Sample. Historical data were drawn from the 1998 and 2003 NIS.

## Definitions

### Diagnoses, ICD-9-CM, and Clinical Classifications Software (CCS)

The principal diagnosis is that condition established after study to be chiefly responsible for the patient’s admission to the hospital. Secondary diagnoses are concomitant conditions that coexist at the time of admission or that develop during the stay.

ICD-9-CM is the International Classification of Diseases, Ninth Revision, Clinical Modification, which assigns numeric codes to diagnoses. There are about 13,600 ICD-9-CM diagnosis codes.

CCS categorizes ICD-9-CM diagnoses into a manageable number of clinically meaningful categories. This “clinical grouper” makes it easier to quickly understand patterns of diagnoses and procedures.

### Types of hospitals included in HCUP

HCUP is based on data from community hospitals, defined as short-term, non-Federal, general and other hospitals, excluding hospital units of other institutions (e.g., prisons). HCUP includes data from OB-GYN, ENT, orthopedic, cancer, pediatric, public, and academic medical hospitals. Excluded are long-term care, rehabilitation, psychiatric, and alcoholism and chemical dependency hospitals. However, if a patient received long-term care, rehabilitation, or treatment for psychiatric or chemical dependency conditions in a community hospital, the discharge record for that stay will be included in the NIS.

### Unit of analysis

The unit of analysis is the hospital discharge (i.e., the hospital stay), not a person or patient. This means that a person who is admitted to the hospital multiple times in one year will be counted each time as a separate “discharge” from the hospital.

### Costs and charges

Total hospital charges were converted to costs using HCUP cost-to-charge ratios based on hospital accounting reports from the Centers for Medicare and Medicaid Services (CMS).^4^ Costs will reflect the actual expenses incurred in the production of hospital services, such as wages, supplies and utility costs, while charges represent the amount a hospital billed for the case. For each hospital, a hospital-wide cost-to-charge ratio is used. Hospital charges reflect the amount the hospital billed for the entire hospital stay and do not include professional (physician) fees. For the purposes of this Statistical Brief, costs are reported to the nearest hundreds.

### Hospital location

The classification of whether a hospital is in a metropolitan area (“urban”) or non-metropolitan area (“rural”), is defined from the American Hospital Association (AHA) Annual Survey using the 1993 U.S. Office of Management and Budget definition.

### Median community-level income

Median community-level income is the median household income of the patient’s ZIP Code of residence. The cut-offs for the quartile designation are determined using ZIP Code demographic data obtained from Claritas. The income quartile is missing for homeless and foreign patients.

### Payer

Payer is the expected primary payer for the hospital stay. To make coding uniform across all HCUP data sources, payer combines detailed categories into more general groups:

– Medicare includes fee-for-service and managed care Medicare patients.
– Medicaid includes fee-for-service and managed care Medicaid patients. Patients covered by the State Children’s Health Insurance Program (SCHIP) may be included here. Because most state data do not identify SCHIP patients specifically, it is not possible to present this information separately.
– Private insurance includes Blue Cross, commercial carriers, and private HMOs and PPOs.
– Other includes Workers’ Compensation, TRICARE/CHAMPUS, CHAMPVA, Title V, and other government programs.
– Uninsured includes an insurance status of “self-pay” and “no charge.”

When more than one payer is listed for a hospital discharge, the first-listed payer is used.

### Region

Region is one of the four regions defined by the U.S. Census Bureau:

– Northeast: Maine, New Hampshire, Vermont, Massachusetts, Rhode Island, Connecticut, New York, New Jersey, and Pennsylvania
– Midwest: Ohio, Indiana, Illinois, Michigan, Wisconsin, Minnesota, Iowa, Missouri, North Dakota, South Dakota, Nebraska, and Kansas
– South: Delaware, Maryland, District of Columbia, Virginia, West Virginia, North Carolina, South Carolina, Georgia, Florida, Kentucky, Tennessee, Alabama, Mississippi, Arkansas, Louisiana, Oklahoma, and Texas
– West: Montana, Idaho, Wyoming, Colorado, New Mexico, Arizona, Utah, Nevada, Washington, Oregon, California, Alaska, and Hawaii

### Discharge status

Discharge status indicates the disposition of the patient at discharge from the hospital, and includes the following six categories: routine (to home), transfer to another short-term hospital, other transfers (including skilled nursing facility, intermediate care, and another type of facility such as a nursing home), home health care, against medical advice (AMA), or died in the hospital.

### Patient complexity

Cases with the highest severity of illness are discharges with a score of 3 or 4 on the APR-DRG severity of illness scale. The four severity of illness subclasses are numbered sequentially from 1 to 4 indicating minor, moderate, major, or extreme severity of illness. The determination of severity of illness is disease-specific. Thus, the significance attributed to complicating or comorbid conditions is dependent on the underlying problem. For example, certain types of infections are considered a more significant problem in a patient who is immunosuppressed than in a patient with a fractured arm. In APR-DRGs, high severity of illness is primarily determined by the interaction of multiple diseases. Patients with multiple comorbid conditions involving multiple organ systems represent difficult-to-treat patients who tend to have poor outcomes. The assignment of a patient to a severity of illness subclass takes into consideration not only the level of the secondary diagnoses but also the interaction among secondary diagnoses, age, principal diagnosis, and the presence of certain OR procedures and non-OR procedures.

Percentage with at least one major therapeutic procedure: All procedures were determined to be major (i.e., requiring an operating room) or minor and therapeutic or diagnostic based on the Procedure Classes which can be found at: http://www.hcup-us.ahrq.gov/toolssoftware/procedure/procedure.jsp.

Percentage on mechanical ventilation was calculated as the percentage of patients in the hospital who have ICD-9-CM procedure codes 96.70–96.72

Mean number of chronic conditions per patient: All diagnoses on all records were determined to be either chronic or non-chronic. The definition of chronic conditions was based on the Chronic Condition Indicator which can be found at: http://www.hcup-us.ahrq.gov/toolssoftware/chronic/chronic.jsp.

## For More Information

For more information about HCUP, visit www.hcup-us.ahrq.gov.

For additional HCUP statistics, visit HCUPnet, our interactive query system, at www.hcup.ahrq.gov.

For information on other hospitalizations in the U.S., download HCUP Facts and Figures: Statistics on Hospital-based Care in the United States in 2008, located at http://www.hcup-us.ahrq.gov/reports.jsp.

For a detailed description of HCUP, more information on the design of the NIS, and methods to calculate estimates, please refer to the following publications:

Steiner, C., Elixhauser, A., Schnaier, J. The Healthcare Cost and Utilization Project: An Overview. Effective Clinical Practice 5(3):143–51, 2002.

Introduction to the HCUP Nationwide Inpatient Sample, 2008. Online. May 2010. U.S. Agency for Healthcare Research and Quality. http://hcup-us.ahrq.gov/db/nation/nis/NIS_2008_INTRODUCTION.pdf

Houchens, R., Elixhauser, A. Final Report on Calculating Nationwide Inpatient Sample (NIS) Variances, 2001. HCUP Methods Series Report #2003-2. Online. June 2005 (revised June 6, 2005). U.S. Agency for Healthcare Research and Quality. http://www.hcup-us.ahrq.gov/reports/CalculatingNISVariances200106092005.pdf

Houchens R.L., Elixhauser A. Using the HCUP Nationwide Inpatient Sample to Estimate Trends. (Updated for 1988–2004). HCUP Methods Series Report #2006-05 Online. August 18, 2006. U.S. Agency for Healthcare Research and Quality. http://www.hcup-us.ahrq.gov/reports/2006_05_NISTrendsReport_1988-2004.pdf

1 Chu, M.C. and Rhoades, J.A. The Uninsured in America, 1996–2009: Estimates for the U.S. Civilian Noninstitutionalized Population under Age 65. Statistical Brief #290. August 2010. Agency for Healthcare Research and Quality, Rockville, MD. http://www.meps.ahrq.gov/mepsweb/data_files/publications/st290/stat290.pdf (March 7, 2011).

2 DeNavas-Walt, Carmen, Bernadette D. Proctor, and Jessica C. Smith, U.S. Census Bureau, Current Population Reports, P60-238, Income, Poverty, and Health Insurance Coverage in the United States: 2009, U.S. Government Printing Office, Washington, DC, 2010.

3 The Kaiser Family Foundation. Health Coverage & the Uninsured: Trends in Health Coverage. Retrieved from: http://www.kff.org/uninsured/trends.cfm (March 16, 2011).

4 HCUP Cost-to-Charge Ratio Files (CCR). Healthcare Cost and Utilization Project (HCUP). 2001–2008. U.S. Agency for Healthcare Research and Quality, Rockville, MD. www.hcup-us.ahrq.gov/db/state/costtocharge.jsp.