# HCUP AND ITS DATA PARTNERS

HCUP is a family of health care databases and related software tools and products developed through a Federal-State-Industry partnership and sponsored by the Agency for Healthcare Research and Quality (AHRQ). HCUP databases bring together the data collection efforts of state data organizations, hospital associations, private data organizations, and the Federal government to create a national information resource of encounter-level health care data. The HCUP Partnership has grown from 8 states in 1988 to 45 states in 2011, and it would not be possible without the current contributions from the following data collection Partners:

- Alaska State Hospital & Nursing Association
- Arizona Department of Health Services
- Arkansas Department of Health
- California Office of Statewide Health Planning and Development
- Colorado Hospital Association
- Connecticut Hospital Association
- Florida Agency for Health Care Administration
- Georgia Hospital Association
- Hawaii Health Information Corporation
- Illinois Department of Public Health
- Indiana Hospital Association
- Iowa Hospital Association
- Kansas Hospital Association
- Kentucky Cabinet for Health and Family Services
- Louisiana Department of Health and Hospitals
- Maine Health Data Organization
- Maryland Health Services Cost Review Commission
- Massachusetts Division of Health Care Finance and Policy
- Michigan Health & Hospital Association
- Minnesota Hospital Association
- Missouri Hospital Industry Data Institute
- Montana MHA An Association of Montana Health Care Providers
- Nebraska Hospital Association
- Nevada Department of Health and Human Services
- New Hampshire Department of Health & Human Services
- New Jersey Department of Health and Senior Services
- New Mexico Health Policy Commission
- New York State Department of Health
- North Carolina Department of Health and Human Services
- Ohio Hospital Association
- Oklahoma State Department of Health
- Oregon Association of Hospitals and Health Systems
- Pennsylvania Health Care Cost Containment Council
- Rhode Island Department of Health
- South Carolina State Budget & Control Board
- South Dakota Association of Healthcare Organizations
- Tennessee Hospital Association
- Texas Department of State Health Services
- Utah Department of Health
- Vermont Association of Hospitals and Health Systems
- Virginia Health Information
- Washington State Department of Health
- West Virginia Health Care Authority
- Wisconsin Department of Health Services
- Wyoming Hospital Association