# ACKNOWLEDGMENTS

Thanks to Eva Witt and Jayna Dickens (Thomson Reuters) for programming support; Nancy Jordan (Thomson Reuters) for editorial assistance; and Kathy Hickey (Thomson Reuters) for creating Web documents. This report draws from and updates previously published HCUP Fact Books and Statistical Briefs, which can be accessed at http://www.hcup-us.ahrq.gov/reports.jsp and http://www.hcup-us.ahrq.gov/reports/statbriefs/statbriefs.jsp.