# ACKNOWLEDGMENTS

Funding to produce section five of this year’s report, which details trends in inpatient and emergency department care for mental health and substance abuse conditions, was provided by the Substance Abuse and Mental Health Services Administration (SAMHSA).

Thanks to Eva Witt and Nils Nordstrand (Thomson Reuters) for programming support; Nancy Jordan (Thomson Reuters) for editorial assistance; and Kathy Hickey (Thomson Reuters) for creating Web documents. This report draws from and updates previously published HCUP Fact Books and Statistical Briefs, which can be accessed at http://www.hcup-us.ahrq.gov/reports.jsp and http://www.hcup-us.ahrq.gov/reports/statbriefs.jsp.